# Acknowledgments

We would like to thank Dr. Pasqualina Santaguida and Dr. Cynthia Balion for their helpful insights and guidance during the development of this report.

We also thank our librarian, Maureen Rice, for her thorough management of search terms and project methodology. We would also like to thank the following people who assisted with screening and data extraction: Sameer Rawal, Connie Freeborn, Maureen Rice, Mary Gauld, and Lynda Booker. Thank you to Mary Gauld for her assistance with project coordination and to Karen Siegel for being our Task Order Officer.

Thank you to our editorial staff, Cecile Royer, Roxanne Cheeseman, and Maureen Rice for providing invaluable input into this document, as well as to Rashmi D’Mello for her assistance managing data.