# Discussion

## Diagnosis

Question 1. What is the performance of diagnostic tests for preclinical and/or clinically significant lymphedema?

a) What inclusion criteria (including patient demographics, signs, and symptoms) were used in studies evaluating the performance of diagnostic tests of lymphedema?

Most of the diagnosis studies involved persons with breast cancer. Caution must be used when applying the results of diagnosis studies done in one patient population to another population as the specific characteristics of a test might not be easily transferrable. For example, a test developed for assessing lymphedema in persons with breast cancer may contain built-in nuances from this disease population, thereby rendering it non-transferrable to other populations. All diagnostic tests should be validated in the population of interest before widespread use in that population.

The age range of persons in the 41 studies was wide enough to encompass younger, non-diseased persons who were used as comparators in some of the diagnostic testing publications. The generally middle-aged nature of study subjects reflected the fact that most studies involved cancer patients, who are typically diagnosed and treated in middle age or later.

b) Is there any “gold standard” method to formally grade or measure the severity of lymphedema?

Only three of the studies in the diagnostic testing portion of this report contained methods to grade the severity of lymphedema.81,83,92 The methods were either non-validated,83 vaguely defined,92 or both.81 None of the methods was described as a gold standard.

The remaining diagnostic studies were conducted with the intent of evaluating tests that would differentiate persons with and without lymphedema. There was no attempt to stage the severity of lymphedema in any of these studies.

Based on the evidence from the extracted studies, there does not appear to be a gold standard for grading the severity of lymphedema.

c) What comparators were used in the studies of diagnostic tests? Was the test compared to a “gold standard”, bedside exam, radiologic investigation, or other means?

Although rarely identified as gold standards, the frequency of use of different measures of limb volume or circumference would suggest that these measures are the de facto gold standards for diagnosing secondary lymphedema. Furthermore, the consistent reliability and validity of these measures (see Question 1e) indicates that they are well suited for use as gold standards. It should be recognized that among lymphedema researchers, some will accept a gold standard such as limb volume assessed through water displacement, but there is no evidence to suggest a definitive gold standard.77 However, based on the extent of use, as well as the consistent evidence for reliability and validity, it is recommended that limb volume or circumference be considered the gold standard for diagnosing secondary lymphedema.

Interestingly, in the narrative review (see Chapter 1), the medical textbook literature suggests that imaging tests such as ultrasound and lymphoscintigraphy should be used as gold standards to diagnose lymphedema. However, few of the extracted studies included ultrasound or lymphoscintigraphy; studies that included these imaging tests did not consider them to be gold standards. Rather, these tests were evaluated as index tests (the tests under investigation).

d) What is the sensitivity and specificity of tests used to diagnose lymphedema?

In the eight studies that contained examinations of the sensitivity and specificity of diagnostic tests for secondary lymphedema, sensitivities ranged from 5 to 100 percent and specificities ranged from 71 to 100 percent. However, it was not possible to rank order the tests in terms of performance because there were too few studies from which to permit generalization, persons with three different underlying conditions were the subject of the studies (breast cancer, melanoma, Kaposi’s Sarcoma), a mix of different tests were used (changes in circumference with different cut points, self reports, imaging), and several different reference standards were also used. Researchers must use a common reference standard as a first step to providing a clearer picture of the sensitivity and specificity of tests in persons with secondary lymphedema.

e) What are the psychometric properties (reliability, validity, responsiveness) of these diagnostic methods?

Reliability. There is consistent evidence to indicate that lymphedema can be reliably measured using circumferential measures or volume displacement. It should be noted that these studies were conducted in breast cancer patients with secondary lymphedema primarily in the upper extremities. One study pertained to the trunk of the body.86 The excellent reliability of these measures might not be transferable to situations where lymphedema occurs in other parts of the body, or to cases where lymphedema occurs secondarily to other diseases besides breast cancer.

There is too little evidence to draw conclusions about the reliability of other tests such as tonometry, ultrasound, lymphoscintigraphy, or bioimpedance.

Validity. Twenty-three of the 30 validity studies involved some use of volume displacement or limb circumference as a diagnostic test for secondary lymphedema. Based on consistently high correlation coefficients, there is strong evidence that displacement and circumference are interchangeable amongst one another in terms of results. This interchangeability applies despite the various means of measuring displacement or circumference.

Tests involving bioimpedance show good validity when compared to tape measured circumference or perometry, although the correlation coefficients were not as high as the coefficients in the displacement-circumference comparisons. Self reported symptoms on the Lymphedema and Breast Cancer Questionnaire (LBCQ) also show good validity in comparison to bioimpedance, perometer, and tape measure, although the evidence is limited to a single study and correlation coefficients were also lower than the ones calculated for the displacement-circumference comparisons.71

The validity of ultrasound, lymphoscinitgraphy, CT scan, or MRI was evaluated in four studies. There is little evidence for the validity of these tests owing to the limited number of studies, small sample sizes, a questionable reference standard in one study,92 and questionable means of scoring lymphoscinitgraphy in two studies.81,92

Given the limited extent to which the LBCQ has been examined as a diagnostic tool for secondary lymphedema, and the lower correlation coefficients found in the bioimpedance studies, the evidence suggests that volume displacement or limb circumference are the most valid means of diagnosing secondary lymphedema. Most of the validity studies included breast cancer patients, so the conclusions about validity may not be wholly transferrable to other disease groups. Further work must be done to establish the diagnostic validity of these tests in populations other than persons with breast cancer.

Responsiveness. There is a dearth of evidence on the responsiveness to change of diagnostic tests for secondary lymphedema. Only two of the studies included in this report28,31 evaluated responsiveness to change; both were conducted in the breast cancer population. Researchers in the field should certainly be cognizant of the results of these studies if they choose water displacement, limb circumference, or tissue resistance as a means of testing for lymphedema in their own research projects. However, more work needs to be done to establish the property of responsiveness in common diagnostic tests for lymphedema. Until such work is completed, one cannot draw any conclusions about responsiveness to change in this area.

f) How frequently and for how long should patients be measured for the development of lymphedema or its sub-clinical precursor? Does this vary with the diagnostic test method?

There is no evidence to answer either key question as none of the included diagnostic studies addressed either question. These studies were undertaken to examine the sensitivity, specificity, or psychometric properties of various tests in comparison to one another, so persons who were included in these studies typically had a diagnosis of lymphedema. Non-lymphedema control groups were included in some instances to provide comparisons, but not to ascertain measurement times for development of lymphedema. One study did specifically compare the incidence of lymphedema over time using four tests and five assessments,27 but the sole rationale for conducting five assessments at quarterly intervals was that the assessments could be performed at the same time as regularly scheduled followup appointments with oncologists. The suitability of five quarterly assessments was not under study. Another study conducted followup a maximum of 14 times per participant, but the rationale for this number was not provided by the authors.95

The studies that did provide a rationale for multiple assessments were designed to examine test-retest and interrater reliability, or validity, so multiple assessments were necessary. None of these studies was designed to investigate the frequency or length of time necessary for persons to be measured for the development of lymphedema. Consequently, there was no pattern of frequency or length associated with any specific test.

For question 1f to be answered, a group of persons without lymphedema at baseline would have to be followed up for a set amount of time. During this time, different tests at regular intervals could be employed to assess whether lymphedema develops. The testing intervals could be varied (within or between tests) on different subgroups of patients to get a clearer picture of the issues at hand.

g) Does the diagnostic test method influence the choice of lymphedema treatment or patient outcome? What outcomes were measured in studies of diagnostic tests of lymphedema?

There is no evidence in the 41 diagnostic testing studies to answer either of these questions. Only four studies contained mention of the type of treatment offered to patients, and the point of these studies was not to examine treatment itself, but to study diagnostic test properties. Outcomes of treatment were not reported in three of the studies.66,80,85 In the fourth study, outcomes were reported, but the authors made no attempt to link outcomes to the choice of diagnostic test.81

## Treatment

Question 2. What were the patient selection criteria in the studies (inclusion and exclusion criteria)? Did they differ by treatment modality?

There were multiple inclusion and exclusion criteria spread across the 36 studies. There was no grouping of criteria attached to any specific treatment modality. Consequently, there is no evidence to suggest that patient selection criteria differed by treatment modality.

Question 3. What were the criteria used to initiate treatment for lymphedema? When was treatment initiated compared to the time of onset of the lymphedema? What were the criteria used to stop therapy? Did these criteria vary with treatment modality?

In all 36 treatment studies extracted for this report, a diagnosis of lymphedema was the only specific criteria used to initiate treatment. Only seven studies reported the approximate time of recruitment following onset of lymphedema. All except one of these studies began recruitment within 1 year of onset, but there was a wide range of recruiting times within this 1 year period. It should be noted that these are recruitment times following onset of lymphedema, not the times to initiation of treatment. Although it is likely that lymphedema treatment was initiated soon after recruitment, the time frame between recruitment and initiation was not reported in any article. Therefore, no evidence exists to provide a clear answer to the question about time of treatment initiation.

Only five studies reported specific criteria to stop treatment.47,110,112,116,133 This number is too small to assess whether stopping criteria varied with treatment modality in the 36 studies that were extracted for this report.

Question 4. Who provided the treatments in the studies? What information was provided on their professional training or certification in lymphedema care?

The authors of 17 of the 36 treatment studies did not detail who provided the lymphedema treatment. Except in the case of patient self-massage, the provision of lymphedema treatment requires a trained professional such as a physiotherapist or a technician familiar with the operation of an IPC device. To enhance reporting, as well as to facilitate judgments about the generalizability of published studies, authors of future studies in the domain of lymphedema treatment should report on the professional status and qualifications of the persons delivering lymphedema therapy.

Question 5a. Was one type of pneumatic compression device and sleeve (e.g., non-segmented compression device, sequential segmented compression, or segmented compression with calibrated gradient pressure) more effective in reducing lymphedema than another for any type of lymphedema along the continuum, or patient characteristic (e.g., demographics, comorbidities)?

Twelve studies included IPC treatment.50,103,104,108-113,130 There was no evidence from which to determine whether one type of IPC device and sleeve were more effective than others were across the continuum. The lack of evidence was partly a result of the fact that there were simply too few studies from which to conduct meaningful comparisons. Comparison was mainly inhibited by the degree of heterogeneity between articles: nine different types of IPC were investigated against multiple comparators. Comparators included MLD,108,109,111 compression bandage or sleeve,108-111,113 massage,103,113 skin care and prophylaxis,112 laser,104 or ultrasound.50 In two studies, the authors did not clearly describe the IPC device.104,112

The lack of evidence was further driven by the fact that IPC was delivered in conjunction with other treatments in six studies. IPC was given at the same time as study participants received MLD and compression bandages108 or compression garments or stockings.113,130 IPC was given after 2 weeks of treatment with a compression sleeve109 or it was followed by the application of elastic bandages.103 Additionally, IPC was part of a multimodal treatment in a study where the subject groups differed on receipt of tape or bandage (both groups got IPC).128 These differing regimens made it difficult to tease out the effects of IPC alone when conducting indirect comparisons across studies.

The same IPC devices were used in two sets of studies. The Sequential Circulator 2004 demonstrated statistically significant reductions versus MLD and compression garments in two studies,108,111 but the treatment regimens involving IPC differed across the studies in terms of length of daily IPC application and number of applications. Also, one study used IPC to treat persons with an initial diagnosis of lymphedema108 and the other used IPC as maintenance treatment.111 These characteristics worked against the extent to which the performance of the Sequential Circulator IPC could be indirectly compared across these two studies.

Lympha-Press was another IPC system used in two studies.109,130 Indirect cross comparisons between these two studies were also difficult because of differences in treatment regimen (Lympha-Press following 2 weeks with a compression sleeve109 or Lympha-Press concomitantly with compression stockings130). There were also differences in comparators (MLD,109 compression stockings or Flowtron IPC130).

Two types of Flowtron device were used in a study comparing different therapeutic regimens for compression cycles and chamber sleeves.125 Only one comparison was statistically significant at the 5% level, perhaps due to low power as none of the four treatment groups contained more than 20 subjects.

None of the extracted studies broke down treatment results by patients characteristics. Therefore, no evidence was found to assess whether one type of IPC device and sleeve were more effective in reducing lymphedema based on specific sets of patient characteristics.

Question 5b. Did the studies of IPC for lymphedema in patients with comorbidities such as wounds, arterial and/or venous insufficiency, diabetes, congestive heart failure, infection, etc., report the need to modify their treatment protocols? Did it affect treatment outcome?

There were no reports in the extracted studies of the need to modify treatment protocols on account of comorbidity. It would appear that most comorbidities with a potential effect on treatment outcome were addressed at the design stage of the studies, through the specification of exclusion criteria (e.g., exclude persons with congestive heart failure or any other contraindication to treatment113). In some cases, participants were removed from a study during followup due to the development of an adverse effect such as lymphangitis.110 Neither the use of exclusion criteria nor removal because of adverse effects suggests a protocol modification. There was no evidence in the extracted studies to address whether protocol modifications would affect treatment outcome.

Question 5c. Did the timing of IPC application and/or the sequence of use of the various IPC device types (either alone or in combination with other therapies) influence outcomes either positively or negatively?

There is no evidence to address whether the timing of the IPC application might have influenced the study outcomes. Six of the studies did not contain reports on timing.50,103,104,110,125,128,130 In the other six studies, the treatment regimens were too heterogeneous to allow for the isolation of any potential effect of timing. For sequence of use, the conclusion is the same: the mix of different treatments does not permit the isolation of the effect of sequence. Hence, there is no evidence for sequence as well. Additionally, there are simply too few studies from which to establish definitive patterns about timing or sequence.

Question 6. What protocols for single modality treatments resulted in the best outcomes of lymphedema therapy? Consider parameters such as usage schedules and characteristics of treatment such as intensity, duration, frequency and setting (self-administered at home versus professionally administered applied in a medical clinic), and if applicable pumping times/cycles and pressures.

There were 12 studies that examined single modality treatments for lymphedema. This reflects the fact that most lymphedema treatment is delivered as some form of combination therapy. Most of the studies adopted unrealistic comparators to maintain the ‘single modality’ distinction. For example, it is unlikely that persons with secondary lymphedema would be treated in standard clinical practice with only a booklet on healthy eating116 or instructions to continue with usual activities,47,117 or no treatment whatsoever.127,132 By the same token, the use of sham laser33,118 is questionable because there is no actual treatment given to patients. Ideally, the comparator should be the standard, medically-accepted treatment for lymphedema in the locality where researchers are conducting the study.

Notwithstanding the above, there was no evidence from which to ascertain whether certain treatment protocols would lead to better outcomes. Certainly this was the case for exercise47,48,129 and elastic stockings,132 where too few studies of each treatment negated any ability to compare protocols. For the other treatments (diet, laser, IPC, bandage, tape), the number of studies of each treatment was also not sufficient to investigate the effect of protocol differences on outcomes.

To address the effect of protocol on outcome, a series of studies with nearly identical samples, lengths of followup, comparator therapies, and outcomes would need to be constructed, with the only difference being the protocol used to deliver the treatment of interest. In the diet, laser, and IPC studies, there was little standardization in most of these areas (with the exception of the definition of outcome). Additionally, epidemiologic and statistical issues such as bias and power would have to be addressed in the design and analysis of the studies to increase the confidence in results. In one RCT, placebo patients were allowed to cross over to the active treatment group and analyses were conducted with these ‘crossovers’ included in both groups. Also, all of the studies except one48 had fewer than 100 participants. From a methodological perspective, there is simply too much noise from which to tease out the signal of a protocol effect on outcome.

Question 7: Were there any treatments, combinations of treatment methods, or sequence of treatments shown to be more effective or ineffective for any type of lymphedema along the continuum, or patient characteristics (e.g., demographics, comorbidities)? Of particular interest: Is there evidence that the use of compression sleeves or low stretch bandaging is effective in maintaining reductions in lymphedema achieved through the use of other modalities (e.g., IPC, manual lymphatic drainage, exercise)?

As studies used multiple outcomes in a variety of patient types, comparisons of treatments to identify those which are more or less effective are problematic. In no group of studies were the populations defined or the results reported to such a degree of detail that it is possible to identify groups of patients for whom these treatments are more, or less, effective.

A further potential reason for the lack of benefit seen in many studies is the issue of sample size. While some authors reported attempts at sample size calculations,48,112,113,115,117,123,124,128 very few provided any indication of estimates of benefit or variance in the study groups or study power and as a whole, did not report on sample size calculations. One group of authors did report on sample size calculations and reported less eligible patients than initially anticipated.116 The majority of studies enrolled 50 patients or less, suggesting that authors were expecting a large difference in benefit between study groups. As there was little detail in the majority of studies, it is unclear if statistical significance was not achieved due to overestimation of benefit or underestimation of variance within the groups.

Studies were even less likely to show a treatment benefit to patients regarding arm function and quality of life. Several potential reasons may explain this. Firstly, variance of these measures within studied populations may be such that statistical detection of change may be unlikely with limited study numbers. Additionally, in those studies which did result in reduced lymphedema volume, these reductions may not have been sufficient to result in a quality of life change. Finally, patient satisfaction outcomes may not be well correlated to arm volume. Perhaps other non-measured items are at play such as stiffness or pain.

Bandaging and elastic sleeves are commonly prescribed treatments, likely because of their low cost and relative availability. Two studies compared these treatments to more conservative measures (i.e., high versus low pressure bandaging,124 compression garments and exercise to exercise alone129), but the small number of studies made it difficult to comment on treatment benefit. Low quality evidence of modest benefit is provided from pre-post measurements of some studies,115,119,123,133 but should be interpreted with caution as there is no evidence to suggest that such reductions would not have happened in the absence of any care. Further low quality evidence for a benefit from elastic sleeves comes from the observation that patients using sleeves in studies with long term followup were more likely to retain initial benefit compared to patients from studies that did not. This issue was further addressed in Chapter 3. Again, this should be interpreted with caution, as no included studies were intended to specifically address this observation.

Question 8: What comparators were used in the studies? Are these comparators consistent with usual care for lymphedema?

Many treatments have been suggested to provide benefit for patients with lymphedema. Despite this, no single treatment has emerged as a gold standard in clinical trials thus there appears to be no standard comparator for RCTs. Elastic sleeve was used in 4 of 36 studies and was most common comparator against the study treatment.110,115,116,130 Compression bandaging or stocking was used in 5 studies.119,123,124,133,134 Sleeve and bandaging were likely chosen as the most common comparators because of their low cost and relative availability, not because of evidence of benefit.

Question 9: What outcomes were measured in studies of lymphedema therapy? How effective were these treatment methods in reducing lymphedema?

Multiple outcomes were used in these reports. Objective measurements, usually relating to volume were most reported.

Many studies reported that treatment brought about a reduction in lymphedema volume. However, relative benefit is difficult to appreciate in that despite studies including comparator groups, some provided pre- and post-treatment assessments of each group but did not provide between group comparisons.111,131 Other studies provided p values for comparisons but did not report point estimates in differences of benefit110,112,130,132 leaving clinicians to question the clinical benefit of treatment. Even in those studies that did, report point estimates of benefit, the specific outcomes reported varied such that cross comparisons were difficult to make. For instance, arm measurements may have resulted in reporting of circumference differences,103 percent volume loss,122 absolute volume loss,109 or proportion of patients achieving a pre-specified degree of benefit.48,110

Question 10: Did any studies show that the time of treatment initiation (single modality or combination therapy) relative to symptom onset, any other lymphedema characteristics, or any patient characteristics influenced or predicted treatment outcome?

Since few studies were sufficiently powered to detect a difference in the primary outcome, most trials were did not have power to detect differences in patient subgroups which were predictive for response. Few trials randomized patients with a stratification scheme or performed adjusted analyses to allow for detection of predictive factors. One RCT with 141 subjects specifically looked at differences according to cancer severity, race, physical activity, diet, and BMI and found no effect.48

Question 11: What was the length of followup in studies of lymphedema therapy? How long were the benefits of treatment maintained?

Considering the chronicity of lymphedema, very few trials performed long term followup in their study population. Only eight trials reported outcomes at 6 months or beyond.48,50,104,105,110,111,115,132 One study reported outcomes at week 30 of the study, but this was only 12 weeks from the last treatment.33 There was no consistent evidence regarding the length to which treatment benefits could be maintained.

Question 12: What harms have been reported associated with the various treatments for lymphedema? Do any patient characteristics (e.g., demographics, comorbidities) or etiology of lymphedema increase the risk of these harms?

Due to the nature of these studies, it was not always possible to delineate which patients were in which treatment group, preventing readers from drawing conclusions about the relative harms of various treatments. The majority of withdrawals and adverse events were related to treatment scheduling or disease recurrence, neither of which would be the direct result of therapy. Adverse events likely related to study therapy were all rare.

Even if all adverse events were in the treatment groups, their infrequency would be unlikely to result in statistical significance if formally tested. No studies reported on factors which may increase the risk of harms associated with treatment. There was no evidence in the extracted studies to answer this question.

## Non English Language Studies

Non English language studies were excluded from the original scope of the TA. In conjunction with AHRQ and CMS, we revisited this decision after peer review of the draft report and decided to examine whether the non English literature contained results that differed from studies published in the English language. We reran the search and screening strategies outlined in Chapter 2 above and found 5 non English diagnosis studies and 8 non English treatment studies that met the other report inclusion criteria. These studies passed all levels of screening and would have been included in the TA had they been published in English. We summarize these studies below.

### Diagnosis

All 5 diagnosis studies investigated upper limb lymphedema secondary to breast cancer.139-143 The size of the study populations with lymphedema ranged from 16^143^ to 74.^139^ Four publications were validity studies with the following index tests and comparators: bioimpedance versus arm volume,139 perometer versus water volume displacement,140 ultrasound versus arm circumference,142 and arm circumference versus water volume displacement.143

Results were reported descriptively without quantitative statistics in two studies. In the first study, the authors reported detection of lymphedema in 8 persons using bioimpedance and in the same 8 persons using arm volume, but the condition was detected on average 9 months earlier using bioimpedance.139 In the second study, the authors reported that changes in limb volume measures were similar between perometry and water displacement, but they did not provide correlation coefficients, Kappa’s, etc.140

Authors provided quantitative results in two other studies. Ultrasound was moderately correlated with arm circumference (r = 0.48 to 0.55) in a study where the researchers found measures of arm circumference to be unreliable.142 Another group of authors found strong correlations between measures of arm circumference and water volume displacement (r = 0.90 to 0.98).

The fifth study compared lymphoscintigraphy and clinical symptoms (including arm volume) in the diagnosis of secondary lymphedema.141 Twenty-five persons were allocated nonrandomly to each of the lymphoscintigraphy and clinical groups. Twenty persons in the lymphoscintigraphy group were identified on testing as showing symptoms of lymphatic impairment. Testing in this group was conducted prior to breast cancer surgery, 1-3-6 months postoperatively, and 1 year and 3 years postoperatively. Nine persons in the clinical group were found to have lymphedema during the course of normal postoperative followup.

Since the testing protocols in the fifth study were conducted on separate groups, we could not calculate sensitivity or specificity, nor assess the validity of lymphoscintigraphy versus clinical diagnosis. However, in this study, the authors propose a testing and treatment protocol using lymphoscintigraphy, which addresses key questions 1f and 1g. In the study, persons who showed signs of lymphatic impairment on lymphoscintigraphy were given a combination therapy involving MLD, bandage, mechanical lymphatic drainage, and elastic garments. Persons who were unresponsive to combination therapy received microsurgery. Only two persons with lymphatic impairment failed to improve after receipt of combination therapy. These persons received microsurgery and subsequently exhibited a complete regression of edema and improved lymphatic drainage.141

Overall, the 5 non English diagnosis studies did not contribute substantive new information to the TA. The studies were conducted in the familiar population of breast cancer patients and the tests had all been evaluated in English language publications. The correlation between ultrasound and arm circumference in one non English study142 was lower than many of the reported correlations in the English literature, but this could be a function of the specifics of one study rather than an indication of a new and important finding. Another non English study141 addressed two key questions that were not covered in the English literature; however no general conclusions can be drawn from a single observational study of only two diagnostic tests.

### Treatment

The 8 treatment studies were observational, with sample sizes ranging from 30^144,145^ to 440.^146^ Lengths of followup, in the studies where authors reported such information, ranged from 28 days144 to 10 years.146 All 8 studies involved breast cancer survivors with upper limb lymphedema. The authors of only one report specified the type of individual who provided therapy, i.e., a ‘kinesiology therapist’.147

Three studies examined single modality treatments. The first study compared an education program for self administered MLD against an unspecified control treatment over 6 weeks of followup. Arm function, measured using a vaguely described questionnaire, was better in the treated group over the entire followup period (p<0.05).148 In the second study, three groups were compared over 28 days: MLD via the ‘Asdonk standard’ for 1 hour/day; non Asdonk standard MLD for 1.5 hours/day; non Asdonk standard MLD for 1 hour/day. Although the author describes the Asdonk standard method, there are no references to this method given in the published manuscript.144 The author reports a greater reduction in arm volume in the Asdonk group versus the other groups over the course of followup, but does not provide p-values or other quantitative statistics. The third study of single modality treatments compared single chamber IPC using a Jobst machine with multi chamber IPC using a Lymph-a-mat machine. Lymphedema severity decreased within each group over an unspecified followup time (described as ‘beginning’ and ‘end’ in the published figures); however, there was no statistically significant difference between groups at the 5% level.149

Three studies investigated multi modal treatments. The first study compared multi layer bandaging and MLD to simplified bandaging and MLD. Simplified bandaging, which was considered the active treatment, was 2 bandages juxtaposed one over the other rather than a more complex method of wrapping multiple bandages. After 12 to 16 sessions over 4 weeks, the group treated with simplified bandaging in addition to MLD showed larger decreases in edema relative to the comparison group (p = 0.04).147 The second study involved a combination treatment of MLD, IPC, and exercise in two groups, with one of the groups given additional treatment in the form of bandage. The authors provide intragroup comparisons over time, but do not provide intergroup comparisons.145 The third study involved a 10 year followup of 440 persons assigned nonrandomly to one of four groups. Each group received IPC at 40 to 110mmHg for 15 sessions lasting 1 hour each. Treatment was limited to IPC in one group, but treatment was IPC plus electrostimulation of muscles in a second group, IPC plus magnetic therapy in a third group, and IPC plus both electrostimulation and magnetic therapy in a fourth group. Percent changes in limb volume were highest in the fourth group, with all results statistically significantly different at the 5% level.146

Two studies examined whether the time of initiation of lymphedema treatment would affect treatment results. The first study saw treatment initiated less than 1 year after breast cancer surgery versus 1 to 2 years post surgery. Treatment in both groups was a combination of MLD, IPC, bandage, and exercise. Faster reduction of arm swelling was observed in the group with earlier treatment initiation.150 Conversely, the second study found no differences between groups when treatment was initiated 3 months after lymphedema diagnosis versus 12 months post diagnosis. The treatment regimen in this study was physical therapy, electrostimulation, massage, and IPC.151

The non English treatment studies mirrored the high degree of heterogeneity observed in the English language treatment studies. The non English studies were characterized by different treatment combinations and varying lengths of followup, which inhibit one from drawing clear conclusions to answer the key questions. Two studies did consider an issue that was unaddressed in the English language literature, namely whether treatment effect was related to timing of treatment initiation (key question 11).150,151 However, the studies’ authors reported contrary results using different treatment protocols and initiation times. Again, too much heterogeneity prevented us from answering a key question.

The non English language treatment studies do not add any substantive information to the results obtained from the English language literature.

## Conclusions

Most of the diagnostic accuracy and treatment studies were conducted in persons with a history of breast cancer. This is important to note because the sensitivity and specificity, and psychometric properties, of the diagnostic tests for secondary lymphedema could differ in non-breast cancer patient populations. This suggests that the diagnostic tests should be evaluated in non-breast cancer populations prior to the tests’ use in these populations. The need for evaluation in these populations certainly applies to diagnostic tests involving limb volume or circumference, despite the fact that these tests were shown to have very good properties in the breast cancer population. The same caution regarding evaluation in different populations must also be applied to studies of treatments for secondary lymphedema. Most treatments were evaluated in the breast cancer population, so there is no automatic assurance that their efficacy is transferable to other populations. Evaluation of treatment efficacy in non breast cancer populations is an important step for future research.

Based on the evidence, limb and volume circumference are the de facto ‘gold standard’ tests from which to assess the presence of secondary lymphedema. However, these tests do not have a standard threshold or cut off point to indicate the presence or absence of lymphedema. Similarly, there is no consistent means of actually measuring volume or circumference. Although validity assessment suggests good interchangeability between different measures of limb volume or circumference, the heterogeneity of the evidence was too substantial to enable the drawing of conclusions about the type of measure that would be the most appropriate for diagnosing secondary lymphedema.

The different methods of measuring limb volume or circumference detract from comparisons of sensitivity and specificity. These comparisons are best done by selecting a set measurement method and then varying the cut off points to estimate the optimal cut off point using a receiver operating characteristic (ROC) curve.152 None of the diagnostic testing studies employed an ROC curve, perhaps due to the lack of agreement on a gold standard means of diagnosing lymphedema.

There was no evidence to suggest an adequate diagnostic testing protocol. The extracted studies failed to provide an indication of suitable frequencies of testing or time spans within which testing should be done. Additionally, there was no information to suggest whether the type of diagnostic test would have an effect on the choice of treatment or on patient outcomes.

Regarding treatment for secondary lymphedema, there was no evidence concerning the optimal criteria to initiate or stop treatment. While the studies suggested that most treatments did reduce the size of the lymphatic limb, there was too much heterogeneity in terms of therapy, inclusion, and exclusion criteria, and treatment protocols to suggest the optimality of one type of treatment over another. Despite the multiplicity of inclusion and exclusion criteria, almost no studies contained reports of treatment benefits in any subgroup of patients. In fact, most studies were not designed to look for treatment benefits in subgroups.

Adverse effects were only reported in a small number of studies. The adverse effects that were reported were generally rare and mild, and unlikely to be a major clinical issue.

The methodological quality of the extracted diagnosis and treatment studies was generally ‘fair’. Many quality issues may have been related to a lack of adequate reporting rather than to methodological shortcomings in the conduct of the research. However, the authors of some studies omitted the reporting of fundamental aspects of their research. For example, there were reliability articles that did not contain mention of the intervals between administrations of the tests of interest, none of the validity studies indicated whether index test results were interpreted without knowledge of reference test results, and the majority of RCTs did not include comment on whether outcome assessors were blinded. While reporting oversight may be one reason for these omissions, the fundamental nature of the omitted elements suggests a certain degree of caution should be exercised when interpreting study results. This suggestion reflects a degree of healthy skepticism in the assessment of scientific research, i.e., to assume inadequate quality unless the study authors present evidence to the contrary.102

Although the quality of the extracted articles suggests the need for a guarded approach to interpreting results, quality did not appear to play a major role the answers to the key questions. The articles were far too heterogeneous in terms of test, treatment, and outcome to ascertain whether studies of a certain quality tended to group around any particular test, treatment, or outcome. Indeed, most of the studies were of ‘fair’ quality anyway, which suggests that quality was not a major factor in the response or interpretation of the key questions.

In looking at the extracted articles as a whole, it can be concluded that there is no evidence in the literature to suggest an optimal diagnostic testing protocol, an optimal frequency or duration of treatment, the most efficacious treatment combinations (including the use of maintenance therapy), and the length of time for which persons should be tested or treated for lymphedema.

## Recommendations for Future Research

Diagnostic Testing. Prior to the initiation of further research into diagnostic testing, clinicians and researchers in the field of secondary lymphedema need to agree on a uniform, gold standard, diagnostic test. Existing work suggests that limb volume or circumference has already emerged as the de facto gold standard, but a set means of measuring volume or circumference should be adopted by the clinical and research communities. Ideally, this set means should be accessible by clinical and research centers globally to promote uniformity. If the strong validity of different measures of volume or circumference in persons with breast cancer is emblematic of the situation in other patient populations, then simple, basic, readily usable, and currently existing methods should be preferred to expensive devices that might not provide an improvement in diagnostic accuracy (or that might not be available or practical in all clinical settings). In other words, a simple tape measure need not be replaced by an expensive machine if the concurrent validity between methods is good and the machine does not improve upon the number of patients who can be assessed within a clinically relevant timeframe.

Once the gold standard test has been adopted, work must proceed to establish a meaningful cut off point that will be uniformly regarded as the threshold to distinguish a person with secondary lymphedema from a person without secondary lymphedema. Comparison of different cut off points using ROC curves is recommended to achieve this objective.

Over time, new and better tests may be developed and this will necessitate a comparison against the gold standard. A comparative study should recruit patients immediately after a medical event (e.g., tumor resection) that is known to cause secondary lymphedema. Patients would then be assessed at regular intervals using the gold standard test and the new test. It may not be possible to blind patients to the type of test they receive, but different assessors should be employed to independently assess each patient on the different tests within a time frame that is short enough to control for changes in patients’ lymphedema status over time. The tests results could be used to calculate test-retest and interrater reliability, as well as validity and sensitivity and specificity. The cut off points for the new test could also be varied to create ROC curves.

Treatment. Different treatment regimens should be compared between groups in RCTs. Treatment protocols should be clearly described and randomization should be conducted via computer-generated algorithms. RCTs must be adequately powered to detect a clearly defined primary outcome. The ethics of conducting an RCT and subjecting participants to an experimental treatment when there is little hope of detecting a true effect (should one exist) due to low power needs to be considered carefully by researchers in the field.

As a multiplicity of outcomes has been reported, making cross study comparisons and any future meta analyses difficult, commonly agreed upon outcomes should be encouraged. If the authors believe a priori that important subgroup effects are possible, then the study should be powered to detect effects in these subgroups as well. Experimental and comparator treatments must be clearly labeled and the comparator should be a standard treatment regimen for secondary lymphedema. Although sham treatments (e.g., laser) may satisfy the minimum regulatory requirements for showing efficacy, the real world clinical utility of a novel treatment would best be demonstrated against an existing, standard treatment. Sham treatment may be an option if the experimental treatment is intended to be an adjunct to standard therapy (e.g., laser given in addition to MLD and compression bandaging, with one group getting real laser treatment, the other getting sham laser, and both receiving MLD and compression bandaging). Maintenance therapies, where used, should be clearly described by study authors. Blinding of study participants, clinicians, and healthcare professionals who administer treatment may not be possible due to the nature of the therapies, but at a minimum, the outcome assessors should be blinded to treatment.

To avoid the publication of ambiguous reports, study authors should use existing quality scales12-15 and the 2010 CONSORT statement for RCTs153 as templates for producing scholarly manuscripts. One of the extracted studies provides a good example of reporting the results of an RCT.48

Most of the studies extracted for this report involved lymphedema to the upper extremities. Lower limb lymphedema was not well represented in the studies, despite its high incidence from cancer treatment.20 More RCTs should be conducted in patients with secondary lymphedema in the lower limbs.

Although a great deal of research into the diagnosis and treatment of secondary lymphedema has already been undertaken, there is no evidence to suggest the optimal diagnostic test or treatment. Similarly, there is no evidence to suggest whether certain tests or treatments may benefit some types of patients more than others may. The field of research into secondary lymphedema is ripe for advancement and the contents of this report may serve as a springboard to guide future scientific endeavors in this domain.