# Results

## Literature Review and Screening

The literature search yielded 6,814 unique citations. In total, 6111 citations (90 percent) were excluded from further review following the initial level of title and abstract screening. Of the 703 citations promoted to the second level of title and abstract screening, 472 (67 percent) were excluded and 231 proceeded to full text screening. Of the 231, 13^53-65^ (6 percent) could not be retrieved despite extensive searches of library holdings from multiple universities, interlibrary loan requests, and contacts with authors. This left 218 articles, of which 77 (35 percent) English articles passed full text screening and proceeded to data extraction and quality assessment. Of the 77 English articles, 36 were related to the treatment of lymphedema and 41 were related to the diagnosis of lymphedema. There were 13 non-English articles that passed full text screening (five diagnosis and eight treatment). Figure 1 depicts the flow of studies through the screening process. As well, the figure shows the reasons for study exclusion. The remainder of this chapter contains sections describing the evidence for the key questions 1 to 12 and a quality assessment of the studies.

Figure 1 Flow diagram showing the numbers of articles processed at each level

Figure 1 is a flow diagram indicating the numbers of citations included and excluded at each level of screening. The literature search yielded 6,814 unique citations. In total, 6,111 citations (90 percent) were excluded from further review following the initial level of title and abstract screening. Out of the 703 citations promoted to the second level of title and abstract screening, 472 (67 percent) were excluded and 231 proceeded to full text screening. Of the 231, thirteen (6 percent) could not be retrieved despite extensive searches of library holdings from multiple universities, inter-library loan requests, and contacts with authors. This left 218 articles, of which 77 (35 percent) english articles passed full text screening and proceeded to data extraction and quality assessment. Of the 77 english articles, 36 were related to the treatment of lymphedema and 41 were related to the diagnosis of lymphedema. There were 13 non-english articles that passed full text screening (5 diagnosis and 8 treatment).

## Quality Assessment

### Diagnosis

The overall quality assessment for the diagnostic studies was ‘fair’. Figure 2 shows the distribution of quality rankings for the 41 diagnostic studies.27,28,30,31,36,66-101

Figure 2 Distribution of quality rankings for diagnostic studies

Freq.=number of studies

Figure 2 contains three bar graphs and shows the distribution of quality rankings for the 41 studies included in the diagnosis section. The first bar graph containing three bars,depicts the eight sensitivity and specificity studies. One of these studies is ranked as good, six studies are ranked as fair and one study is ranked as poor. The second bar graph containing three bars, depicts the nine reliability studies. One study is ranked as good, seven studies are ranked as fair and one study is ranked as poor. The last bar graph containing three bars, depicts the thirty studies containing validity information. Four studies are ranked as good, twenty six studies are ranked as fair and no study is ranked as poor. Please note that some studies overlapped in more than one category and thus the total number of studies included in the bar graphs is more than the total number of included diagnostic studies.

The primary quality issue with the diagnostic studies was a lack of clarity in reporting the details of patient withdrawals, intermediate results, and selection and training of raters. The possibility exists that patient withdrawals were minimal or nonexistent in most of these studies due to the limited number of assessments (usually one or two conducted on the same day) and purpose of the assessments (to examine the utility of diagnostic tests rather than to administer a treatment). The reporting of intermediate results may in fact be irrelevant to most diagnostic studies because the intent was to compare the results of different tests, rather than to follow a cohort of persons over time. Given the intent of diagnostic accuracy studies, the authors may not have thought it necessary to use limited journal space to describe the selection and training of raters. Thus, many of the ‘fair’ studies may have been rated as such due to reporting or relevancy issues rather than due to fundamental flaws in the research. Certainly, one limitation of quality assessment is that reviewers essentially examine the quality of what was reported in the published article rather than what was actually done in the study.102

More problematic in terms of quality was the fact that four of nine reliability studies28,67,92,100 did not contain reports of whether appropriate intervals were used between administrations of the tests of interest. While this may be a reporting rather than a quality issue, a fundamental aspect of any reliability study is to ensure that repeated administrations of the test occur in a timeframe where the underlying condition of interest has not changed, (e.g., the severity of a person’s lymphedema remains constant). It will not be possible to assess test-retest or interrater reliability if the underlying condition changes between administrations of the diagnostic test. Authors of reliability studies should comment on the timeframe of their test administrations. In addition, none of the 30 validity studies reported whether the results of the index test were interpreted without knowledge of the results of the reference standard. To prevent the results of the first test from biasing the interpretation of results from the second test, different persons should assess the test results in a blinded fashion. Authors of validity studies should report whether the test results were interpreted in a blinded fashion.

Tables 2 to 4 contain a summary of the quality assessment of the diagnostic accuracy studies.

Table 2 Quality of sensitivity and specificity studies using QUADAS

| Hayes68 2008 Australia | Spillane69 2008 Australia | Peer72 2007 Canada | Hayes74 2005 Australia | Bland78 2003 U.S. | Norman83 2001 U.S. | Cornish95 2001 Australia | Godoy70 2007 Brazil
1. Was the spectrum of patients representative of the patients who will receive the test in practice? | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
2. Were selection criteria clearly described? | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes
3. Is the reference standard likely to correctly classify the target condition? | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Unclear
4. Is the time period between reference standard and index test short enough to be reasonably sure that the target condition did not change between the tests? | Unclear | Yes | Unclear | Yes | Unclear | Unclear | Unclear | Unclear
5. Did the whole sample or a random selection of the sample, receive verification using a reference standard of diagnosis? | No | Yes | Yes | Yes | Yes | Yes | Yes | Yes
6. Did patients receive the same reference standard independent of the index test results? | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Yes
7. Was the reference standard independent of the index test (i.e., the index test did not form part of the reference standard)? | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Unclear
8. Was the execution of the index test described in sufficient detail to permit replication of the test? | No | Yes | Yes | Yes | Yes | Yes | Yes | No
9. Was the execution of the reference standard described in sufficient detail to permit its replication? | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No
10. Were the index test results interpreted without knowledge of the results of the reference standard? | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear
11. Were the reference standard results interpreted without knowledge of the results of the index test? | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear
12. Were the same clinical data available when test results were interpreted as would be available when the test is used in practice? | Unclear | Yes | Yes | Yes | Yes | Yes | Yes | Yes
13. Were uninterruptable/intermediate test results reported? | No | No | Yes | Yes | Unclear | Unclear | No | Unclear
14. Were withdrawals from the study explained? | No | No | No | No | Yes | No | Yes | Yes
Quality Rating | Poor | Fair | Fair | Good | Fair | Fair | Fair | Fair

Table 3 Quality assessment of reliability studies with modified QUADAS

Study | Were study patients representative of the patients who will receive the test(s) in practice? | Were selection criteria for patients clearly described? | Were correct statistical measures used? | Was execution of test and comparator described in sufficient detail to permit replication in another study? | Were withdrawals from the study explained? | Were intermediate results/incomplete data reported? | Did assessors have adequate professional training to perform test/measurement? | How were raters selected? | Was interval between test-retest appropriate? | Did independent ratings take place within a time frame that would ensure the condition did not change? | Quality rating
Chen31 2008 Taiwan | Yes | Yes | Yes | Yes | No | No | Yes | Unclear | Yes | Yes | Fair
Deltombe30 2007 Belgium | Yes | Yes | Yes | Yes | No | No | Yes | Yes | Yes | Yes | Fair
Megens82 2001 Canada | Yes | Yes | Yes | Yes | No | No | Yes | Unclear | Yes | Yes | Fair
Meijer77 2004 Netherlands | Yes | Yes | Yes | Yes | No | No | Unclear | Unclear | Yes | Yes | Fair
Mosley67 2008 Australia | Yes | Yes | No | Yes | No | No | Yes | Unclear | Unclear | Unclear | Poor
Norman83 2001 U.S. | Yes | Yes | Yes | Yes | No | Unclear | Yes | Yes | Unclear | Unclear | Fair
Roberts86 1995 U. K. | Yes | No | Yes | Yes | No | No | Unclear | Unclear | Yes | Yes | Fair
Taylor28 2006 Australia | Yes | Yes | Yes | Yes | No | No | Yes | Yes | Unclear | Unclear | Fair

Table 4 Quality assessment of validity studies using modified QUADAS

Study | Were study patients representative of the patients who will receive the test(s) in practice? | Were selection criteria for patients clearly described? | Were the index test and comparator described in sufficient detail to permit replication in another study? | Were withdrawals from the study explained? | Were intermediate results/incomplete data reported? | Did assessors have adequate professional training to perform test/measurement? | Is the comparator test likely to correctly classify the condition? | Were the correct statistical tests used to measure validity? | Was the time period between the application of the index test and the comparator test short enough to ensure the condition did Not change between tests? | Did all patients who received the index test also receive the comparator test? | Were the index and comparator tests performed independently of one another? | Were the results of the index test interpreted without knowledge of the comparator test? | Quality rating (Good/Fair/Poor)
Armer27 2005 U.S. | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Unclear | Yes | Yes | Yes | No | Fair
Armer36 2003 U.S. | Yes | Yes | No | No | No | Yes | Yes | Yes | Unclear | Yes | Unclear | Unclear | Fair
Bates88 1992 U.K | Yes | Yes | Yes | Yes | Unclear | Unclear | Yes | Yes | Unclear | Yes | Yes | Unclear | Fair
Cornish85 1996 Australia | Yes | Yes | Yes | No | No | Unclear | Yes | Unclear | Yes | Yes | Yes | No | Fair
Czerniec100 2010 Australia | Yes | Yes | Yes | Yes | Unclear | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | Good
Damstra73 2006 Netherlands | Yes | Yes | Yes | No | No | Yes | Yes | Yes | Yes | Yes | Yes | No | Good
Gebousky92 2008 Czech Republic | Yes | Yes | Yes | No | No | Yes | Unclear | Unclear | Unclear | Yes | Unclear | No | Fair
Halaska90 2006 Czech Republic | Yes | Yes | Unclear | No | Yes | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | Fair
Karges79 2003 U.S. | Yes | Yes | Yes | Yes | Yes | Unclear | Yes | Unclear | Yes | Yes | Yes | No | Fair
Latchford84 1997 Australia | Yes | No | Yes | No | No | Yes | Yes | Yes | Unclear | Yes | Yes | No | Fair
Mayrovitz66 2000 U.S. | Yes | Yes | Yes | No | No | Yes | Yes | Yes | Unclear | Yes | Yes | No | Fair
Mayrovitz93 2008 U.S. | Yes | Yes | Yes | No | No | Unclear | Yes | Unclear | Yes | Yes | No | No | Fair
Mayrovitz94 2009 U.S. | Yes | Yes | Yes | No | No | Unclear | Yes | Yes | Yes | Yes | No | Unclear | Fair
Mayrovitz136 2009 U.S | Yes | No | Yes | Yes | Unclear | Unclear | Yes | Yes | Unclear | Yes | Yes | Unclear | Fair
Meijer77 2004 Netherlands | Yes | Yes | Yes | No | No | Unclear | Yes | Yes | Yes | Yes | Yes | No | Fair
Mellor76 2004 U. K. | Yes | Yes | Yes | No | No | Unclear | Unclear | Yes | Unclear | Yes | Yes | Unclear | Fair
Mirnajafi75 2004 Australia | Yes | Yes | Yes | Yes | No | Unclear | Yes | Unclear | Unclear | Unclear | Unclear | Unclear | Fair
Moseley80 2002 Australia | Yes | Yes | Yes | No | No | Unclear | Yes | Yes | Yes | Yes | Yes | No | Fair
Norman65 2001 U.S. | Yes | Yes | Yes | No | No | Yes | Yes | Yes | Unclear | Yes | Yes | Unclear | Fair
Ridner71 2007 U.S. | Yes | Yes | Yes | No | No | Yes | Yes | Unclear | Yes | Yes | Yes | No | Fair
Ridner97 2009 U.S | Yes | Yes | No | Yes | Unclear | Unclear | Unclear | Yes | Unclear | Yes | Yes | Unclear | Fair
Roberts86 1995 U. K. | Yes | No | Yes | No | No | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | Fair
Sagen96 2009 Norway | Yes | Yes | Yes | Yes | Unclear | Unclear | Yes | Yes | Unclear | Yes | Yes | Yes | Good
Stanton91 1997 U.K | Unclear | Yes | Yes | Unclear | Unclear | Unclear | Yes | Yes | Unclear | Yes | Yes | Yes | Fair
Szuba81 2002 U.S. | Yes | Yes | Yes | No | No | Unclear | Yes | Yes | Yes | Yes | Yes | Unclear | Fair
Taylor28 2006 Australia | Yes | Yes | Yes | No | No | Yes | Yes | Yes | Unclear | Yes | Yes | No | Fair
Tewari89 2008 Australia | Yes | Yes | Yes | Yes | No | Unclear | Yes | Yes | Unclear | Yes | Yes | No | Fair
Ward87 1992 Australia | Yes | Yes | Yes | Unclear | Unclear | Unclear | Yes | Yes | Unclear | Yes | Yes | Unclear | Fair
Ward98 2009 Australia | Yes | Yes | Yes | No | Unclear | Unclear | Yes | Yes | Unclear | Yes | Yes | Unclear | Fair
York99 2009 Australia | Yes | Yes | Yes | No | Unclear | Unclear | Unclear | Yes | Unclear | Yes | Yes | Unclear | Fair

### Treatment

Of the 36 studies that looked at treatments for secondary lymphedema, 30 were randomized controlled trials (RCTs)33,47,48,103-129 and six were observational (cohort) studies.50,130-134 The majority of the RCTs were of ‘fair’ quality and there was an even split between ‘good’ and ‘fair’ quality observational studies (Figure 3).

Figure 3 Distribution of quality rankings for treatment studies

Freq.=number of studies

Figure 3 contains two bar graphs and depicts the distribution of quality rankings for the 36 studies included in the treatment section. The first bar graph contains three bars and shows the distribution of quality rankings of the randomized controlled studies (RCT's). Quality assessment for the RCT's was done with the Jadad Scale. The first bar on the left indicates that eight RCT's were ranked as good. The middle bar shows that fifteen RCT's were ranked as fair. The bar on the right shows that seven RCT's were ranked as poor. The second bar graph contains three bars and depicts the distribution of quality rankings of the observational studies which were ranked using the Newcastle-Ottawa Scale (NOS). The first bar shows that three observational studies were ranked as good. The middle bar shows that three studies were ranked as fair. The last bar is absent as no studies were ranked as poor.

The major quality issues with the RCTs were an inadequate description of the randomization process in about half of the studies, no report of double blinding in many of the studies, and no reporting of methods to assess adverse effects in the studies that contained reports of harms.Lack of reporting of the randomization process is common in many RCTs, although a simple sentence (e.g., “Patients were randomized using a computer generated sequence of numbers”) should suffice to inform readers of the likely integrity of the process. Less acceptable methods of randomization, such as distribution of envelopes containing group assignments or coin tosses, are more susceptible to manipulation or not always truly random. To adequately assess the methodological quality of RCTs, authors should report the randomization process. Blinding may have been impossible in many of the studies due to the nature of the treatments. For example, it would be difficult to blind study participants or the persons administering treatment in an RCT where manual lymphatic drainage (MLD) alone is being compared to MLD plus intermittent pneumatic compression (IPC). However, other methods could be used to correct for the inability to blind. For example, persons assessing outcomes in the study groups could be different from the study investigators and persons who deliver treatment. These assessors could be blinded to participants’ treatment regimen. Most of the studies did not mention whether outcome assessors were blinded, so there is no way to ascertain whether knowledge of treatment may have biased any results. Regarding adverse effects, the few RCTs that included reports of harms generally did not specify how these conditions were defined or measured. Thus, there is no way to determine whether the ascertainment of adverse effects may have been biased in the extracted clinical trials.

Turning to the observational studies, the major quality issue was a lack of addressing the comparability of the exposed and unexposed groups in the design or analysis of the studies. In the absence of randomization, control of confounding in observational studies requires techniques such as matching, stratification, or use of multivariable regression analysis. Four of the six studies130,131,133,134 did not contain reports of whether methods were used to control for confounding. The authors of the other two studies50,132 indicated that the exposed and unexposed groups were matched on severity of lymphedema.

Tables 5 and 6 contain a summary of the quality assessment of the treatment studies.

Table 5 Quality assessment of RCT’s with Jadad Scale

Study | Jadad Score | Quality Rating
Radakovk103 1993 Yugoslavia | 1 | Poor
Hou105 2008 China | 3 | Poor
Kessler106 2003 Switzerland | 3 | Poor
McKenzie107 2003 U.S. | 3 | Poor
Kozanoglu104 2000 Turkey | 3 | Poor
Pilch125 2009 Poland | 3 | Poor
Bialoszewski126 2009 Poland | 3 | Poor
Williams114 2002 U.K. | 4 | Fair
Szuba108 2002 U.S. | 4 | Fair
Andersen115 2009 U.K. | 4 | Fair
Johansson109 1998 Sweden | 4 | Fair
Bertelli110 1991 Italy | 4 | Fair
Szuba111 2002 U.K. | 4 | Fair
Shaw116 2000 U.K. | 5 | Fair
Shaw117 2007 U.K. | 5 | Fair
KavianI118 2007 Iran | 5 | Fair
Didem119 2005 Turkey | 5 | Fair
Dini112 1998 Italy | 5 | Fair
Jahr120 2008 Germany | 5 | Fair
Maiya121 2008 Singapore | 5 | Fair
Sitzia122 2002 U.K. | 5 | Fair
Irdesel129 2007 Turkey | 5 | Fair
Damstra124 2009 Netherlands | 6 | Good
Lau127 2009 China | 6 | Good
McNeely123 2004 Canada | 6 | Good
Hayes47 2000 Australia | 6 | Good
Tsai128 2009 China | 6 | Good
Schmitz48 2009 U.S | 7 | Good
Wilburn113 2006 U.S. | 7 | Good
Carati33 2003 Australia | 8 | Good

Table 6 Quality assessment of observational studies using Newcastle-Ottawa Scale (NOS)

Study | Type of Study | NOS Star Rating | Quality Assessment
Johansson133 1999 Sweden | Cohort | 6 | Fair
Berlin130 1999 Sweden | Cohort | 6 | Fair
Frischenschlager134 1991 Austria | Cohort | 6 | Fair
Pinell131 2007 U.S. | Cohort | 7 | Good
Brambilla132 2006 Italy | Cohort | 8 | Good
Balzarini50 1993 Italy | Cohort | 8 | Good

## Diagnosis Studies

Question 1. What is the performance of diagnostic tests for preclinical and/or clinically significant lymphedema?

a) What inclusion criteria (including patient demographics, signs, and symptoms) were used in studies evaluating the performance of diagnostic tests of lymphedema?

Of the 41 diagnosis studies contained in the review, 35 included persons who had breast cancer (Table 7).27,28,30,31,36,67,68,70,71,73-79,81-87,89-99,101 Other disease related inclusion criteria were melanoma tumor removal,69 AIDS and Kaposi’s Sarcoma,72 or lymphedema diagnosis.66,73,77,79,80,88,90,99 Miscellaneous criteria included subjects who had a traumatic accident79 or who lived within a certain radius of the study site.68,74,95 For comparative purposes, many diagnostic studies also included nondiseased persons such as clinic staff,28,91 healthy patients,71,90,97 or medical students and surgical residents.91,93 Most studies had liberal age requirements (e.g., 18 years or more,27,71,77,78,97 less than 75 years68,74) and wide ranges of ages of included persons (e.g., 35 to 67 years,82 40 to 83 years88). Mean and median ages of included persons tended to lie above 50 years.30,67,73,80,83,85,89,92,93,98 Time since diagnosis or treatment of the primary condition (e.g., cancer) was an inclusion criterion in three studies.67,69,74 Timeframes in these studies were variable: six months or less,74 more than six months,69 and at least 12 months.67 Three studies excluded persons with concomitant skin disease;31,75,76 three studies excluded pregnant women.97,98,100

Table 7 Basic data diagnostic studies

Author | Study Type (Reliability, Validity, Sensitivity/Specificity) | Sample Size | Question #1a | Question #1b | Question #1f | Question #1g
Author | Study Type (Reliability, Validity, Sensitivity/Specificity) | Sample Size | Inclusion/Exclusion Criteria | Measure of Severity of LE | Frequency of Assessment for LE | Outcomes
Armer27 2005 U.S. | Validity | n=221 | Persons diagnosed with BCa, scheduled for Rx, no prior history of LE or BCa, >18 years of age in the Midwest | NR | 5 quarterly assessments to track incidence of LE | NR
Armer36 2003 U.S. | Validity | n=80 | 40 women with LE, 40 healthy control, no history of breast Ca or LE | NR | 2 assessments to measure validity | NR
Bates88 1992 U.K | Validity | n=38 | Patients with LE following treatment for BCa, mean age 63 years, mean duration of LE 44 months | NR | Up to 3 measurements if necessary | NR
Bland78 2003 U.S. | Sensitivity and Specificity | n=32 with LE n-58 without LE | Newly diagnosed resectable BCa. Age: ≥18 years, male or female, average age 53.7 years, all female, half of patients had radiation therapy Eligible patients were scheduled for mastectomy or lumpectomy, with lymph node sampling, dissection, or sentinel node biopsy, or breast conservation therapy followed by radiation therapy Previous axillary surgery or radiation, planned mastectomy without axillary surgery or radiation therapy, inability to provide consent, or no plans to followup after surgery | NR | 3 assessments per year for up to three years | NR
Chen31 2008 Taiwan | Reliability | Total n=31 Trial 1: Water displacement and circumference n=14 Trial 2: Tonometry n=17 | Pts who developed LE after breast carcinoma surgery Those with skin problems or wounds around measurement areas | NR | Single assessment | NR
Cornish95 2001 Australia | Sensitivity and Specificity | n=102 LE patients n=60 healthy control | 102 pts with BCa from 25 to 82 years old, living within 50 km of Brisbane 60 female volunteers | NR | Maximum of 14 assessments to examine Dx capability of BIS | NR
Cornish85 1996 Australia | Validity | LE patients n=20 Control n=20 | Pts with ≥Grade II unilateral LE of upper limb after surgery and/or radiotherapy for BCa. Mean age 60 yrs (32-78) Controls volunteers from clinic and staff | NR | Daily measurements for four weeks as part of treatment protocol | NR
Czerniec100 2010 Australia | Validity and reliability | n=33 LE patients n=18 controls | Women with unilateral arm LE following treatment for BCa (mean age 58±10.0 years); healthy controls (mean age 52±7 years) | NR | Two assessments four weeks apart | NR
Damstra73 2006 Netherlands | Validity | n=25 | Females suffering from LE age range 47-82 years (mean ± SD: 61.7±9.5); complete and partial mastectomy following BCa surgery axillary node dissection No signs of metastasis | NR | Multiple assessments to permit study of test-retest or interrater reliability | NR
Deltombe30 2007 Belgium | Reliability | n=30 LE patients | Women with chronic arm LE secondary to unilateral BCa Rx Dx was clinically evident LE All had axillary lymph node dissection, 27 total mastectomies, 3 partial mastectomies, 8 chemotherapy, and 29 radiations. Age range 46 - 79 years (mean 63.9 ± 9 years) | NR | Single assessment | NR
Gebousky92 2009 Czech Republic | Validity | n=88 women | Women with suspicion of unilateral secondary LE of upper limbs due to BCa Rx, aged 39-84 years (60.2±10.4) | 5-point ordinal scale to grade severity | 2 assessments to measure validity | NR
Godoy70 2007 Brazil | Sensitivity and Specificity | n= 90 | Women with LE following surgical Rx for BCa | NR | Single assessment | NR
Halaska90 2006 Czech Republic | Validity | Total n=101 Group A n=60 (circumference & MFBIA): subgroups A1 n=7 (circumference & MFBIA 1-100kHz & water displacement), A2 n=20 (& MFBIA 200kHZ) Group B n=5 (circumference & MFBIA); Group C n=36 (circumference & MFBIA) | Group A: healthy women as control, mean age 40.20 years (22-75yrs) Group B: pronounced LE, mean age 63.3 years (55-78 yrs) Group C: undergoing BCa surgery, mean age 60.0 years (37-76yrs) | NR | Single assessment | NR
Hayes74 2005 Australia | Sensitivity and Specificity | Total n=294 clinical component n=218 data complete n=176 | Women diagnosed unilateral BCa ≤6 months Age: ≤75 years, residing within 100 km of Brisbane | NR | Single assessment | NR
Hayes68 2008 Australia | Sensitivity and Specificity | n=287 | Women with unilateral breast cancer (BCa) with or without LE after Rx age: <75 years, (aged 54±10 years on average) residing within 100 km of Brisbane | NR | 5 assessments at 3 mo intervals 6 to 18 mo post surgery | NR
Karges79 2003 U.S. | Validity | n=14 | Dx of upper-extremity LE and receiving intervention, 12 postmastectomy LE and 1 LE from traumatic accident Selected in a consecutive manner. Sample of convenience | NR | Multiple assessments to permit study of test-retest or interrater reliability | NR
Latchford84 1997 Australia | Validity | n=15 | 15 consecutive patients with Grade 1, unilateral post- mastectomy LE, with mean age of 60 years | NR | 2 assessments to measure validity | NR
Mayrovitz136 2009 U.S | Validity | n=18 LE n= 12 control | 8 men and 10 women with lower extremity secondary LE; mean age 72± 18.6 years; 12 healthy controls | NR | Multiple assessments to measure validity | Change in TDC and tonometry after MLD Rx
Mayrovitz93 2008 U.S. | Validity | n=10 | Ten women (mean 71 +/- SD 14.1) with unilateral LE subsequent to BCa surgery or radiation Rx | NR | 4 assessments | NR
Mayrovitz94 2009 U.S. | Validity | n=30 | 10 women with unilateral arm LE subsequent to BCa surgery or RT 20 women with no history of LE | NR | 4 assessments to compare single vs. 3 measures of tissue dielectric constant | NR
Mayrovitz66 2000 U.S. | Validity | Total pts n=62 legs n=142 arms n=42 | Patients referred to an outpatient wound healing and LE center | NR | 2 assessments pre and post treatment | NR
Megens82 2001 Canada | Reliability | n=25 | Women at risk for LE who had undergone axillary lymph node dissection surgery for BCa age range 35-67 years | NR | Multiple assessments to permit study of test-retest or interrater reliability | NR
Meijer77 2004 Netherlands | Reliability and Validity | n=18 right upper extremity n=12 left upper extremity | BCa Rx-related LE of upper extremity Age: ≥18 years (mean 56.4 ± 11.6 SD) Co-morbidity, recent operations on the upper extremity, inability to elevate the upper extremity 90 degrees in the shoulder girdle, inability to extend the elbow | NR | Multiple assessments to permit study of test-retest or interrater reliability | NR
Mellor76 2004 U.K. | Validity | n=10 | Ten women (mean 59 +/- SD 9) with LE subsequent to unilateral BCa surgery or radiation Rx Skin disease or skin trauma | NR | 2 assessments to measure validity | NR
Mirnajafi75 2004 Australia | Validity | n=17 | Seventeen women with unilateral arm LE secondary to axillary clearance and RT Skin comorbidities | NR | 2 assessments to measure validity | NR
Moseley67 2002 Australia | Reliability | n=12 healthy volunteers n=12 LE patients | Women who had breast conserving surgery for BCa (± radiotherapy ± chemotherapy) ≥12 months ago and who were in remission. Aged 48-82 years (mean 61.6 ± 9.7 years); time since surgery range 2 - 20 years (mean 8.7 ± 4.7 years) | NR | Single assessment | NR
Mosely80 2002 Australia | Validity | n=33 n=28 women n=5 men | Secondary LE (28 women, 5 men) aged 39-88 years (mean 59 ± 13 years) with a Dx of LE of lower extremities | NR | 5 assessments to study correlation of BIS and perometry over time | NR
Norman83 2001 U.S. | Sensitivity and Specificity and reliability | Total n=43 measured independently by 2 physical therapists for interobserver agreement n=25 | LE following Rx for BCa. 41 unilateral, 2 bilateral mean age 54.1 years; all female; all women had LE diagnosed by their therapists | Comparing circumferential differences between affected and unaffected arms | Multiple assessments to permit study of test-retest or interrater reliability | NR
Peer72 2007 Canada | Sensitivity and Specificity | n=40 | 21 men and 19 women, mean age 36.68 years, range 20 - 71 years) with AIDS-KS; Dx confirmed by titer and biopsy Children, pregnant/lactating women, patients undergoing Rx | NR | Single assessment | NR
Ridner71 2007 U.S. | Validity | Study completers n=31 Data included n=25 Healthy volunteers (HV) n=14 LE patients n=11 | HV group: ≥18 years with no self reported LE or BCa LE group: ≥18 years with BCa Rx LE in one arm only no swelling or primary LE before BCa Rx, no medical contraindications; no pregnant women; no metal implants or pacemakers that would interfere with impedance measurements | NR | Single assessment | NR
Ridner97 2009 U.S | Validity | n=98 BCa LE n=75 BCa no LE n=60 controls | Women with arm LE after BCa | NR | Single assessment | NR
Roberts86 1995 U.K. | Validity and Reliability | n=15 | 14 subjects with LE 1 healthy subject | NR | Two sets of 2 assessments to measure test-retest reliability and validity | NR
Sagen96 2009 Norway | Validity | n=23 | Women with LE following surgery for BCa Mean age 64±11 years | NR | Single assessment | NR
Spillane69 2008 Australia | Sensitivity and Specificity | n=66 | Inguinal or ilio-inguinal dissection for melanoma >6 months previous 31 male, 35 female Age: median 44.2 years (range, 20 - 95 years) 9 received radiotherapy | NR | Single assessment | NR
Stanton91 1997 U.K | Validity | n=12 | Women with post mastectomy lymphedema | NR | Multiple assessments | NR
Szuba81 2002 U.S. | Validity | n=19 | 19 consecutive prospectively identified patients with post-mastectomy LE (average age 67+/- 10.1 years) Exclusion: recurrent or active malignancy | 8-point scoring system | 2 assessments to measure validity | NR
Taylor28 2006 Australia | Reliability and Validity | BCa and LE n=22, BCa no LE n=19, control n=25 | BCa patients and from healthy controls. All women | NR | Multiple assessments to permit study of test-retest or interrater reliability | NR
Tewari89 2008 Australia | Validity | Total n=87 arms measured n=174 | Women from a breast clinic with sentinel node biopsy with axillary clearance for BCa, mean age 58.6 years (range 17-81 years) | NR | Single assessment | NR
Ward87 1992 Australia | Validity | LE n=15 Control n=15 | Women with LE following BCa treatment; average age 53 years; duration of LE 1.5 months (average)Female controls from clinical staff/investigative team | Grade 2 LE (on 1-6 scale) | Single assessment | NR
Ward98 2009 Australia | Validity | LE n=45 Control n=21 | Women clinically diagnosed with unilateral arm LE after BCa. Healthy control group, no history LE or BCa | NR | 2 assessments each device to measure validity | NR
York99 2009 Australia | Validity | Arm LE n=28 Leg LE n=16 Healthy controls n=28 | Women with arm LE post BCa Women with leg LE secondary to Ca Controls, no history of LE or surgery to axilla | NR | Single assessment | NR

Abbreviations: AIDS-KS=Acquired Immune Deficiency Syndrome-Karposi’s Sarcoma, BCa=Breast Cancer, BIS=Bioimpedance Spectroscopy, Dx=diagnosis HV=healthy volunteer, LE=Lymphedema, MFBIA=Multifrequency Bioelectrical Impedance, MO=months, NR=Not Reported, Pts=Patients, RT=Radiotherapy, Rx=Treatment, SD=Standard Deviation.

b) Is there any “gold standard” method to formally grade or measure the severity of lymphedema?

Only three articles pertaining to diagnostic testing for lymphedema included a measure of severity (Table 7). In a study comparing self reported lymphedema (i.e., patient questionnaire about whether limbs are a different size and whether the differences are noticeable) to physical therapists’ measures of arm circumference, the severity of lymphedema was assessed by comparing the circumferential differences between the affected and unaffected arms.83 Differences of ≤2 cm signified mild lymphedema, >2 or <5 cm indicated moderate lymphedema, and ≥5 cm or more suggested severe lymphedema. This severity scale was developed by the two physical therapists who were involved in the study. The authors did not provide any details about the validity of this classification. The authors also compared self-report on the questionnaire to a ‘rule based’ assessment of circumferential differences: ≤1 cm meant no lymphedema, >1 cm and ≤2 cm indicated mild lymphedema, >2 cm and <5 cm signified moderate lymphedema, and ≥5 cm meant severe lymphedema. The authors do not cite the source of the rule based severity classification, nor do they indicate whether the classification has been used elsewhere.

The authors of a study comparing the reliability of lymphoscintigraphy versus a vaguely defined clinical assessment used a 5-point ordinal scale to grade the severity of lymphedema: 0=healthy; 1=latent; 2=reversible; 3=spontaneously irreversible; 4=elephantiasis.92 Lymphoscintigrapic and clinical assessors were supposed to use the data from their assessments to classify patients on the scale, but the authors did not provide the scoring rules for making this classification. The authors wrote that their scale was similar to existing recommendations,135 but they did not explain these similarities nor did they explain points of departure from these similarities.

In another study of lymphoscintigraphy, the authors developed an 8-point scoring system for persons with postmastectomy lymphedema. The system was based on imaging results and ranged from 0 (normal lymphatic drainage) to 8 (severe lymphatic impairment).81 The authors report that the system was developed “empirically” (p. 1172), but they do not provide details on its development, nor do they provide a precise set of scoring rules.

c) What comparators were used in the studies of diagnostic tests? Was the test compared to a “gold standard”, bedside exam, radiologic investigation, or other means?

The vast majority of diagnostic testing studies in the report included changes in limb volume or circumference as a comparator (Table 8). This included five studies of sensitivity and specificity,68,69,74,78,95 seven reliability studies,28,30,31,77,82,83,100 20 validity studies,27,28,36,66,71,73,76,77,79-81,83,85,87-91,98,100 and two responsiveness studies.28,31 Other types of test were used sparingly; vaguely defined or undefined clinical examinations in two studies,72,92 ^99m^Tc-hexakis-2-methoxy isobutyl isonitrate scan (MIBI scan) in one study,72 lymphoscintigraphy in one study,92 and tissue dielectric constant in two studies.93,94 The remaining tests (e.g., bioimpedance71,80,85) tended to be more narrow in scope, as opposed to general tests such as magnetic resonance imaging (MRI) or computed tomography (CT) scans that are used in many areas of medicine. MRI and CT scans were used in one study.96

Table 8 Psychometric properties of diagnostic studies

Author | Test(s) | Sample Size | Reliability | Validity | Responsiveness
Armer27 2005 U.S. | Circumferential measurements, infrared laser perometry LE and Breast Cancer Questionnaire (LBCQ) | n=221 | NR | Tests (Incidence of lymphedema 6 months/12 months) 200 mL difference in limb volume (24%/42%) 10% change in limb volume (8%/21%) 2 cm change in limb volume (46%/70%) LBCQ (19%/40%) | NR
Armer36 2003 U.S. | LBCQ vs. arm circumference measurements | n=40 LE group n=40 Control group | NR | LBCQ be predictive of ≥2 cm difference in arm circumference | NR
Bates88 1992 U.K | Subcutaneous interstitial fluid pressure vs. limb circumference | n=38 | NR | Intervals of 10 cm were compared to intervals of 3.81 cm (1.5 inches) and the correlation between measures was calculated to be 0.94 or greater | NR
Bland78 2003 U.S. | Index Test: Circumferential measurements Reference Test: 10% change or more in volume. 1 cm change in circumference at any site | n=90 | NR | NR | NR
Chen31 2008 Taiwan | Water displacement Circumference measurement Tonometry | Total n=31 Trial 1: Water displacement and circumference n=14 Trial 2: Tonometry n=17 | ICCs for test-retest and interrater reliability ranged from 0.69 to 0.88 | NR | Defined as smallest difference detectable 75 ml for water displacement 0.46 to 1.02 cm for limb circumference measurement 0.32 to 1.01mm for tissue resistance
Cornish95 2001 Australia | Index Test: MFBIA Reference Test: Limb circumference | n=102 LE patients n=60 healthy control | NR | NR | NR
Cornish85 1996 Australia | Bioimpedance daily measurements vs. circumferential measurements taken daily throughout 4 weeks of lymphedema treatment | n=20 LE Patients n=20 Control | NR | Bias scores decreased from 31% to 15% between 1 and 26 days of followup. Lower bias scores indicate better agreement | NR
Czerniec100 2010 Australia | Limb circumference, perometry, bioimpedance spectroscopy (BIS) and self report of LE | n=33 LE patients n=18 control | ICCs for intrarater reliability 0.95 to 1.00 for the three physical measures and 0.50 for visual analogue scale; interrater reliability, calculated for the physical measures only, ranged from 0.98 to 1.00 | High agreement between limb circumference, perometry and BIS (r = 0.89- 0.99) Moderate agreement between physical measures and self-report (r= 0.65-0.71) | NR
Damstra73 2006 Netherlands | Inverse water volumetry vs. circumferential measurements (Herpertz method) | n=25 | NR | ICCs ranged from 0.89 to 0.91 | NR
Deltombe30 2007 Belgium | Circumferential measurements using frustum sign method and the disk model method, water displacement, and Opto-electronic volumetry | n=30 LE patients | ICC for interrater reliability: Frustrum sign 0.937 Disk method 0.990 Water 0.987 Opto-Electronic 0.997 ICC for intrarater reliability: Frustrum sign 0.958 Disk method 0.989 Water 0.991 Opto-Electronic 0.997 | NR | NR
Gebousky92 2009 Czech Republic | Index Test: Lymphoscintigraphy Reference Test: Clinical examinations | n=88 Number of limbs n=176 | NR | Model predicts expert’s conclusions on lymphedema in 95% of the cases | NR
Godoy70 2007 Brazil | Perometry and volumetry | n= 90 | NR | NR | NR
Halaska90 2006 Prague | Multifrequency bioelectrical impedance, circumferential measurements, subgroup with water displacement | Total n=101 Group A n=60 (circumference & MFBIA):subgroups A1 n=7 (circumference & MFBIA 1-100kHz & water displacement), A2 n=20 (& MFBIA 200kHZ) Group B n=5 (circumference & MFBIA); Group C n=36 (circumference & MFBIA) | NR | Correlation between circumferential measurements and water displacement was 0.94 | NR
Hayes74 2005 Australia | Index Test: Multifrequency bioelectrical impedance Reference Test: Sum of arm circumference and self report | Total n=294 Clinical component n=218 Data complete n=176 | NR | NR | NR
Hayes68 2008 Australia | Index Test: Bioimpedance spectroscopy (BIS) Reference Test: Comparator: Sum of arm circumference and self report | n=287 | NR | NR | NR
Karges79 2003 U.S. | Volumetric measurements taken with a volumeter minus fingers (UE-F) circumferential measures taken with a tape measure, calculated volume formula using truncated cone formula | n=14 | NR | Correlation coefficient for volumetric measurements and tape measure was 0.98 | NR
Latchford84 1997 Australia | Arm circumference measurements every 10 cm vs. arm circumference measurements every 4 cm | n=15 | NR | Correlations between interval measures of 10 cm and 3.81 cm was 0.94 | NR
Mayrovitz136 2009 U.S | Tonometry tissue tester vs. Tissue dielectric constant (TDC) | n= 18 LE n= 12 control | NR | No discernible correlation between tonometry and TDC for either controls or LE patients | NR
Mayrovitz93 2008 U.S. | Tissue Di-electric constant | n=10 | NR | Correlations were 0.99 for the nonedematous arm, and 0.98 for the edematous arm | NR
Mayrovitz94 2009 U.S. | One Tissue Di-electric constant measurement vs. average Tissue Di-electric constant measurements | n=10 LE group n=20 Control group | NR | Correlation between single TDC measurement and average TDC measurements were: Edematous arm: 0.98 Non-edematous arm: 0.99 | NR
Mayrovitz66 2000 U.S. | Circumference measurements: Manual (Gulick tape measure) vs. automated (optoelectric system [Pero-System, Perometer Model 350S}) | Total pts n=62 legs n=142 arms n=42 | NR | Correlation coefficients between measures were 0.98 for legs and 0.96 for arms | NR
Megens82 2001 Canada | Circumference and volume measurements | n=25 | ICCs for interrater and test-retest reliability: Circumferential data 0.99 Volumetric data 0.99 | NR | NR
Meijer77 2004 Netherlands | Indirect volume determination (Sitzia's method) vs. water displacement | n=30 | Intrarater reliability for water displacement ranged from 0.95 to 0.98 Intrarater reliability for Sitzia’s method ranged from .90 to .99 with one low ICC of .62 | Comparing Sitzia’s method to water displacement: ICCs ranged from 0.71 to 0.87 Comparison of arm circumference measures at 4 cm with measures at 8 cm ICCs of 0.80 for one rater and 0.92 for a second rater | NR
Mellor76 2004 U.K. | Dermascan ultrasound | n=10 | NR | Ultrasound strongly correlated with arm circumference, r=0.95 | NR
Mirnajafi75 2004 Australia | Torsional rigidity of skin | n=17 | NR | Power to rotate normal skin exceeded power to rotate diseased skin by 46.3%. Not significant (p=0.13) | NR
Moseley67 2002 Australia | Bioimpedance vs. Tonometry | n=12 healthy volunteers n=12 LE patients | Covariance for bioimpedance ranged from 0.002 to 0.0086 Covariance for tonometry ranged from 0.0129 to 0.0325 | NR | NR
Moseley80 2002 Australia | Perometry and bioimpedance | n=33 | NR | Correlation coefficient between perometry and bioimpedance was 0.61 | NR
Norman83 2001 U.S. | Index Test: Self report questionnaire Reference Test: arm circumference | Total n=43 Measured independently by 2 physical therapists for interobserver agreement n=25 | Interobserver agreement high, weighted kappa of 0.80 | Weighted kappa’s ranged from 0.70 to 0.84 | NR
Peer72 2007 Canada | Index Test: ^99m^Tc-MIBI Whole Body Scan Reference Test: Clinical assessment | n=40 | NR | NR | NR
Ridner71 2007 U.S. | Circumference measurements, infrared laser perometry, bioelectrical impedance (BIS) and lymphedema and breast cancer questionnaire (LBCQ) | Study completers n=31 Data included n=25 Healthy volunteers (HV) n=14 LE n=11 | NR | Correlations among instruments ranged from 0.71 to 0.99 Significant correlation LBCQ and tests for swelling (0.61-0.76) and tightness (0.61-0.68) | NR
Ridner97 2009 U.S | Single frequency bioelectrical impedance vs. limb index ratio | n= 98 BCa survivors with LE n= 78 BCa survivors with no LE n=60 healthy controls | NR | Mean and median bioimpedance measures greater in the arms of women with lymphedema who survived breast cancer, compared to breast cancer survivors without lymphedema or healthy controls | NR
Roberts86 1995 U.K. | Modified Harpenden Skinfold Calipers Arm volume measurements | n=14 LE patients n=1 Healthy subject | Coefficient of standard variation of 5% | Correlation between caliper measures and questionnaire scores was 0.75 | NR
Sagen96 2009 Norway | Simplified water displacement instrument (SWDI) vs. Cross sectional area (CSA) by computed tomography | n= 23 | NR | Correlation of SWDI and total CSA of upper arm was r=0.904; correlation of SWDI and CSA of subcutaneous tissue r=0.867; correlation of SWDI and CSA of muscle tissue r=0.725 | NR
Spillane69 2008 Australia | Index Test: Infrared Opto-electronic perometer technique Reference Test: circumference measurements, brief questionnaire | n=66 | NR | NR | NR
Stanton91 1997 U.K | Opto-electronic limb volumeter (Perometer) and limb circumference | n=12 | NR | Correlation of 0.988 between Perometer and limb circumference in patients with LE | NR
Szuba81 2002 U.S. | Quantitative radionuclide lymphoscintigraphy | n=19 | NR | Correlation of outcome of therapy with pre-therapeutic axillary radioactivity level r=0.5 | NR
Taylor28 2006 Australia | Circumferential measurements vs. water displacement | Total n=66 n=22 BCa w/o lymphedema n=19 BCa with lymphedema, n=25 control group | Interrater reliability for circumferential measurements ranged from 0.97 to 0.99 Interrater reliability for water displacement measurements ranged from 0.94 to 0.99 | Correlations between methods was 0.98 | Standard error of mean ≤150 mL
Tewari89 2008 Australia | Circumferential measurements | n=87 total n=174 arms measured | NR | Pearson’s correlation between circumferential and volumetric measurements was 0.92 for narrow tape and 0.88 for wide tape | NR
Ward87 1992 Australia | Multifrequency bioelectrical impedance vs. limb circumference | n=15 LE n=15 controls | NR | Impedance inversely correlated with limb size (r=0.7) | NR
Ward98 2009 Australia | Bioelectrical impedance vs. Perometry | n=66 total n=45 with BCa LE n=21 healthy controls | NR | Correlation between bioimpedance and perometry was r=0.926 for total subject cohort (LE + controls) and r=0.919 for LE subjects alone | NR
York99 2009 Australia | Bioimpedance spectroscopy (BIS) vs. single frequency bioimpedance analysis (SFBIA) | n=28 Arm LE n=16 Leg LE n=28 Healthy controls | NR | High concordance of BIS ratios with SFBIA for arms and legs (r=0.99) as long as SFBIA frequency from low end of spectrum. Concordance deteriorated as frequency increased. | NR

Abbreviations: BCa=Breast Cancer, BIS=Bioimpedance Spectroscopy, BMI=Body Mass Index, ICC=intraclass correlation, IWV=Inverse water Volumetry, LE=Lymphedema; MFBIA=Multiple Frequency Bioelectrical Impedance Analysis, NR=Not Reported (indicates that no information on this item was contained in the published study), SOAC=Sum of Arm Circumference, TDC=Tissue Di-electric constant.

The comparator in one study was an author developed, 4-item questionnaire about truncal swelling.86 The degree of swelling was scored from 0 to 8, with higher scores indicating more swelling. The authors do not report how they developed this questionnaire, or whether they tested its psychometric properties prior to use in the study.

The thrust of most of the studies was to compare one or more tests to a measure of limb volume or circumference, thereby suggesting that the gold standard would actually be limb volume or circumference (although these measures were rarely identified as gold standards by study authors). In some cases, volume or circumference measures were compared against one another (e.g., Chen et al.,31 Karges et al.,79 Latchford et al.,84 Godoy et al.70) or in conjunction with one another.70

d) What is the sensitivity and specificity of tests used to diagnose lymphedema?

The authors of eight studies68-70,72,74,78,83,95 examined the sensitivity and specificity of tests to diagnose lymphedema (Table 9). Six studies included tests that involved changes in volume or circumference.68-70,74,78,95 The authors of one study diagnosed lymphedema using a difference in arm circumference of 5 cm between the treated and untreated arms.68 A second test in the same study was self-report, which consisted of a ‘yes or no’ question about whether subjects experienced swelling since the diagnosis of breast cancer. The test of interest in this study was bioimpedance. Sensitivity and specificity were 42 percent and 88 percent for arm circumference and 61 percent and 59 percent for self report, compared to bioimpedance.

Table 9 Sensitivity and specificity studies

Author | Study Design | Sample Size | Inclusion/Exclusion Criteria | Index Test | Reference Test | Sensitivity/Specificity
Bland78 2003 U.S. | Sensitivity/Specificity | n=90 | ≥18 years, male or female eligible. New diagnosed resectable BCa. Scheduled for mastectomy or lumpectomy, with lymph node sampling, dissection, or sentinel node biopsy, or breast conservation therapy followed by radiation therapy. Participants average age was 53.7 years, all female, half of patients had RT | Percent change in circumferential measurements above and below the elbow | 10% change or more in volume. 1 cm change in circumference at any site | Sensitivity 37% and Specificity 92% for a 10% change in circumference above and below elbow Sensitivity 80% and Specificity 71% for a 5% change in circumference above and below elbow
Cornish95 2001 Australia | Sensitivity/Specificity | n=102 n=60 control | Dx BCa, living within 50 km of Brisbane pathological confirmation of tumor malignancy Axillary dissection | Bioimpedance (BI) | Limb volume | Sensitivity BI vs. limb Volume=100% Specificity BI=98%
Godoy70 2007 Brazil | Sensitivity/Specificity | n= 90 | Women with LE following surgery for BCa Mean age 54.8 ± 11.7 yrs | Perometry | Volumetry | Comparator test was unclear; Sensitivity ranged from 73 to 90%; specificity ranged from 69 to 78 percent
Hayes74 2005 Australia | Sensitivity/Specificity | Total n=294 Clinical component n=218 Data complete n=176 | Dx with unilateral BCa ≤6 months, aged ≤75 years, residing within 100 km of Brisbane | MFBIA | SOAC Self report | Difference in SOAC >5 cm: Sensitivity 35%, Specificity 89%. Difference in SOAC >10 cm: Sensitivity 5%, Specificity 100%; Self report Sensitivity 65%, Sensitivity 77%
Hayes68 2008 Australia | Sensitivity/Specificity | n=287 | Women with unilateral BCa <75 years, (avg. 54±10 years) residing within 100 km of Brisbane; with or without LE after Rx | BIS | SOAC Self report | Sensitivity 42% SOAC vs. BIS, Specificity 88% Sensitivity 61% Self report vs. BIS, Specificity 59%
Norman83 2001 U.S. | Sensitivity/Specificity, reliability and validity | Total n=43 measured independently by 2 physical therapists for interobserver agreement n=25 | LE following Rx for BCa; 41 unilateral, 2 bilateral; mean age 54.1 years; all female; all women had LE diagnosed by their therapists | Self report questionnaire | Clinical assessment (limb circumference measurement) | Questionnaire sensitivity 93 to 96% and Specificity 69 to 75% for the Dx of LE
Peer72 2007 Canada | Sensitivity/Specificity | n=40 | 21 men and 19 women, mean age 36.68 (20-71) years with AIDS-KS; Dx confirmed by titer and biopsy | ^99m^Tc-MIBI Whole Body Scan | Clinical assessment | 18/40 subjects diagnosed with LE using ^99m^Tc-MIBI 12/40 subjects diagnosed with LE using clinical examination
Spillane69 2008 Australia | Sensitivity/Specificity | n=66 | Patients who had previously undergone an inguinal or ilio-inguinal dissection for melanoma >6 months previous, 31 male, 35 female, median age 44.2 (20-95) years range (20-95 years), 9 received RT | Infrared Opto-electronic perometer technique | Arm circumference Self assessment questionnaire | Sensitivity 56% and Specificity 95% for perometry vs. self assessment Sensitivity 50% and Specificity 100% for perometry vs. arm circumference

Abbreviations: AIDS-KS=Acquired Immune Deficiency Syndrome-Karposi’s Sarcoma, BCa=Breast Cancer, BIBioimpedance, BIS Bioimpedance Spectroscopy, DxDiagnosis LE=Lymphedema, MFBIA=Multifrequency Bioelectrical Impedance, Rx=treatment, SOAC=Sum of Arm Circumference

Another study contained measures of whole limb volume perometry and arm circumference on persons diagnosed with lymphedema following melanoma.69 Perometry changes of at least 15 percent and circumference changes of at least 7 percent signified lymphedema. The test of interest was patient self assessment of whether lymphedema was moderate or severe. Sensitivity and specificity were 56 percent and 95 percent for perometry and 50 percent and 100 percent for arm circumference, compared to self assessment. The authors of another study, conducted with persons suffering from lymphedema following breast cancer, compared an abbreviated number of circumferential measurements to a more extensive number of measurements.78 For the abbreviated regimen, two measurements were taken, one above and one below the elbow. The comparator test involved measurements taken across the palm of the hand, at the wrist, at 10 cm intervals proximal to the wrist, and at the elbow. Sensitivity and specificity were 37 percent and 92 percent for the abbreviated measurement regimen when a 10 percent change in circumference versus the preoperative state was defined as lymphedema. When the threshold change was lowered to 5 percent, sensitivity was 80 percent and specificity was 71 percent.78

Persons with breast cancer were included in a study where the tests of interest involved differences in the sum of arm circumference between the treated and untreated arms.74 Circumferential differences to diagnose lymphedema were established at ≥5 cm and ≥10 cm. A self report test was also evaluated in the study. Self report contained one question asking patients if they experienced swelling after the diagnosis of lymphedema (response: yes or no). The test of interest was multifrequency bioimpedance. For differences of ≥5 cm versus bioimpedance, sensitivity was 35 percent and specificity was 89 percent; for differences of ≥10 cm versus bioimpedance, sensitivity was 5 percent and specificity was 100 percent; for self report compared to bioimpedance, sensitivity was 65 percent and specificity was 77 percent.

Bioimpedance was again used diagnostically in a study of 102 persons with breast cancer.95 Bioimpedeance measures were taken prior to surgery, one month postsurgery, and then at two month intervals until 24 months following surgery. Clinical diagnosis of secondary lymphedema was established through measures of limb volume. The sensitivity of bioimpedance compared to limb volume was 100 percent and the specificity was 98 percent.

A self report served as the test of interest in a study involving persons with breast cancer.83 This self report contained two questions asking patients whether they noticed if and to what extent their limbs were a different size. The comparator was assessment by a physiotherapist, which was either rule based (i.e., measured changes in circumferential measurement) or clinical observation. Sensitivity comparisons to the rule based and clinical assessments ranged from 93 to 96 percent; specificity comparisons ranged from 69 to 75 percent.

In a study composed of persons with AIDS-related Kaposi’s Sarcoma, the tests of interest were a ^99m^Tc-hexakis-2-methoxy isobutyl isonitrate scan (scintigraphy) and an undefined clinical examination.72 Forty persons were included in the study and 18 were diagnosed with lymphedema using the scan and 12 were diagnosed using the clinical examination.

The final study assessed sensitivity and specificity for multiple cut off points using volumetry and perometry taken together as a joined set of measurements.70 The comparator test was unclear. Sensitivity ranged from 73 to 90 percent; specificity ranged from 69 to 78 percent.

e) What is the performance of diagnostic tests for preclinical and/or clinically significant lymphedema? Consider – what are the psychometric properties (reliability, validity, responsiveness) of these diagnostic methods?

Reliability. Nine studies examined the reliability of different diagnostic tests for lymphedema (Table 8).28,30,31,67,77,82,83,86,100 Seven of the nine studies involved diagnoses using circumferential measurement or volume displacement.28,30,31,77,82,83,100 In general, both test-retest and interrater reliability of circumferential measurement and volume displacement were extremely high, with intraclass correlation coefficients (ICCs) ranging from 0.91 to 0.99.^30,31,77,82^ In one study, a single rater had an uncharacteristically low test-retest ICC of 0.62 for indirect volume determination using Sitzia’s method (a formulaic method of calculating volume displacement using circumference, with circumference measures of the arm being taken at 8 cm intervals).77 In fact, it was the use of Sitzia’s method that produced the lowest ICCs in any of the seven volume or circumference studies (i.e., all ICCs below 0.91 resulted from tests involving Sitzia’s method).

The authors of a study on circumferential measures and water displacement assessed interrater reliability using the intrasubject correlation, which is based on analysis of variance and multilevel modeling.28 Like the ICCs, the intrasubject correlations were quite high (i.e., 0.94 to 0.99).

In one study, two physiotherapists developed a scale to measure the severity of lymphedema (see Question 1b).83 The physiotherapists had high interrater agreement with one another; they agreed on ratings for 20 of 25 persons, with a weighted kappa of 0.80.

Tissue resistance measured with a tonometer was evaluated in two studies. ICCs for test-retest and interrater reliability ranged from 0.69 to 0.88^31^ The between-subject reproducibility of tonometry, measured by dividing the standard deviation of all patient values by the mean of all patient values (to calculate the covariance), was good because the covariance was low (0.002 to 0.0086).67 Bioimpedance also had good reliability, which was indicated by a low covariance (0.0129 to 0.0325).67

One study contained an assessment of truncal swelling due to secondary lymphedema.86 On two consecutive days, the authors took truncal skinfold measurements using calipers from five study participants. Test-retest reliability was excellent (correlation coefficient of 0.99).

The final reliability study examined intrarater and interrater reliability for four diagnostic tests: visual analogue scale of self reported swelling, arm circumference assessed using a tape measure, arm volume assessed using a perometry, and bioimpedance.100 ICCs for intrarater reliability ranged from 0.95 to 1.00 for the three physical measures and 0.50 for the visual analogue scale. Interrater reliability, calculated for the physical measures only, ranged from 0.98 to 1.00.

Validity. Thirty studies contained examinations of the validity of various tests to diagnose secondary lymphedema (Table 9). Twenty-six studies involved lymphedema of the arm,27,28,36,71,73,75-77,79,81,83-85,87-94,96-100 two of the legs,80,136 and one of the truncal area.86 One study included persons with leg or arm lymphedema.66

All except six of the validity studies included a test of limb volume or circumference. Of the six exceptions, three studies were undertaken to assess lymphedema using measurements of tissue dielectric constant.93,94,136 The correlation between a single measure of tissue dielectric constant and the mean of three measures was greater than or equal to 0.98 in two studies.93,94 There was no correlation between tissue dielectric constant and tissue indentation force (r = - 0.07) in another study.136

A study without limb volume or circumference was a comparison of lymphoscintigraphy and clinical assessment (see Question 1b) to stage lymphedema on a five-point scale.92 The weighted kappa of 0.77 indicated excellent agreement on staging between these methods. A 4-item questionnaire on truncal swelling was compared to caliper-based skinfold measures of truncal swelling in a study of 12 persons.86 The questionnaire was developed by the authors and there was no report of whether it was validated prior to use in the study. The correlation between caliper measures of ‘creep’ (i.e., skin deformations over time) and the questionnaire score (score range is 0 to 8, with higher scores indicating more swelling) was 0.75. The final validity study without a measure of limb volume or circumference compared the torsional rigidity of normal versus lymphedema-affected skin in a group of persons with secondary lymphedema.75 The authors found that the power to rotate normal skin exceeded the power to rotate diseased skin by 46.3 percent, although the difference was not statistically significant at the 5 percent level (p = 0.13).

Two validity studies compared perometer to tape measure. Correlation coefficients between measures were 0.98 for legs and 0.96 for arms in one study66 and 0.99 for arms in the other study.91

Seven studies measured water displacement and made comparisons with limb circumference. In one of these studies, limb circumference was measured using frustrum calculation and tape measure.79 In frustrum calculation, the limb is viewed as a geometric shape (usually a cone) and specialized formulae are used to measure circumference. In three other studies, limb circumference was calculated using tape measure alone28,89 or an unexplained method.90 Correlation coefficients ranged from 0.88 to 0.99. In the fifth study, inverse water volumetry was compared to limb circumference expressed as a ratio between the affected and unaffected limbs and the ICCs ranged from 0.89 to 0.91.^73^ In the sixth study, water displacement was compared to Sitzia’s method (a specific formula for frustrum calculation137) of measuring arm circumference (at 4 or 8 cm intervals) and ICCs ranged from 0.71 to 0.87.^77^ Comparison of arm circumference measures at 4 cm with measures at 8 cm yielded ICCs of 0.80 for one rater and 0.92 for a second rater. The seventh study compared interstitial fluid pressure with arm volume (r = 0.29 after outlier removal).88

The focus of one study was entirely on different interval measures of arm circumference.84 Intervals of 10 cm were compared to intervals of 3.81 cm (1.5 inches) and the correlation between measures was calculated to be 0.94 or greater.

One study was undertaken to compare two types of physiotherapists’ assessments of arm circumference (see Question 1b) to a self report questionnaire.83 The self report questionnaire asked respondents to indicate whether their affected and unaffected limbs were a different size and whether the differences were noticeable. Weighted kappa’s ranged from 0.70 to 0.84, primarily depending on the type of assessment. The lowest kappa’s were estimated when the rule-based assessment of arm circumference was compared to the questionnaire (kappa’s of 0.70 and 0.76).

Five studies involved bioimpedance and a group of other tests: perometer alone,80,98 tape measure alone,85,87 or the combination of perometer, tape measure, and the Lymphedema Breast Cancer Questionnaire (LBCQ).71 In three of these five studies,71,80,87 correlation coefficients between all tests ranged from 0.61 to 0.99, with lows of 0.61 between bioimpedance and perometer80 and 0.70 between bioimpedance and arm circumference assessed with tape measure.87 Statistically significant correlations between symptoms on the LBCQ and other tests were limited to two domains, namely swelling and firmness/tightness (correlation coefficients between 0.61 and 0.76).71 The fifth study involving bioimpedance contained an undefined measure of ‘bias’, expressed as a percentage, to examine agreement with tape measure.85 The authors stated that lower bias indicated better agreement. Bias scores decreased from 31 to 15 percent between days 1 to 26 of followup.

Three symptoms on the LBCQ were found to be predictive of a ≥2 cm difference in arm circumference.36 Odds ratios (95 percent confidence intervals) for each domain were 8.0 (1.2 to 54.7) for heaviness, 96.9 (9.9 to 951.6) for swelling, and 9.9 (1.8 to 53.9) for numbness. The large odds ratio for swelling reflects the fact that all except one subject with swelling also had a ≥2 cm difference in arm circumference.

Two studies involved bioimpedance alone. The first study found that mean and median bioimpedance measures were greater in the arms of women with lymphedema who survived breast cancer, compared to breast cancer survivors without lymphedema or healthy controls.97 Another study found single-frequency bioimpedance to be highly correlated (r = 0.99) with bioimpedance spectroscopy.99

Ultrasound was used to measure skin thickness in one study with arm circumference as the comparator test.76 Ultrasound measures of average skin thickness were strongly correlated with arm circumference (r = 0.95) and duration of edema (r = 0.68). Average subcutis thickness was also strongly correlated with arm circumference (r = 0.84) and duration of edema (r = 0.67).

In another imaging study, lymphoscintigraphy was compared to arm volume.81 The outcome of therapy, which was a combination of MLD, compression bandages, and exercise, was moderately correlated with pre-therapeutic axillary radioactivity level (r = 0.50). The authors also reported that the lymphoscintigraphy score on the 8-point scoring system (see Question 1b) was positively correlated with the magnitude of excess arm volume, duration of lymphedema prior to receipt of therapy, and elapsed time since surgery for breast cancer. However, no correlation coefficients were provided for these comparisons.

A final imaging study found correlations of 0.73 and 0.87 when cross-sectional CT scans of the muscles and subcutaneous tissue were compared to water displacement.96 In the same study, the authors compared MRI signal intensity to water displacement and calculated a kappa of 0.78.

One other study assessed validity without the benefit of using correlation coefficients or ICCs.27 Four different diagnostic tests were used to estimate the incidence of lymphedema after 6 or 12 months of followup in persons diagnosed with breast cancer.27 The four tests were 200 mL difference in limb volume, 10 percent change in limb volume, 2 cm change in limb volume, or reports of limb swelling or heaviness (currently or in the past year) on the LBCQ. Incidence of lymphedema estimated with the 200 mL test was 24 percent after 6 months and 42 percent after 12 months. Incidence estimated with the 10 percent change test was 8 percent after 6 months and 21 percent after 12 months. Incidence estimated with the 2 cm change test was 46 percent after 6 months and 70 percent after 12 months. Incidence estimated with reports of limb swelling or heaviness was 19 percent after 6 months and 40 percent after 12 months.

A final validity study compared correlations across four different tests: a visual analogue scale to capture self-reported degree of swelling, tape-measured arm circumference, arm volume measured by perometry, and bioimpedance.100 Correlations ranged from 0.65 to 0.71 when the scale was compared to each of the three physical measures. Among the physical measures alone, correlations ranged from 0.89 to 0.99.

Responsiveness. Only two studies contained examinations of responsiveness to change (Table 8).28,31 In the first study, responsiveness was defined as the smallest difference that could be detectable by the use of water displacement, limb circumference measurement, or tissue resistance.31 Differences were 75 mL for water displacement, 0.46 to 1.02 cm for limb circumference measurement, and 0.32 to 1.01 mm for tissue resistance. In the second study, a standard error of the mean of less than or equal to 150 mL was found to be measurement error in an investigation of limb circumference measurement and water displacement.28 Both studies recruited persons with breast cancer, although one study also included an undefined control group.28

f) How frequently and for how long should patients be measured for the development of lymphedema or its sub-clinical precursor? Does this vary with the diagnostic test method?

Fifteen of the 41 diagnostic studies included in this report involved a single assessment of patients (Table 7).30,31,67,69,71,72,74,87-91,96,98,99 The authors of one of these studies reported that two of 40 patients received a repeat ^99m^Tc-hexakis-2-methoxy isobutyl isonitrate scan,72 but no reason was given for performing the second test. None of the authors provided a rationale for limiting their assessments to a single point in time.

The remaining 26 studies involved two or more assessments. In four studies, there were repeat assessments without a clear rationale to explain why.66,68,78,136

Seven of the 26 studies contained multiple assessments to permit the study of test-retest or interrater reliability.28,73,77,79,82,83,100 These repeat assessments were typically performed two or three times, usually on the same day, 1 week apart, or 4 weeks apart.

In six studies, two assessments were conducted to assess the validity of various tests: lymphoscintigraphy versus clinical examination,92 lymphoscintigraphy versus arm volume,81 torsional rigidity on swollen and non-swollen arms,75 ultrasound versus arm circumference,76 LBCQ versus arm circumference,36 and 10 cm versus 3.81 cm (1.5 inches) measures of arm volume.84

One study, on truncal lymphedema, contained two sets of two assessments to examine the test-retest reliability of skinfold caliper measurements and the validity of caliper measurements versus a 4-item questionnaire about truncal swelling.86

More than two assessments were done in seven of the 26 studies: a mean of two assessments to compare single frequency bioimpedance and bioimpedance spectroscopy;97 four assessments to compare a single measure of tissue dielectric constant with the mean of three measures of tissue dielectric constant;93,94 five quarterly assessments to examine the calculation of incidence of lymphedema over time using each of four methods (i.e., 200 mL difference in limb volume, 10 percent change in limb volume, 2 cm change in limb volume, or self reported limb swelling or heaviness);27 five assessments (baseline, once weekly for 3 weeks, and 1 month post-baseline) to study the correlation of bioimpedance and perometry over time;80 seven assessments of volumetry versus perometry at different cut off points;70 and a maximum of 14 assessments to examine the diagnostic capability of bioimpedance.95

In the last of the 26 studies, measures of limb circumference and bioimpedance were taken daily for 4 weeks as part of the treatment protocol for a larger study being done to investigate a self-management program for lymphedema.85

In the 26 studies with multiple assessments, all except eight studies75,86,92-94,97,99,136 included either limb volume or limb circumference as a diagnostic test. None of the 26 studies contained recommendations for the length of time that patients should be measured for the development of lymphedema, nor was there any evidence of variance based on type of test.

g) Does the diagnostic test method influence the choice of lymphedema treatment or patient outcome? What outcomes were measured in studies of diagnostic tests of lymphedema?

None of the 41 diagnostic studies reported whether a specific test influenced the choice of treatment or an outcome. In fact, the authors of only four studies mentioned the lymphedema treatment that was being given to patients. Treatments included complex decongestive therapy (CDT),66 a program to elevate and passively exercise the legs,80 self-management following an intensive, 4 week phase of compression therapy, massage, and compression bandaging, and85 a combination therapy of MLD, compression bandaging, and exercise.81 In three studies, the ongoing evaluation of these three treatments provided an opportunity to investigate diagnostic tests.66,80,85 The tests did not drive the choice of treatment nor outcome. In the fourth study, patients diagnosed with lymphedema during followup received combination therapy, but the published report did not contain information on the extent to which the therapy may have been selected with the diagnostic test (lymphoscintigraphy) in mind.81 None of the 41 studies reported on patient outcomes because they were concerned with the diagnosis of lymphedema, rather than the resolution of the condition.

## Treatment Studies

Question 2. What were the patient selection criteria in the studies (inclusion and exclusion criteria)? Did they differ by treatment modality?

The primary inclusion criterion in 32 of 36 treatment studies extracted for the report was lymphedema secondary to breast cancer (Table 10).33,47,48,50,103-105,107-125,127-130,133,134 Focusing only on the 23 RCTs with a Jadad score between 4 and 8 (fair or good methodological quality), most trials included women with secondary lymphedema due to breast cancer. Twelve of the 23 RCTs with a Jadad score between 4 - 8 contained specifications that participants must be in remission, have no relapse, or have no metastases.48,108,110-112,115-117,124,127-129 Five of these 23 RCTs contained definitions of lymphedema as ‘mild’,110,115 ‘moderate to severe’,124,128 or ‘chronic’.111 Other definitions included categorization of lymphedema by excess volume in the affected limb,48,108,113,114,116,127 degree of swelling and excess volume,33,115 or degree of swelling alone.118,121 Eight of the trials with a Jadad score above 3 excluded participants with comorbidities that would affect swelling or the ability to receive treatment,108,109,111,112,118,124,127,128 eight excluded persons who received treatment within the 6 month period prior to baseline (treatment for lymphedema,48,109,110,115,123,128,129 treatment for something unspecified112), and five had a minimum elapsed time requirement between treatment and study enrolment (time since radiation,108,120 time since surgery,115 time since ‘treatment’47,124). Six trials with Jadad scores between 4 and 8 had age requirements for inclusion33,47,120,122,124,127 and five others had a minimum arm circumference or volume requirement for inclusion.112,117,119,123,124 There were at least 21 other inclusion and exclusion criteria in the 23 RCTs with Jadad scores between 4 and 8 (Table 10); however, none of these criteria appeared in more than three trials and most did not appear in more than one RCT.

Table 10 Treatment basic study data

Study | Study Design | Type of Treatment | Sample Size | Cause of Lymphedema | Definition of Lymphedema | Co-morbidities | Other Inclusion/Exclusion Criteria
RCT
Andersen115 2000 Denmark | Prospective Randomized Study | MLD as adjunct therapy | Intervention: n=20 Control: n=22 | ≥4 months post surgery LE secondary to BCa treatment | 1+ LE symptoms volume ≥200 ml between arms and/or ≥2 cm circumference difference | NR | Exclusion: - bilateral BCa - treatment for LE during previous 3 mths - BCa recurrence - severe LE arm volume difference >30%
Bertelli110 1991 Italy | RCT | Electronically stimulated lymphatic drainage (ESLD) | n=37 ESLD n=37 Control | LE secondary to unilateral radical, modified mastectomy or quadrantectomy with axillary node dissection | Mild LE (delta value >10 cm and <20 cm) | NR | Inclusion: - no evidence of distant metastases or local relapse - no Rx in last 6 mths - no signs of lymphangitis Exclusion: - wearing a cardiac stimulator - currently receiving CT or RT
Bialoszewski126 2009 Poland | RCT | Kinesiotape vs. lymphatic drainage | n=12 n=12 | Lower extremity LE after leg lengthening operation | Physical examination and radiographic images to Dx LE | NR | Inclusion: -age 15-40 years
Carati33 2003 Australia | RCT crossover plus within group comparison of one cycle vs. two cycle | LLLT one cycle vs. LLLT two cycles | n=37 n=27 | LE secondary to BCa treatment | >200 ml difference between arms or ≥2 cm difference in arm circumference | NR | Inclusion: - female Exclusion: - presence of co-morbidities - significant change to the arm in past 3 months - inability to abduct arm for measurement - presence of primary LE of lower limbs
Damstra124 2009 Netherlands | RCT | Compression therapy: low vs. high pressure bandaging | n=18 low pressure n=18 high pressure | LE following BCa | Patients with moderate to severe LE as defined by ISL | NR | Inclusion: -female ->18 years of age -12 months post BCa Rx without signs of reoccurrence Exclusion: -allergy to materials -systemic diseases -arterial or venous disease
Didem119 2005 Turkey | RCT | Complex Decongestive Physiotherapy vs. Standard Physiotherapy | n=27 CDP n=26 SP | LE following BCa surgery and/or RT/CT | Arm circumference difference of 2-5 cm | NR | Inclusion: - LE ≥1 year Exclusion: - obvious psychiatric Illness - severe pain in axillary region - severe cardiac disease - uncontrolled hypertension - malignancy
Dini112 1998 Italy | RCT | IPC | n=40 IPC n=40 Control | LE following BCa surgery and/or RT/CT | Arm circumference difference of 2-5 cm from unaffected arm | NR | Inclusion: - LE ≥1 year - no lymphangitis - no evidence of local or distant relapse - no other serious or psychiatric illness that would preclude treatment or follow-up Exclusion: - prior specific therapy for LE - bilateral breast surgery - bilateral axillary node dissection
Hayes47 2009 Australia | RCT | Mixed exercise program (aerobic and resistance) | n=16 Exercise n=16 Control | LE secondary to BCa treatment | Upper limb LE diagnosed by a health professional | NR | Inclusion: - women <76 years with completed Rx for unilateral BCa ≥6 months prior - able to travel to clinic for exercise for 12 weeks
Hou105 2008 China | RCT | Bone Marrow Stromal Cell Transplantation or Complex Decongestive Therapy | n=15 BMSC n=35 CDT | Lymphedema secondary to BCa | NR | NR | Exclusion: - radiotherapy
Irdesel129 2007 Turkey | RCT | Compression garment and exercise | n=10 exercise n=11 exercise + compression | LE secondary BCa | NR | NR | Exclusion: -BCa operation <4 months ago -recurrence or bilateral BCa -elephantiasis -congestive heart failure -deep vein thrombosis -acute infection -stage 4 BCa
Jahr120 2008 Germany | RCT | Deep Oscillation® (DO) plus MLD | n=11 DO + MLD n=10 MLD | LE secondary to BCa treatment | NR | NR | Inclusion: - age 18-80 years, updated documentation of aftercare - pt living near study center - ≥6 weeks since RT Exclusion: - Deep Oscillation® Rx in 3 months preceding study - acute inflammation - acute thrombosis - heart disease - electronic implant - pregnancy subject - sensitivity to electric fields
Johansson109 1998 Sweden | RCT | MLD vs. sequential pneumatic compression | n=14 MLD n=14 SPC | Unilateral LE after BCa surgery with axillary nodal dissection | >10% difference in LE affected arm vs. unaffected arm | NR | Exclusion: - previous contralateral breast disease - intercurrent disease affecting the swollen arm - difficulty participating for reasons such as dementia - treatment within the last 6 mths (except for wearing compression sleeve) - resolution of LE during initial use compression sleeve by all participants
Kaviani118 2006 Iran | RCT | LLLT | n=4 LLLT n=4 Control | LE secondary to BCa treatment | ≥2 cm swelling in affected arm | NR | Inclusion: - no contraindications to laser therapy Exclusion: - metastatic disease
Kessler106 2003 Switzerland | RCT | Standard physiotherapy plus manual lymphatic drainage | n=11 SP and MLD n=12 SP | LE following hindfoot surgery | Clinically diagnosed post-operative swelling | NR | - Age: 18-75 yrs - good physical condition - no contraindications for lymph drainage
Kozanoglu104 2009 Turkey | RCT | Pneumatic compression vs. low level laser therapy | n=25 PC n=25 LLLT | Modified radical mastectomy with complete axillary dissection and radiotherapy | LE defined as difference of more than 2 cm at 3/7 points | | Inclusion: - history of arm LE for at least 3 months Exclusion: - metastases - ongoing RT - cellulitis - venous thrombosis - inflammatory disease - history of severe trauma - photosensitivity - medications that affect electrolyte balance - limitation in UE joints - physical therapy other than skin care - home exercises for LE in past 6 months
Lau127 2009 China | RCT | LLLT vs. no Rx | n=11 LLLT n=10 control | LE secondary to BCa treatment | Arm volume difference of more 200 ml | NR | Inclusion: -18+ years -unilateral mastectomy + chemo and/or radiation Exclusion: -metastases -Hx of severe trauma to arm -kidney, heart or lung disorder -medications that alter body fluids -primary LE of lower limb -decrease shoulder ROM -cellulitis past 3 months
Maiya121 2008 India | RCT | LLLT and exercise | n=10 LLLT + exercise n=10 control (compression + exercise) | LE secondary to BCa treatment | circumference of UE 2 cm at any 2 points compared to normal limb | NR | Inclusion: - mastectomy for BCa - completion of RT Exclusion: - primary LE - infection of the limb
McKenzie107 2003 Canada | RCT | Exercise (resistance training plus arm ergometer) | n=7 Exercise n=7 Control | LE secondary to BCa | LE >2 cm and <8 cm at 1 measurement point | NR | Exclusion: - stage III LE - bilateral disease - medication that effects swelling
McNeely123 2004 Canada | RCT | MLD with CB vs. CB alone | n=22 intervention n=20 control | LE secondary to BCa | ≥150 ml difference between arms | NR | Inclusion: - ≥4 months since wearing compression sleeve - ≥6 months since active Rx for LE Exclusion: - local Ca recurrence - distant metastases - undergoing RT or CT - infection in LE limb - evidence of contraindications to Rx - uncontrolled hypertension - heart disease - renal insufficiency - venous thrombosis
Pilch125 2009 Poland | RCT | IPC with varied compression and sleeve type | n=57 | LE secondary BCa | NR | NR | Inclusion: -age 39-80 years
Radakovic103 1998 Yugoslavia | RCT | Manual drainage vs. sequential external pneumatic compression | n=18 manual drainage n=18 SEPC | Women with amputated breast and axillary gland | NR | NR | Inclusion: - women with no sign of metastatic changes - patients referred after RT
Schmitz48 2009 U.S *companion Schmitz138 | RCT | Weight lifting vs. no weight lifting | n= 141 intervention n=71 control n=70 | LE secondary to BCa | Difference in volume or circumference of 10% or more affected vs. unaffected arm | NR | Inclusion: -1-15 years since BCa Dx -unilateral LE -BMI less 50 -not actively trying to lose weight -no evidence of cancer -no medical conditions that would limit exercise -no history of weight lifting in past year -at least one lymph node removed
Shaw 116 2007 U.K. | RCT | Weight reduction program along with conventional treatment with compression hosiery | n=21 intervention n=11 control n=10 | Arm LE following surgery for BCa | Affected arm volume ≥15% larger than unaffected | May or may not have been receiving hormone treatment | Inclusion: - remission from Ca - BMI ≥25 kg/m^2^
Shaw 117 2007 U.K. | RCT | Diet intervention plus multilayer bandaging then compression hosiery or hosiery alone | n=19 weight reduction n=17 low fat diet n=15 control | Arm LE secondary to BCa treatment | ≥20% greater volume than unaffected arm | NR | Inclusion: - Ca remission
Sitzia122 2002 U.K. | RCT | MLD vs. SLD | n=15 MLD n=13 SLD | LE secondary to BCa | Moderate or severe edema (≥20%) | NR | Inclusion: - 18+ yrs - no active disease - no previous Rx except support hosiery
Szuba108 2002 U.S | Study 1 Randomized prospective study | IPC as adjunct therapy to decongestive lymphatic therapy | Study 1 n=12 IPC and DLT n=11 DLT | Study 1 unilateral BCa related LE | ≥20% increase in volume compared to unaffected arm | NR | Inclusion: - ≥12 wks post Rx Exclusion: - active infection - Ca recurrence - concomitant venous occlusion
Szuba111 2002 U.S. | Study 2: Randomized controlled crossover study | IPC as adjunct therapy to daily maintenance (compression garment, self administered manual lymphatic massage) | Study 2: n=13 maintenance n=12 maintenance + IPC | Study 2 unilateral BCa related chronic LE | NR | NR | Inclusion - completed intensive DLT ≥1 mo and <1 yr previously Exclusion: - active infection - Ca recurrence - concomitant venous occlusion - bilateral LE of upper extremity
Tsai128 2009 China | RCT | DLT + IPC with short stretch bandages vs. DLT + IPC with kinesiotape | n=21 DLT n=20 DLT with kinesiotape | LE secondary BCa | Moderate or severe LE (2 cm + difference between arms) | NR | Inclusion: -unilateral LE 3+ months Exclusion: -active Ca -diuretics or other lymphedema influencing drugs -port catheter -skin disease -irremovable bracelet/ring -decrease ROM UE
Wilburn113 2006 U.S. | RCT crossover trial with 30 day washout period | IPC Maintenance Therapy Flexitouch™ vs. standard care (self-administered message plus elastic compression garment | n=5 Flexitouch n=5 control | Unilateral, BCa associated LE | ≥10% volume increase over normal arm | NR | Exclusion: - bilateral LE of upper extremity - active Ca - active infection - clinical evidence of venous obstruction or active thrombophlebitis - pulmonary edema - congestive heart failure - history of pulmonary embolism - contraindications to the Rx used in study
Williams114 2002 U.K. | Randomized Controlled Crossover | MLD and SLD | Group A: n=15 Group B: n=16 | LE secondary to BCa | >10% excess volume measured two times | NR | Inclusion: - >3 months, >1 yr post Ca Rx Exclusion: - active Ca - odema-influencing drugs
Observational Studies
Balzarini50 1993 Italy | Cohort | Ultrasound Therapy | n=50 treatment n=100 control | LE Secondary to BCa | % difference between arms Mild ≤6.5% Moderate 6.5 to 13% Severe ≥13% | NR | Inclusion: - chronic arm LE Exclusion: - patients who underwent regional RT
Berlin130 1999 Sweden | Cohort | Compression with sleeves vs. intermittent compression with Flowtron vs. intermittent compression Lympha-Press + compression sleeves | Total: n=46 Group 1: n=28 Group 2: n=8 Group 3: n=19 *actual total is 55 | LE secondary to BCa surgery | ≥100 ml difference between arms | NR | NR
Brambilla132 2006 Italy | Cohort | Elastic compression stockings | n=50 Elastic stockings n=15 Control | Classic Kaposi's sarcoma-associated LE | Grade II LE according to ISL | NR | Inclusion: - LE limited to below the knee
Frischenschlager 134 Austria | Cohort | MLD + compression stockings + exercise + psychosocial support vs. above treatment without psychosocial | Total n=30 Psychosocial n=15 Control n=15 | LE secondary to BCa surgery | NR | NR | Inclusion: -female
Johansson133 1999 Sweden | Cohort | CB vs. CB + MLD | n=18 CB group n=20 CB + MLD | Unilateral arm LE after BCa surgery with axillary nodal dissection | ≥10% difference in volume between abnormal and normal arm | NR | Exclusion: - contralateral breast disease - intercurrent disease affecting the swollen arm - difficulty participating for reasons such as dementia - Rx within the last 6 mths (except for wearing compression sleeve)
Pinell131 2007 U.S. | Cohort | Manipulative therapy plus bandaging | n=16 LE patients with associated chest wall/axillary or pelvic/inguinal tumors n=56 LE patients without mass | Cancer survivors with LE previously treated with surgery, RT or both | ≥2 cm difference in girth between patient’s limbs | NR | Inclusion: - referred to 2 Atlanta area clinics

Abbreviations: BCa=Breast Cancer, BMI=Body Mass Index, BMSC=Bone Marrow Stromal Cell Transplantation, Ca=Cancer, CB=Low stretch compression bandaging, CDP=Complex Decongestive Physiotherapy, CDT=Complex Decongestive Physiotherapy, CT=chemotherapy, DLT=Decongestive Lymphatic Therapy, ESLD=Electronically Stimulated Lymphatic Drainage, IPC=intermittent pneumatic compression, ISL=International Society of Lymphology, LE=Lymphedema, LLLT=Low-level Laser Treatment, MLD=Manual Lymph Drainage, mo=Month, NR=Not Reported, PC=Pneumatic Compression, pts=patients, RT=Radiation Therapy, RCT=Randomized Control Trial, ROM=Range of Motion, RT=radiotherapy, Rx=Treatment, SEPC=Sequential External Pneumatic Compression, SLD=Simple Lymphatic Drainage, SP=Standard Physiotherapy, SPC=Sequential Pneumatic Compression, UE=Upper extremity, UST=Ultrasound therapy

There were seven RCTs with Jaded scores between 1 and 3 (poor methodological quality).103-107,125,126 The inclusion criteria in these trials did not differ substantially from the trials with Jadad scores between 4 and 8. Five of the seven RCTs were conducted in breast cancer survivors. The exceptions were trials conducted in persons who had ‘hindfoot’106 or lower limb lengthening surgery.126

In the five observational studies included in the review, four were conducted in breast cancer survivors,50,130,133,134 with the fifth in persons suffering from Kaposi’s Sarcoma132 and the sixth in persons with various cancers.131 The observational studies generally had fewer inclusion and exclusion criteria than the RCTs (one observational study excepted133), but these criteria did not appreciably differ from the criteria used in the RCTs.

The inclusion and exclusion criteria were spread across the 36 studies. There was no grouping of similar criteria attached to any specific treatment modality.

Question 3. What were the criteria used to initiate treatment for lymphedema? When was treatment initiated compared to the time of onset of the lymphedema? What were the criteria used to stop therapy? Did these criteria vary with treatment modality?

In the 23 RCTs with Jadad scores between 4 and 8, the criterion used to initiate treatment was a diagnosis of secondary lymphedema. Details are shown in Table 11. This basic condition was specified as an inclusion criterion in all of the trials. In seven of these 23 RCTs, the authors specified general timeframes for recruitment compared to the time of onset of lymphedema: at least 3 months104,118 or greater than 3 months,114 a median of 9 to 10.5 months,109 less than 1 year,112 less than or equal to 2 years,119 or 0 to 5 years.113 Eleven studies contained reports of the time of recruitment following surgical or chemotherapy treatment for cancer: 3 to 6 weeks,121 at least 3 months,108 at least 4 months,115,129 at least 6 months,47,110 at least 12 months,116,117,124 between 1 month and 1 year,111 or at least 4 years.120 In five RCTs, there was no report of when treatment was initiated compared to time of onset of lymphedema or treatment for cancer.33,122,123,127,128 One study reported that subjects had a history of breast cancer 1 to 15 years before study entry.48

Table 11 Key questions treatment

Study | Question #3 | Question #4 | Question #6 | Question #8 | Question #9 | Question #11 | Question #12
Study | Time of LE Onset Time of Rx initiation Criteria to Start/stop Rx | Provider of Treatment and Qualifications | Treatment Parameters | Comparators in Study Consistent With Usual Care | Patient Outcomes Results | Length of Study Length of Followup | Did any Harms (adverse events) Occur From Rx?
RCT’s
Andersen115 2000 Denmark | LE onset: After surgery Time Rx start: ≥4 months from BCa Rx Criteria to start Rx: Unilateral LE of arm after early treatment of breast cancer Criteria to stop Rx: NR | “an experienced and certified lymphotherapist according to the Vodder school of practice” | Intervention Group: standard care + MLD and training in self-massage. Standard care=custom-made sleeve and glove garment providing 32-40 mmHg compression; educational information and recommendations; instruction in physical exercises; education in skin care. MLD=8 1hr session over 2 wk period Control Group: Standard care as described above (control group was allowed to crossover to treatment group after 3 mths) | Comparator was standard care Usual care | Change in volume of affected arm patient-reported symptoms related to LE No significant difference in arm volume or patient-reported symptoms between the 2 groups | Length of study: 2 weeks Length of followup: 12 months | NR
Bertelli110 1991 Italy | LE onset: NR Time Rx start: ≥6 months after BCa Rx Criteria to start Rx: diagnosis of secondary LE Criteria to stop Rx: change of ≥25% in circumference of LE affected arm vs. contralateral arm | NR | Intervention group: wearing standard elastic sleeve 6 hrs/day for 6 mths + ESD applied in 2 cycles of 2 wks each divided by 5 wk interval Each cycle=10 x 30 min sessions Control group: wearing standard elastic sleeve for 6 hrs/day for 6 mths | Wearing standard (not customized) elastic sleeve Consistent with usual care | Mean variation in limb measurements in 2 groups Clinically significant reduction of LE (≥25% compared to the initial values) No significant difference between the 2 groups <50% achieved a clinically significant reduction (48.4% controls and 41.4% intervention) | Length of study: 6 months Length of followup: NR | NR
Bialoszewski126 2009 Poland | LE onset: post leg lengthening surgery Time Rx start: post surgery Criteria to start Rx: LE lower extremity Criteria to stop Rx:NR | NR | Intervention group: Kinesiotaping for 10 days (tape remained on skin 10 days) Control group: lymphatic drainage 1x/day x 10days Both groups had standard physiotherapy (not described) | Kinesiotape vs. lymphatic drainage Consistent with usual care | Limb circumference Kinesiotape resulted in a significant reduction in limb circumference | Length of study: 10 days Length of followup: NR | NR
Carati33 2003 Australia | LE onset: NR Time Rx start: NR Criteria to start Rx: Diagnosis of postmastectomy LE Criteria to stop Rx: NR | NR | Intervention Group: LLLT 1 Block (9 sessions, 17 minutes each, 3x/ week x 3 weeks), 8 weeks rest followed by a repeat block of laser Control Group: Sham First Block (9 sessions, 3x week x 3 weeks), 8 weeks rest followed by a block of LLLT | LLLT vs. sham laser treatment Not consistent with usual care | Groups matched at baseline 2 LLLT sessions: 31% of pts had reduction in 2-3 mths time (>200 mls); 1 LLLT session and sham session showed NS Measured by perometry, bioimpedance, tonometry and goniometer | Length of study: 24 months Length of followup: 3 months | NR
Damstra124 2009 Netherlands | 3-50 months post surgery Time Rx start: ≥12 months post surgery Criteria to start: Dx of LE Criteria to stop: NR | specially trained staff | Bandages applied for two hours then removed and applied for 24 hours | Low stretch bandages vs. High stretch bandages Consistent with usual care | Reduction of edema volume in arm; sub-bandage pressure, patient comfort, side effects and safety No significant difference in volume change between low and high stretch bandages | 24 hours Length of follow up: none | Patients with high pressure bandages reported more pain and discomfort
Didem 119 2005 Turkey | LE onset: LE onset >1 year after surgery Time Rx start: Rx started average of 3 years after surgery Criteria to start Rx: Diagnosis of LE (mild to moderate) Criteria to stop Rx: NR | Physiotherapist | Therapy sessions: 3x/wk x 4 wks Intervention group: CDP (MLD, compression, exercise & skin care) Control group: PT (bandage, elevation, exercises) Both groups: trained for home program of compression bandage, exercise, self message, skin care, and walking | Complex decongestive therapy vs. physiotherapy Consistent with usual care | Circumference volume Range of motion (goniometry) and shoulder function CDP decrease >PT (p<0.05). No significant difference between groups ROM | Length of study: 4 weeks Length of followup 3,6,12,&24 months to be reported later | NR
Dini112 1998 Italy | LE onset: Onset of LE less than one year before start of study Time Rx start: 1>yr after LE Criteria to start Rx: LE defined as >10 cm difference between upper extremities Circumference recorded at 7 points LE was mild to moderate Criteria to stop Rx: occurrence of adverse event | NR | IPC: 2 cycles of 2 weeks, separated by a five week interval. Each cycle consisted of five x 2 hour sessions / week at a constant pressure. No other concomitant physical treatment | Guidelines about skin care and prophylaxis for edematous limb Not consistent with usual care | Limb circumference at 7 points Within group significant difference Between group not significantly different | Length of study: 9 weeks Length of followup: none | Withdrawals but no adverse events/harms
Hayes47 2009 Australia | LE onset: NR Time Rx start:≥6 months after BCa Rx Criteria to start Rx: Finished BCa treatment 6 months prior and have LE Criteria to stop Rx: Occurrence of adverse event | Exercise physiologist Physiotherapist No details provided about qualifications | 12 weeks of moderate intensity, aerobic and resistance exercise (supervised) 20-45 min per session (progressed) 3-4x/week (progressed) | NR | Bioimpedance Perometry No significant change between groups | Length of study: 12 weeks Length of followup: 3 months | One person had significant increase in swelling throughout study. Diagnosed with recurrent cancer 6 months after end of study
Hou105 2008 China | LE onset: NR Time Rx start: 5 years after surgery Criteria to start Rx: Diagnosis of secondary LE Criteria to stop Rx: NR | Provider qualifications not stated | Intervention group: BMSC one time operation followed by custom garment Control group: CDT (MLD, compression therapy, remedial exercises and deep breathing) details not reported | Stromal cell transplant vs. decongestive therapy BMSC not usual care | Volume (disk model), pain (self report scale) Both groups reduction in volume and pain; BMSC group had better longterm results | Length of study: NR Length of followup: 52 weeks | NR
Irdesel129 2007 Turkey | LE onset:3-60 months Time Rx start: >4 months post BCa surgery Criteria used to start: LE post BCa Criteria used to stop: NR | Researcher | Intervention group: Exercise 3x/day for six months + compression garment all day except when sleeping Control group: Exercise 3x/day for six months | Exercise and compression garments Consistent with usual care | Shoulder ROM and tenderness; VAS; limb circumference No significant difference between groups | Length of study: 6 months Length of followup: NR | NR
Jahr 120 2008 Germany | LE onset: NR Time Rx start: Rx started ~4 years and 1 month after surgery Criteria to start Rx: Diagnosis of secondary LE Criteria to stop Rx: NR | Physiotherapist | Intervention group: 2-3 x/ wk x 4 wks combined therapy + 8 weeks of MLD Control group: 1-2 sessions of 30-45 min/week of MLD | Deep Oscillation ® + MLD vs. MLD Consistent with usual care | Pain (VAS) Swelling Pain: DO + MLD decrease of 4.0 to 2.0 VAS MLD no change Swelling: DO + MLD >decrease MLD. No significant difference between groups | Length of study: 4 weeks Length of followup: 8 weeks | NR
Johansson109 1998 Sweden | LE onset: Median of 9-10.5 months Time Rx start: Median of 9-10.5 months Criteria to start Rx: Unilateral arm lymphedema Criteria to stop Rx: NR | MLD provided by physiotherapist trained in Vodder technique | Both groups wore a compression sleeve for 2 wks then the MLD group had MLD treatments (Vodder technique) lasting 45 min/day 5 day/wk for 2 wks SPC group were treated with Lympha-Press pump for 2 hrs/day, 5 days/wk for 2 wks | MLD vs. SPC Consistent with usual care | Arm volume body weight passive mobility isometric muscle strength subjective assessment MLD or SPC when applied in conjunction with a compression sleeve resulted in a notable reduction of lymphedema but no significant difference between the two treatment regimes | Length of study: 2.5 years Length of followup: NR | NR
Kaviani 118 2006 Iran | LE onset: 3 mths Time Rx start: Lymphedema ≥3 mths Criteria to start Rx: Diagnosis of unilateral arm lymphedema Criteria to stop Rx: NR | NR | Intervention group: LLLT: 5 points 3x/ wk x 3 wks; 8 wk interval, then repeat same protocol x 3 weeks Control group: Sham irradiation Assessments at weeks 3, 9, 12, 18, and 22 | LLLT vs. Sham therapy | Reduction in limb circumference: Laser >control except for week 22 Pain reduction: laser >control ROM and heaviness: NS | Length of study: 22 weeks Length of followup: None | NR
Kessler106 2003 Switzerland | LE onset: NR Time Rx start: 2nd post surgery day Criteria to start Rx: Clinically diagnosed post-operative swelling Criteria to stop Rx: NR | Physical therapist with specific training provided physiotherapy (PT) and MLD Nurse applied new bandage after each measurement session | Intervention group: Daily PT exercises (50 without resistance and 25 with slight resistance) along with 30 minute MLD while in hospital Control group: Daily PT exercises same as intervention group | PT exercises alone or with manual lymphatic drainage Consistent with usual care | Change in leg, foot volume (water displacement) Significant volume reduction intervention vs. control (6.4% vs. 0.1%, p=0.011) | Length of study: NR Length of followup: NR | NR
Kozanoglu104 2009 Turkey | LE onset: History of arm LE >3 mo Time Rx start: LE >3 mo Criteria to start Rx: LE defined as difference of ≥2 cm at least 3/7 points Criteria to stop Rx: NR | Physician performed assessments No details of who performed treatment No other details provided | IPC: 2 hrs at 60 mmHg x 20 sessions over 4 wks Laser: 20 min/3x wk x 4 wks (2800Hz, 1.5J/cm2) with a Ga-As 904nm laser device (Electronica Pagani IR27/4) 12 sessions total Both groups daily limb exercises, hygiene and skin care | Pneumatic compression and laser therapy Could be seen as usual care | Limb circumference Visual Analogue Scale Grip strength Significant difference LC and VAS from pretreatment to 12 month followup | Length of study: 4 weeks Length of followup: 12 months | Withdrawals but not mention of adverse events
Lau127 2009 China | LE onset: 22-60 months post BCa Time Rx start: Post Rx BCa Criteria to start: LE post BCa Criteria to stop: NR | NR | Intervention group: LLLT 3x/week for 4 weeks Control group: no LLLT or other Rx Both groups received education about LE | LLLT vs. no Rx Consistent with usual care | Arm volume (volumetry); tonometry tissue resistance; DASH score LLLT significant: decrease arm volume (28%); increase tonometry (33.2%); decrease DASH score | Length of study: 4 weeks Length of followup: 4 weeks (8 weeks after start study) | NR
Maiya121 2008 India | LE onset: NR Time Rx start: 3-6 weeks following mastectomy Criteria to start Rx: Lymphedema defined by 2 cm difference at 2 or more points on upper extremity Criteria to stop Rx: NR | NR | LLLT: (He-Ne Laser-632.8nm and Diode Laser 850nm) at different points in axillary region. 2.4J/cm2 of laser energy per point was given for total of 34 min/day for 10 days After laser, patients performed exercise program for upper extremity (no details given) Control Group: Upper extremity exercises and compression garments for 10 days (no other details provided) Both groups advised to continue their regular daily activity | Upper extremity exercise + compression garments Consistent with usual care | Pain Limb Circumference at 4 points Significant difference mean pain score between groups Significant difference mean circumference at 10 cm and 15 cm LE between groups | Length of study: 10 days Length of followup: NR | “All patients completed the 10 days of treatment without any adverse reactions”
McKenzie107 2003 Canada | LE onset: NR Time Rx start: >6 months post treatment for cancer Criteria to start Rx: Diagnosis of LE (arm difference between 2 cm and 8 cm) Criteria to stop Rx: NR | NR | 8 week progressive exercise program of stretching and resistance training 3x weekly; after 2 weeks, upper body aerobic exercise was added to the program | No specific exercise instruction Consistent with usual care | Arm circumference arm volume and QoL No change in circumference or volume, change in quality of life not statistically significant | Length of study: 8 weeks Length of followup: none | NR
McNeely123 2004 Canada | LE onset: NR Time Rx start: NR Criteria to start Rx: Diagnosis unilateral LE, mild, moderate or severe, both early and chronic Criteria to stop Rx: NR | MLD provided by Physical Therapist trained in the Vodder method Bandaging by physical therapist assistant | Intervention Group: 45 minutes of daily MLD 5 days/week x 4 weeks + bandaging each day Control Group: short stretch bandaging 5 days/week x 4 weeks Both groups educated on proper arm and skin care | Vodder MLD + short stretch bandaging vs. short stretch bandaging alone Consistent with usual care | Volume (volumetry) circumference significant reduction in both groups; but between groups: NS largest reduction in MLD/CB group with early, mild LE | Length of study:4 weeks Length of followup: None | 1 pt withdrew due to skin reaction, 1pt due to discomfort of bandages
Pilch125 2009 Poland | LE onset: NR Time Rx start: NR Criteria to start Rx: LE following BCa Criteria to stop Rx: NR | NR | All groups had 1 hour Rx, 5x/week for 5 weeks Group 1: single chamber, 90sec on: 90 sec off compression Group 2: 3 chamber, 90sec on: 90 sec off Group 3: single chamber, 45 sec on: 15 sec off Group 4: 3 chamber, 45 sec on: 15 sec off | Single chamber vs. multichamber IPC and timing of pressure application Consistent with usual care | Change in arm volume (volumetry) All four groups had significant decrease in LE volume No significant difference between groups | Length of study: 5 weeks Length of followup: none | NR
Radakovic103 1998 Yugoslavia | LE onset: NR Time Rx start: after radiotherapy (RT) Criteria to start Rx: BCa mastectomy patients Criteria to stop Rx: NR | NR | Intervention group: SEPC 60 min x 10 consecutive days, followed by elastic bandages Control group: 30 min of MLD x 10 days + elastic bandages | MLD vs. pneumatic compression Consistent with usual care | Change in arm volume (limb circumference) SEPC 2.24 cm (range 0.6 - 8.4 cm) MLD 0.95 cm (range 0.1 - 3.9 cm). SEPC 2.3X greater than MLD | Length of study: 10 days Length of followup: none | NR
Schmitz48 2009 U.S *companion Schmitz138 | LE onset: NR Time Rx start: 1-15 years after BCa Criteria to start Rx: unilateral BCa with nodes removed and LE Criteria to stop Rx: LE exacerbation or Ca recurrence | Certified lymphedema therapists Fitness trainers with knowledge of lymphedema | Intervention group: 13 weeks supervised weight lifting, 90 min x 2/week; then 39 weeks unsupervised weight lifting; patients wore compression garment during exercise Control group: No prescribed exercise | Weight lifting vs. no weight lifting Consistent with usual care 1 yr fitness membership | Change in arm and hand volume at one year; LE exacerbation; muscle strength No difference between groups limb swelling Exercise group had increased strength, less LE exacerbations | Length of study: 12 months Length of followup: 1 year | No serious adverse events
Shaw 116 2007 U.K. | LE onset: NR Time Rx start: Rx onset ≥12 months after CT or RT Criteria to start Rx: Diagnosis of arm LE Criteria to stop Rx: Completion of regimen | Dietary intervention provided by registered dietitian conventional therapy provided by trained LE nurses | Intervention Group: Individualized dietary advice given on weight reduction diet; dietary compliance assessed at week 4 and week 8 visits Control Group: Healthy eating booklet with no specific dietary intervention | Dietary intervention consistent with usual care | Changes in arm volume (measured manually) Significant change in lymphedema arm (7% ± 6%) vs. normal arm (3% ± 6%) in dietary group | Length of study: 12 weeks Length of followup: NR | NR
Shaw 117 2007 U.K. | LE onset: NR Time Rx start: ≥12 months after Rx for cancer Criteria to start Rx: Diagnosis of secondary LE Criteria to stop Rx: NR | Registered dietitian arm measurements taken by LE practitioners | Intervention group: Group 1: Weight reduction (reduced energy intake) Group 2: Low fat diet (no reduction in energy intake) Control group: No dietary change | 2 dietary interventions vs. no diet intervention | Change in arm volume (Perometer) circumference (measured manually) Significant reduction body weight, BMI and skinfold thickness. NS change arm volume. Significant correlation weight loss and decreased arm volume | Length of study: 24 weeks Length of followup: none | NR
Sitzia 122 2002 U.K. | LE onset: NR Time Rx start: NR Criteria to start Rx: Secondary arm LE after BCa surgery Criteria to stop Rx: NR | Lymphedema specialist Nurse (LS) MLD training (2 year diploma) in specialist management of chronic edema | Intervention Group: MLD: 40 - 80 minutes 5 x week x 2 weeks Control Group: SLD: 20 minutes 5x week x2 weeks | MLD vs. SLD Consistent with usual care | Change in excess limb volume (PCEV) MLD: 33.8%, SLD: 22.0% (mean difference 11.8%) | Length of study: 2 weeks Length of followup: NR | NR
Szuba111 2002 U.S. | Study 2: LE onset: NR Time Rx start: between 1 month and 1 yr post intensive decongestive lymphatic therapy (DLT) Criteria to start Rx: diagnosis of secondary LE Criteria to stop Rx: NR | MLD performed according to Vodder School technique (no details on Rx providers) | Study 2 (2 month-groups switched treatment after 1 month): Group 1: daily self-administered MLD and use of Class II compression garment Group 2: same + 1 hr daily IPC (40-50 mm Hg) | Study 2: DLT alone (regular care) | Study 2: arm volume, skin elasticity (tissue tonometry) joint range of motion (goniometry) IPC was effective as adjunct therapy; there was no impact on skin elasticity or joint ROM | Length of study: 2 months Length of followup: 6 months | Study 2: No adverse responses
Szuba108 2002 U.S. | Study 1: LE onset: NR Time Rx start: ≥3 months from BCa Rx Criteria to start Rx: Diagnosis of secondary LE Criteria to stop Rx: NR | MLD performed according to Vodder School technique (no details on Rx providers) | Study 1 (10 days): Intervention group-daily MLD followed by IPC (30 min at 40-50 mm Hg) then compression bandaging Control group-daily MLD followed by compression bandaging After completion of intervention both groups were fitted with Class II compression garment and instructed in self-applied MLD to be done daily at home | Study 1: DLT alone Consistent with usual care | Study 1: arm volume, skin elasticity (tissue tonometry) joint range of motion (using goniometry) IPC was effective as adjunct therapy; there was no impact on skin elasticity or joint ROM | Length of study: 10 days Length of followup: 30 days | Study 1: one participant reported repetitive headache and modest increase in blood pressure during IPC therapy
Tsai128 2009 China | LE onset: 3+ months post BCa treatment Time Rx start: after 4 weeks control period Criteria to start: LE moderate-severe Criteria to stop: NR | Physical therapists | Both groups received treatment 2h/day, 5x/week for 4 weeks: education on skin care; 30 min MLD, IPC x 1hour at 40mmHg, 20 min exercise and bandaging Intervention group: bandaging was done with kinesiotape Control group: bandaging with short stretch bandages | Kinesiotape and short stretch bandages Consistent with usual care | Limb volume (volumetry) and arm circumference; water content of limb; EORTC questionnaire; time bandages worn daily No significant difference in arm volume or circumference between two groups; kinesiotape better accepted and longer wear time | Length of study: 8 weeks Length of followup: 3 months | NR
Wilburn 113 2006 U.S. | LE onset: 34 ± 34 months Time Rx start: 0-5 months after LE onset Criteria to start Rx: Lymphedema of the upper extremity after surgical and/or radiotherapy Criteria to stop Rx: NR | Physiotherapist self-massage or patient self-administered | Intervention group: Use of Flexitouch machine for 1 hour daily Control group: Self-message for 1 hr daily, then compression garment Each treatment phase lasted 14 days at home with one week washout period between treatments | Self-message and compression garment Consistent with usual care | Limb volume measurements Flexitouch™ mean -208 ± 157 ml; Control: + 52 ± 106 ml p=0.007 HRQOL with SF-36: NS | Length of study: 42 days Length of followup: NR | NR
Williams114 2002 U.K. | LE onset: LE >3 mths Time Rx start: LE >3 mths Criteria to start Rx: Diagnosis of secondary LE Criteria to stop Rx: NR | Therapists qualified in Vodder method of MLD SLD performed by participants (self) after training | Group A: 3 wks (5x wk) daily 45 min MLD treatment followed by 6 wks no treatment followed by 3 wks daily 20 min SLD treatment Group B: 3 wks daily 20 min SLD treatment followed by 6 wks no treatment followed by 3 wks (5x wk) daily 45 min MLD treatment | Both groups same treatment but in reverse order; SLD was comparator treatment Usual Care | Limb volume, caliper creep, dermal thickness, QoL, altered symptoms/sensations MLD reduced volume, dermal thickness, improved some QoL measures and some symptoms/sensations | Length of study: 12 weeks Length of followup: NR | NR
Observational Studies
Balzarini50 1993 Italy | LE onset: Intervention group- 3-52 months Control group- 5-57 months Time Rx start: NR Criteria to start Rx: Diagnosis of secondary LE Criteria to stop Rx: NR | NR | Intervention: 2 UST cycles at 4 month intervals--one cycle=10-30 min sessions Control: MPT, 1 cycle (6 hrs/day for 5 consecutive days) at 4 mo intervals for 1 year *subsets of each group were also given an elastic sleeve to wear | Pneumatic compression Usual care | Arm volume Skin firmness The UST group had greater softening of the arm, better relief of pain, greater scapulo-humeral motion | Length of study: 12 months Length of followup: up to one year | NR
Berlin130 1999 Sweden | LE onset: NR Time Rx start: NR Criteria to start Rx: Diagnosis of secondary LE Criteria to stop Rx: NR | NR | Group 1: Arm compression stockings only for minimum of 4 wks compression used varied between 25 and 50 mmHg Group 2: Intermittent compression with Flowtron used at least 20 min/day minimum 4 wks Group 3: Pneumatic compression with Lympha Press--pressure 90-120 mmHg for 20-30 min 2x/day 5 day/wk Patients also received compression stockings | 1)compression with sleeves 2)intermittent compression with Flowtron 3)intermittent compression Lympha-Press + compression sleeves Not consistent with usual care | Group 1: Arm compression stockings only for minimum of 4 wks. Compression used varied between 25 and 50 mmHg Group 2: Intermittent compression with Flowtron used at least 20 min/day minimum 4wk Group 3: Pneumatic compression with Lympha Press-pressure 90-120 mmHg for 20-30 min 2x/day 5 day/wk Patients also received compression stockings | Length of study: 5 years Length of followup: NR | NR
Brambilla132 2006 Italy | LE onset: NR Time Rx start: NR Criteria to start Rx: Grade II lymphedema Criteria to stop Rx: NR | NR | Intervention Group: Compression stocking from morning until bedtime, stockings were replaced every 6 months Control Group: No treatment physical exams | No treatment Not consistent with usual care | Change in limb volume Intervention Group: 30/50 reduction 6.9% ± 5.1 20/50 increase: 6.7% ± 6.2 Control group: 15/15 increase 5.82% ± 2.16 | Length of study: Intervention group: Mean 66 weeks Control group: Mean 64 weeks Length of followup: Mean 5-6 months | NR
Frischenschlager134 1991 Austria | LE onset: ~5years post BCa Rx Time Rx start: NR Criteria to start Rx: Diagnosis of LE Criteria to stop Rx: NR | Physiotherapist | Psychosocial group: MLD 3x/day for 10 weeks + compression stockings during day, psychosocial and exercise 2 hr/week for 10 weeks Control group: MLD 3x/day for 10 weeks + compression stockings during day and exercise | No active treatment | Score on ‘scale of well being’ and ‘list of complaints’ Significant improvement of well being in psychosocial group from baseline and compared to control group | Length of study: 10 weeks Length of followup: 10 weeks | NR
Johansson133 1999 Sweden | LE onset: NR Time Rx start: NR Criteria to start Rx: Diagnosis of secondary unilateral LE Criteria to stop Rx: Therapy stopped with resolution of arm swelling | Physiotherapist trained in bandaging and in the Vodder MLD technique | Part 1: Both groups received 2 weeks of CB (bandage changed every 2nd day) Part 2: During the 3rd week both groups continued CB but one group also received MLD 45 min/day x 5 days | CB alone vs. CB + MLD Consistent with usual care | Arm volume body weight subjective assessment CB + MLD group had significant difference % volume reduction | Length of study: 19 days Length of followup: NR | NR
Pinell131 2007 U.S. | LE onset: NR Time Rx start: NR Criteria to start Rx: Secondary LE with or without axillary or inguinal disease Criteria to stop Rx: NR | Certified therapist | Intervention group: Skin and nail care, multilayer compression bandages worn at all times and decongestive exercise, MLD 60 - 90 minute/day. Modified MLD technique for patients with axillary or inguinal disease at time of therapy Control group: Same as intervention group without modification | Manipulative therapy (MLD) plus compression bandages Consistent with usual care | Interval measurements of girth along affected limb and computation of volume | Length of study: 39 months Length of followup: NR | NR

Abbreviations: AROM=Active Range of Motion; BCa=Breast Cancer; BMI=Body Mass Index; BMSC=Bone Marrow Stomal Cell Transplantation; CB=Low stretch compression bandaging; CDP=Complex Decongestive Physiotherapy; CDT=Complex Decongestive Therapy; DASH=Disability of Arm Shoulder and Hand; DLT=Decongestive Lymphatic Therapy DO®=Deep Oscillation; ESLD=Electronically Stimulated Lymphatic Drainage; HRQOL=health related quality of life; KS Karposi’s Sarcoma; LC=Limb Circumference; LE=Lymphedema; LLLT=Low-level Laser Therapy; LS=Lymphedema Specialist Nurse; MLD=Manual Lymph Drainage; MPT=mechanical pressure therapy; NR=Not Reported; NS=No Significance; PC=Pneumatic Compression; PCEV=Percentage Change in Excess limb Volume; PML=Post Mastectomy Lymphedema; PT=physical therapist; pts=patients; RT=Radiation Therapy; QoL=Quality of Life; RCT=Randomized Control Trial; ROM=Range of Motion; Rx=Treatment; SEPC=Sequential External Pneumatic Compression; SF-36=short form 36; SLD=Simple Lymphatic Drainage; SP=Standard Physiotherapy; SPC=Sequential Pneumatic Compression; UST=Ultrasound therapy; VAS=visual analogue scale; wk=week; wks=weeks

A single study reported that treatment was initiated for hospitalized patients only because a precondition of study entry was the failure of previous outpatient treatment for lymphedema.124

Only five studies contained criteria to stop therapy. Four of these studies were RCTs that scored in the 4 to 8 range on the Jadad scale. Two RCTs specified stoppage in the event of adverse effects.47,112 Other stopping rules included a change of 25 percent change or more in the circumference of the lymphedema-affected arm versus the contralateral arm110 or completion of the therapeutic regimen.116 A single observational study contained criteria to stop therapy. Patients were not included in the second phase of treatment if there was less than a 10 percent volume difference between their abnormal and normal arm.133

The RCTs with Jadad scores between 0 and 3, as well as the six observational studies, did not exhibit characteristics that were vastly different from what was described above for the 18 RCTs with Jadad scores greater than 3. The exceptions were two RCTs in the Jadad 0 to 3 range that reported ‘extreme’ recruitment times of 2 days after surgery106 or 5 years after surgery.105

Question 4. Who provided the treatments in the studies? What information was provided on their professional training or certification in lymphedema care?

Fifteen out of the 23 RCTs with a Jadad score between 4 and 8 reported the profession of the person who provided the lymphedema treatment. Some trials contained more than one type of professional.47,48,113,116,117,123 The authors of nine trials reported that a physiotherapist provided treatment.47,109,113-115,119,120,123,128 For four of these RCTs, the trial publication indicated that the physiotherapists had been trained in the Vodder technique for the provision of MLD.109,114,115,123 In two other RCTs, the authors wrote that the person who delivered the treatment was trained in the Vodder technique, but they did not mention whether the person was a physiotherapist.108,111 Other professionals included dietitians,116,117 “lymphedema practitioner”,117 “trained staff”,124 physiotherapist’s assistant,123 nurse,116,122 certified lymphedema therapists and exercise trainers who took a 3 day course on lymphedema,48 researcher,129 and an exercise physiologist.47 Two RCTs contained reports of patients self-administering treatment113,114 and nine RCTs did not report the type of professional who administered lymphedema treatment.33,108,110-112,118,121,127,129 In the two trials involving nurses, one nurse was described as holding a 2 year diploma in the management of chronic edema122 and the other nurse was described as being ‘trained in lymphedema’ management.116 The dietitian in one study was described as “certified”.116

Six of the RCTs with Jadad scores between 0 and 3 did not describe the professional providing lymphedema treatment. The lone exception indicated that the professional was a physiotherapist trained in MLD.106 Three of the six observational studies reported the type of professional: ‘certified therapist',131 a physiotherapist trained in the Vodder technique,133 and a physiotherapist with no mention of additional training.134 Details are described in Table 11.

Question 5a. Was one type of pneumatic compression device and sleeve (e.g., non-segmented compression device, sequential segmented compression, or segmented compression with calibrated gradient pressure) more effective in reducing lymphedema than another for any type of lymphedema along the continuum, or patient characteristic (e.g., demographics, comorbidities)?

There were 12 extracted studies that focused on treatment for lymphedema using an IPC device (Table 12). Seven studies were RCTs with Jadad scores between 4 and 8,^108-113,128^ three studies were trials with Jadad scores between 0 and 3,^103,104,125^ and two studies were observational.50,130 There were nine different types of IPC devices used in these studies: Sequential Circulator 2004, a four-chamber pneumatic sleeve and gradient sequential pneumatic pump operated at 40 to 50 mmHg for 30 minutes per day over 10 days108 or 60 minutes per day over 30 days;111 Flexitouch, a home use device consisting of a programmable, pneumatic controller unit, garments capable of fitting an arm or leg, and 26 to 32 independent chambers that inflate and deflate sequentially, used for 1 hour daily over 14 days;113 Lympha-Press, a pump employing nine compression cells, was operated at 40 to 60 mmHG for 2 hours per day over 2 weeks109 or at 90 to 120 mmHg twice daily for 20 to 30 minutes over an unspecified followup period;130 IPC devices described only as ICH8 electrodes and sleeve (eight electrodes with an impulse frequency of 4.5 KHz), applied in two cycles of 2 weeks, divided by a five-week break (each cycle consisted of 10, 30 minute sessions);110 a sequential external pneumatic compression sleeve with twelve overlapping compression chambers (60 to 65 mbars) applied for 60 minutes daily over 10 days;103 a Jobst Extremity Pump used for 6 hours daily for 5 days at 4 month intervals over 1 year;50 Flowtron intermittent compression at 80mmHg applied for 20 minutes daily for a minimum of 4 weeks;130 or Flowtron Plus (model AC 200/2) and Flowtron Flowpac Plus (model FP 2000).125 The specific IPC device was not named in three trials,104,112 although the authors of these RCTs described the degree of treatment (i.e., two cycles, with each cycle being five 2 hour sessions at 60mmHg separated by 5 weeks;112 20 sessions over 4 weeks, with each session consisting of 2 hours of intermittent pressure at 60mmHg;104 20 sessions over 4 weeks, with each session containing 1 hour of pressure at 40mmHg128). The authors of one104 of these two studies named the device manufacturer, but not the device itself.

Table 12 IPC treatment

Study | Question #5a | | Question #5b | | Question #5c
Study | Type of IPC Device | Pumping Time/Cycles and Pressures | Co-morbidities of Patients | Modification of Protocol for Co-morbidities | Timing of IPC Application
RCT’s
Bertelli110 1991 Italy | Electronically Stimulated Lymphatic Drainage (ICH8 Linfomed Fisioline) | Pump Time: 10x 30 min sessions Cycle: 2 cycles of 2 weeks separated by 5 weeks Pressure: 4.5khz frequency sequential stimulation of 8 electrodes | NR | NR | NR
Dini112 1998 Italy | NR | Pump Time: 2 hrs x 5 days/week Cycle: 2 cycles of 2 weeks separated by 5 weeks Pressure: 60 mmHg (constant pressure) | NR | NR | 1 year of LE onset
Johansson109 1998 Sweden | Lympha-Press Type: 9 Compression Cells | Pump Time: 2 hrs/day Cycle: 5 day/week x 2 weeks Pressure: 40-60 mmHg | NR | NR | LE duration 6.5 months (2.3-68.3)
Kozanoglu104 2009 Turkey | IPC device (MJS Healthcare Ltd. U.K.) | Pump Time: 2 hours IPC Cycle: 20 sessions x 4 weeks Pressure: 60 mmHg (intermittent pressure) | NR | NR | Arm LE at least 3 months
Pilch125 2009 Poland | Flowtron Plus Flowtron Flowpac Plus | Flowtron Plus/Flowtron Flowpac Plus Pump Time: 1 hour x 5 days week for 5 weeks Cycle: 1 cycle over 5 weeks Pressure: 30-50 mmHg (single chamber or multi chamber) Flowtron Plus 90sec on, 90 sec off Flowtron Flowpac Plus 45 sec: 15 sec | NR | NR | NR
Radakovic103 1998 Yugoslavia | Sleeve with 12 overlapping compression chambers | Pump Time: 60 min/day Cycle: 1/day x 10 days Pressure: 60 - 65 mbar (gradually activated over 7 min) | NR | NR | NR
Szuba111 2002 U.S. | Sequential Circulator 2004: (BioCompression Systems Inc) | Pump Time: 60 min/day Cycle: 1 month Pressure: 40-50 mmHg (4 chamber, sequential) | NR | NR | Average duration LE 5 yrs
Szuba108 2002 U.S. | Sequential Circulator 2004: (BioCompression Systems Inc) | Pump Time: 30 min/day Cycle: Daily: 10 days Pressure: 40-50 mmHg (4 chamber, sequential) | NR | NR | 12 weeks following cancer treatment
Wilburn 113 2006 U.S. | Flexitouch™ Type: Lightweight portable device for home use consisting of up to 32 separate chambers | Pump Time: 1 hour/day Cycle: 1/day x 14 days Pressure: 1-3 seconds of mild pressure | NR | NR | 5 years of LE onset
Observational Studies
Balzarini50 1993 Italy | Jobst Extremity Pump | Pump Time: 6 hrs/day for 5 consecutive days Cycle: 1 cycle every 4 months over 1 yr Pressure: 30-40 mmHg (uniform pneumatic sleeve) | NR | NR | NR
Berlin130 1999 Sweden | 1) Flowtron 2) Lympha Press | Pump Time: Flowtron: 20 min/day Lympha Press: 20-30 min/day Cycle: Flowtron: 1x/day x4 weeks Lympha Press: 2x/day x unspecified weeks Pressure: Flowtron: 80 mmHg, inflate/deflate x 2 min Lympha Press: 90-120 mmHg, build 20 sec, hold 6 sec, release 4 sec | NR | Lower levels of pressure were permitted in some patients treated with compression stockings | NR

Abbreviations: BMI=Body Mass Index, Ca=Cancer ESD=Electronically Stimulated Lymphatic Drainage, Hrs=Hours, IPC=Intermittent Pneumatic Compression, LE=Lymphedema, min=minutes, NR=Not Reported, RCT=Randomized Control Trials, yrs=years

IPC was statistically significantly better than comparator treatments (usually MLD or compression garments alone) in four studies,103,108,111,113 worse in one study (comparator was laser treatment),104 and no different in five studies.50,109,110,112,130 In one study, subjects were randomized to one-to-one or three-to-one compression cycles, as well as to single-chamber or three-chamber sleeves, with no statistically significant differences found between groups when looking at the absolute extent of edema reduction.125 The typical measure of efficacy was a change in arm volume or circumference.

None of the studies contained breakdowns of treatment efficacy by patient characteristics.

Question 5b. Did the studies of IPC for lymphedema in patients with comorbidities such as wounds, arterial and/or venous insufficiency, diabetes, congestive heart failure, infection, etc., report the need to modify their treatment protocols? Did it affect treatment outcome?

The need to modify protocols was not discussed by the authors of 10 of the 12 studies that included IPC therapy50,103,104,108-113,128 (see Table 12). In one RCT, compression pressure was established for each patient based on the consistency of the edema: lower compression pressures for solid edema and higher pressures for soft edema. Pressures were always kept lower than diastolic blood pressure and ranged from 30 to 50mmHg.125 The authors of one observational study wrote that lower levels of pressure were permitted in some patients treated with compression stockings, but they did not report the number of patients affected by the reductions, the mean decrease in pressure, nor how the reductions may have affected the comparisons with IPC.130 The authors of the observational study indicated that the potential for pressure decreases was offered to participants as a means of increasing compliance, thereby suggesting a protocol modification. However, there was no discussion in either the RCT or the observational study of whether the compliance issue was related to comorbidity.

Question 5c. Did the timing of IPC application and/or the sequence of use of the various IPC device types (either alone or in combination with other therapies) influence outcomes either positively or negatively?

Six of the 12 studies involving IPC contained reports of the timing of the treatment.104,108,109,111-113 IPC applied within 1 year of onset of lymphedema was not statistically significantly different from skin care and prophylaxis (cleaning wounds, gloves during gardening, avoidance of weight gain and venipuncture, prolonged sun exposure and carrying heavy weights),112 but it was better as a supplement to MLD and compression garment when applied an average of 60 mths (3-480 mths) after lymphedema onset111 (see Table 12). In two studies, IPC was applied within 5 years following lymphedema onset, showing better results versus massage as an adjunct to compression garment and showing no difference versus MLD.109,113 One study had IPC applied at least 12 weeks following cancer treatment and results were better when IPC was added to MLD and compression bandaging versus MLD and bandaging alone.108When IPC was applied to patients who had arm lymphedema for at least 3 months, it performed statistically significantly worse than laser.104

Six studies did not report the precise timing of IPC application, with IPC performing statistically significantly better than massage (followed by elastic bandage),103 no difference versus ultrasound,50 no different when added to an elastic sleeve versus the sleeve alone,110 no different when added to compression stockings versus the stockings alone,130 and no different based on compression cycles or single versus triple sleeves, except for a relative edema reduction in the comparison of three-to-one compression cycles using single versus three-chamber sleeves (p = 0.04).125 In the sixth study, IPC was given to both treatment groups as part of a multimodal therapy.128

Two RCTs were crossover designs and in neither instance did the sequence of treatment affect the results, whether for IPC versus massage as adjuncts for compression garment113 or IPC added to MLD and compression garment versus MLD and compression garment alone.111 When IPC was evaluated as part of combination therapy (MLD, massage, or compression garment prior, concurrently, or afterward), it was better than the comparator in two instances103,108 and no different in four instances.50,109,110,130 When IPC was not part of combination therapy, it was worse than the comparator (laser) in one case104 and no different from skin care and prophylaxis in another case.

In one study, IPC was part of a multimodal therapeutic regimen where the active treatment involved different compression bandages.128 Since both groups received IPC, there was no means to assess the independent impact of IPC in this study.

Question 6. What protocols for single modality treatments resulted in the best outcomes of lymphedema therapy? Consider parameters such as usage schedules and characteristics of treatment such as intensity, duration, frequency and setting (self-administered at home versus professionally administered applied in a medical clinic), and if applicable pumping times/cycles and pressures.

There were 12 studies that contained comparisons of single modality treatments: two involved dietary interventions,116,117 three involved laser,33,118,127 three concerned IPC,104,112,124 (one of which was a comparison with laser104) two concerned exercise,47,48 another involved custom-made elastic stockings,132 and the final study examined kinesiology taping.126 Nine were RCTs with Jadad scores between 4 and 8, two were RCTs with a Jadad score between 0 and 3,^104,126^ and one was an observational study.132 See Table 1 for a summary of results.

The two dietary trials were conducted by the same group of researchers. In the first trial, patients were randomized to receive individual dietary advice for weight reduction or a booklet on healthy eating.116 This RCT consisted of 21 patients and followup was for 12 weeks. At week 12, excess arm volume was lower in the group receiving dietary advice (p = 0.003). In the second diet trial (n = 51), three groups were followed for a period of 24 weeks.117 Interventions were dietary advice on weight reduction, diet to reduce fat intake to 20 percent of total energy intake, and a control group told to continue with their habitual diet. Percent excess arm volume decreased in all three groups over the course of followup, but there were no statistically significant differences between groups.

Two laser studies used identical protocols for delivery of laser treatment.33,118 Three treatment sessions were scheduled per week for a period of 3 weeks. Afterward, there was an 8 week interval before the laser was re-administered using the same 3 week schedule. A total of 1.5 Joules/cm^2^ were delivered during each treatment session. Comparators were sham laser treatment using the same schedule118 or sham treatment during the first 3 week period and actual laser treatment during the second 3 week period.33 Followup periods (and sample size) were 22 weeks (n = 8)118 or 30 weeks (n = 53).33 In the study with an entirely sham group,118 decreases in limb circumference were observed in both groups over the course of the trial, but the differences between groups were not statistically significant. In the trial with a partial sham group, the percentage of patients with statistically significant decreases in limb volume of at least 200 mL was higher in the group that received laser therapy at both treatment sessions.

In the third laser study, the active treatment group received scanning laser 3 times weekly for 4 weeks using a dose of 2.0 Joules/cm^2^ over an area of 144 cm^2^.127 The control group did not receive any treatment. The difference in arm volume between groups, favoring the active treatment group, was 12.6 mL (p = 0.04).

One RCT (n = 47) compared laser to IPC over 12 weeks of followup.104 Laser was delivered in three sessions per week for 4 weeks with a total of 1.5 Joules/cm^2^ per session; IPC was given in five sessions per week for 4 weeks at 60mmHg per session. The change in arm circumference between affected and unaffected limbs was greater for laser than IPC over 12 weeks of followup (p = 0.02), but there were no differences on pain or grip strength measures.

A single RCT compared IPC to providing patients with guidelines on skin care for the affected limb.112 IPC was delivered in two cycles lasting 2 weeks each, with a 5-week separation between the cycles. Each cycle consisted of five sessions per week at 60mmHg. Eighty patients were followed over 9 weeks, and no differences were shown in arm circumference between the groups.

The first exercise trial lasted 12 weeks and involved 32 persons.47 Randomization was to a group that received 20 supervised, aerobic or resistance exercise sessions or to a group that was instructed to continue with habitual activities. No differences in reduction of lymphedema were found between the groups. The second exercise trial involved a semi-supervised weight-lifting program versus a fitness center membership with partial supervision. After 1 year, there were no statistically significant differences between groups in terms of the proportions of women with at least a 5% change in limb swelling.48 The weight-lifting group reported reduced severity of lymphedema symptoms, improved upper- and lower-body strength, and fewer incidences of exacerbations of lymphedema.

An observational study examined the use of below-knee, custom-made stockings versus no treatment for lymphedema in a study of 65 persons that lasted for a mean of 5 to 6 months.132 Differences in limb volume were highly significant between the groups and favored the stockings.

An RCT examining high (44 to 50mmHg) versus low (20 to 30mmHg) pressure bandages found statistically significant within group edema reductions after 24 hours, but no statistically significant between group differences.124

A trial comparing kinesiology taping versus MLD in persons who received limb-lengthening surgery reported that the taping was statistically significantly better than MLD.126 However, the authors did not provide quantitative intergroup results (just intragroups results).

Question 7: Were there any treatments, combinations of treatment methods, or sequence of treatments shown to be more effective or ineffective for any type of lymphedema along the continuum, or patient characteristics (e.g., demographics, comorbidities)? Of particular interest: Is there evidence that the use of compression sleeves or low stretch bandaging is effective in maintaining reductions in lymphedema achieved through the use of other modalities (e.g., IPC, manual lymphatic drainage, exercise)?

There were 27 articles that addressed this question. Pneumatic compression was used as a study treatment in nine randomized trials. Six of those trials received a Jadad score of 4-8.^108-113^ Three trials received a lower score.103,104,125 Of the nine trials, IPC was shown superior to some form of massage-based treatment in three,103,108,113 inferior to laser in one,104 and equivalent to MLD with or without bandaging,109,111 elastic sleeve,110 and skin care.112

In one IPC study, a three-chamber sleeve was more efficacious than a single-chamber sleeve, using a three-to-one compression cycle, in reducing the relative extent of edema in women who had breast cancer.125

The addition of massage to more conservative treatments such as bandaging,119,123 simpler forms of massage,114,122 elastic sleeve,115 or physiotherapy alone,106 was tested in six trials. All but one of these studies achieved a Jadad score of 4-8.^106^ These studies typically included skin care and exercise as treatment in both groups. In all cases but one, study subjects had arm lymphedema following treatment for breast cancer. In a single trial, massage was tested in patients following hindfoot (ankle) surgery.106

In those studies of arm lymphedema in breast cancer patients, only one suggested that massage provides improvements in arm volume reduction over more conservative therapy (56% vs. 36%).119 In the single study examining patients following ankle surgery, a benefit of massage was also reported.106

One study noted a significant improvement in volume loss when dietary changes occurred with sleeve use versus sleeve alone,116 while another using dietary changes alone, with neither group using sleeves, did not.117 Less commonly studied treatments including exercise did not provide any additional benefit.47,107

Despite differences occasionally being reported in volume estimates, trials did not typically find differences in outcomes that would more likely effect patient quality of life such as shoulder range of motion,33,109,118 and quality of life scores.107,113

Regarding maintenance of volume reduction following initial treatment, only two studies specifically addressed this issue.111,129 The authors of one study found that patients who continued with IPC in addition to CDT after initial therapy for volume reduction had a significant further reduction of 90 ml (p<0.05) by study end, whereas patients receiving CDT alone did not. While the CDT group regained another 33 ml, it is not reported to what degree those patients maintained their initial volume loss. Unfortunately, the authors did not report between group statistical comparisons, leaving readers unsure of the value of additional pneumatic compression for maintenance. In the second study, two groups of patients were assigned to an exercise program, with one group asked to wear a bandage (40mmHg) at all times except during sleep.129 After 6 months, there were no differences in arm circumference between the two groups.

In one study, participants were randomized to a weight-lifting versus exercise program.48 Both groups were asked to wear a custom-fitted compression garment. The independent effect of this garment could not be ascertained since both groups wore it.

In a study of kinesiology tape versus short-stretch bandage, all subjects received skin care, MLD, IPC, and physical therapy.128 The impact of these additional treatments could not be evaluated since they were given to both groups.

The authors of an observational study compared two groups at different hospitals. Both groups received MLD 3 times weekly and a support stocking worn from morning to evening. The group at one hospital also received 2 hours weekly of vaguely described information sessions and therapeutic exercises. After 10 weeks of followup, the group receiving the additional interventions showed better ‘psychic wellbeing’ than the comparison group (p = 0.02). However, there was no difference between groups regarding the number of physical complaints related to impairment (p = 0.12). We could not assess the effect of MLD or stocking on maintenance of treatment benefit since the study was not designed to investigate this question.

Indirect support for the value of continued therapy for the maintenance of lymphedema volume reduction comes from the observation that four remaining studies, which reported long-term reductions in lymphedema volume of at least 24 weeks, were those, which reported the use of maintenance therapy. In all four studies, therapy was elastic sleeve.50,105,110,115 No studies demonstrated long term volume reduction without the use of maintenance therapy. None of these studies was designed to examine the role of sleeve or bandaging in maintaining benefits of the initial treatment. No trials were identified which compared sleeve or bandage to no treatment in the volume reduction phase of a study.

Question 8: What comparators were used in the studies? Are these comparators consistent with usual care for lymphedema?

In five non-randomized studies, which included a comparator group, all five used different treatments as their comparator. These comparator treatments were pneumatic compression, bandaging, elastic compression garment, stocking and MLD, or no active treatment.50,130,132-134

Several RCTs did not clearly identify the treatments that were considered experimental or control. For purposes of this report, it was assumed that the more conservative therapy was the comparator.

There appeared to be little difference between the comparators chosen for higher or lower quality RCTs. The most common comparator used in nine randomized trials was a group of strategies loosely defined as either “usual care”, sham treatment or no treatment.33,47,107,112,116-118,121,130 The most commonly reported active therapies used as a comparator were some form of decongestive therapy,105,108,111 or elastic sleeve.110,115,130 Less commonly used study comparators were self-massage,113 bandaging alone,123,124 therapies reported as “simple lymphatic drainage”.114,122 Comparators used in some trials included IPC,104 manual lymphatic drainage,120,126 and physiotherapy.106 In two randomized trials involving sequential pneumatic compression vs. MLD103,109 it was difficult to interpret which of the two treatments was intended as experimental and which was the control. In one RCT, the comparator was a 1-year fitness membership with partially supervised instruction.48 See Table 11 for details.

Question 9: What outcomes were measured in studies of lymphedema therapy? How effective were these treatment methods in reducing lymphedema?

A multiplicity of outcomes was used to detect benefit in the trials. The vast majority included some form of measurement related to volume of the affected area, although a few simply recorded changes in limb circumferences without reporting volumes.103,104,110,112,118,121 Other outcomes included subjective symptoms such as pain, heaviness or tension,104,105,109,118,120,121,133 range of motion in joints (usually shoulder),33,108,109,115,118,120,129 grip strength,104,109 measurements of intra- and extra-cellular fluid levels through bioimpedance,33,47 skin-fold thickness,116,117 and skin tonicity using tonometry.33,108,111 Finally, several studies attempted to correlate results of lymphedema treatment with changes in quality of life.107,113

The six observational studies examined a mixed group of patients and treatments. One study reported on the use of ultrasound and pneumatic pressure therapy in breast cancer patients. For reasons that are not clear only 96 of 150 study patients contributed data to the final analysis. The authors found that both groups experienced a reduction in arm circumference over baseline values, but that there was no difference between the two treatment groups.50 Another study of breast cancer patients included some patients with active disease. The reduction in lymphedema volume was 22 percent regardless of disease status but p values were not reported.131 A study in breast cancer patients looked at the value of adding group talks and exercise sessions to a regimen including MLD and compression stocking. Outcomes in this study were measured using ‘psychic well-being’ and ‘physical complaints’ scales, with better psychic well-being shown in the talk/exercise group versus the comparator group (p<0.05). No between-group difference was observed on the physical complaints scale.134 A study of patients with active malignancy included patients with Kaposi’s sarcoma. There was a significant improvement in patients wearing a daily compression stocking versus those who did not (p<0.001) but the size of the benefit was not reported.132 A study of compression bandaging with or without MLD reported a significant percent reduction in lymphedema (p = 0.04) but this significance became borderline when reported as absolute volume (p = 0.07). Both groups experienced a significant reduction in heaviness and tension but only the group receiving MLD experienced less pain (p<0.03). No comparisons were made between groups for these outcomes.133 A further observational study compared sleeve to IPC. The authors found no significant differences in volume reduction between groups and no point estimates were given.130

Of six higher quality trials involving pneumatic compression-based therapies, only two showed benefit over the comparator group, in this case, some form of decongestive therapy. In one, initial volume loss as measured by water displacement was greater in the group receiving pneumatic compression (45%) than in controls (26%).108 In the same report, these authors also tested the same treatments for maintenance of volume reduction. While their report suggested a superiority for pneumatic compression, they did not perform a statistical comparison between groups.111 Another report comparing pneumatic compression to self-massage in a randomized crossover study showed that patients lost 208 ml of fluid in the involved arm after 2 weeks of treatment with pneumatic compression, but gained 52 ml after self-massage (p = 0.003).113

Three additional studies failed to show superiority of pneumatic compression over more conservative measures such as lymphatic massage,109 skin care,112 or elastic sleeve.110 One study showed that a three chamber IPC sleeve was better able than a one chamber sleeve to reduce the relative extent of edema, using a three to one compression cycle.125 However, all other comparisons, including one to one compression cycles involving one or three chambers, did not reach statistical significance at the 5% level.

In11 trials of non-pneumatic compression treatments, differences between groups by the end of the study were reported in four.33,119,121,127 Six studies used some form of massage-based therapy as the study treatment. Of these, only one suggested additional benefit in the massage group.119 In this study, all patients received compression bandaging with the experimental group randomized to receive lymphatic massage three times per week for 4 weeks. Following treatment, there was a greater volume loss in the group receiving massage (56%) compared to those who did not (36%, p<0.05). Both groups increased shoulder mobility, with no difference between groups.

Other studies of arm massage generally found significant volume loss in both study groups but no difference between groups, using bandaging alone,123 elastic sleeve,115 or a less intensive version of massage as comparators.114,122 In these studies, the more intensive treatment trended towards improved benefit with lacking statistical significance, in one case being very close with an additional benefit of 39 ml (p = 0.0053).114

Four studies of laser-based treatment were extracted for this report. Authors showed superiority of laser over exercise,121 sham laser,33 and no treatment.127 The fourth study used sham laser as the control and found a difference favoring actual laser at some intermediate time points, but the authors provided no quantitative statistical comparisons.118

Results on the use of diet were conflicting. One study showed no improvement with either a low fat or low caloric diet,117 while another showed a dramatic improvement in volume loss (349 ml vs. 11 ml), when dietary advice was given in addition to elastic sleeve.117 Neither of these studies reported a significant difference in skin fold thickness between groups.

Therapy with a Deep Oscillation machine in addition to MLD was found to provide initial benefit to women who experienced swelling of the breast following surgery but this was not apparent at study end. Shoulder mobility was improved in the control group. This was the only study of breast, as opposed to arm, lymphedema in women with breast cancer.120

Lower quality trials were more likely to suggest benefit in the study group. Two involving pneumatic compression reported significantly more reduction in arm circumferences when compared to MLD,103 but less than seen following laser.104 A study of bone marrow stromal cell (BMSC) transplantation versus decongestive therapy reported greater reductions in excess arm volumes with transplant (81% vs. 55%; p<0.001) by study end. Both groups experienced a reduction in pain. The hypothesis for the transplant study was that BMSCs would promote the regeneration and reconstitution of lymphatic vessels.105 A study of adding exercise as a method of reducing arm volumes did not suggest any improvement.107 A further study examined the use of manual drainage in addition to physiotherapy in patients who had recently undergone ankle surgery.106 The authors reported improved lymphedema volume loss with the addition of MLD (6.4%) over physiotherapy alone (0.1%; p = 0.01).

Question 10: Did any studies show that the time of treatment initiation (single modality or combination therapy) relative to symptom onset, any other lymphedema characteristics, or any patient characteristics influenced or predicted treatment outcome?

A minority of publications (8/36) commented on factors predictive for response to therapy.48,112,113,115,119,123,131,132 With only two exceptions,131,132 studies reporting on predictive factors were RCTs. No RCTs with a low quality score commented on predictive factors.

Pretreatment lymphedema volume was the most commonly reported factor, with contradictory findings. One study of massage and bandaging suggested a greater percentage response in those patients with mild, as opposed to moderate, cases.123 Another similar study, however, suggested opposite results but did not provide any supporting statistics.119 A third study suggested that pretreatment volumes were “predictive of treatment response” but did not report the direction of this association.113 A fourth study examining pneumatic compression reported no influence of lymphedema severity on response.112 One study also reported a non-significant trend toward better responses in those patients who had been diagnosed with lymphedema for less than 1 year.123 Another reported no such difference with respect to duration.112

One study of MLD suggested that compliance with the use of elastic compression sleeves predicts for a better treatment response.115

Two non-randomized studies reported predictive factors on very specific patient populations in which active disease was allowed in the study groups. One report found no difference in the response to decongestive therapy, regardless of the presence or absence of active disease.131 A further study found that those patients with leg lymphedema from Kaposi’s sarcoma had a similar response to elastic stockings, regardless of chemotherapy use.132

Across all studies, several factors were not found to predict treatment response, including a history of prior radiation, prior chemo therapy, type of previous surgery, a history of prior infection, age, body mass index (BMI), and gender. The authors of an RCT where weight-lifting was the active treatment adjusted their results for cancer stage, number of cancer nodes, race, physical activity, diet, and BMI, and found no effects on the unadjusted results.48

Question 11: What was the length of followup in studies of lymphedema therapy? How long were the benefits of treatment maintained?

Followup periods varied considerably between studies, with little correlation between followup length and study type, intervention or quality. Many studies ended immediately after treatment, with five studies following patient response for up to 1 year.48,50,104,132,134 The shortest of the studies measured patients immediately after 24 hours.124 One RCT suggested that the authors would be reporting followup data in a further report; however, the initial study was published 4 years ago and an update has not been published.119

Of those studies which suggested an initial benefit to therapy and reported followup beyond treatment, some showed a loss of benefit by the end of the study period. One observational study of elastic sleeve or IPC found that both groups had returned to baseline levels 4 to 12 weeks from cessation of treatment. This occurred despite the use of either sleeve or IPC for maintenance.130 One report suggested a superior response to laser compared with sham treatment at 3 weeks following the last laser treatment. This benefit was lost by 7 weeks. No therapy was used beyond the initial study treatment.118

The majority of studies showing durable benefit also provided patients with some form of maintenance therapy.50,104,105,108,110,111,115,120,132 The majority of those studies used elastic sleeves as maintenance therapy with exceptions being a choice of either massage and sleeve or IPC,111 exercises,104 and MLD.120 Of those studies using elastic sleeves following initial therapy, one was an observational study of ultrasound or mechanical pressure therapy in which both groups showed prolonged benefit up to 52 weeks.50 Another followed patients with active Kaposi’s sarcoma for over 1 year, using an elastic stocking.132 Only two RCTs showed benefit for up to 1 year with the use of a sleeve. One study compared MLD to sleeve alone at the initiation of treatment, with both groups showing prolonged benefit.115 The other compared bone marrow stem cell transplant with CDT.105 In this study, both groups showed continuing benefit at 1 year but more so in the group receiving transplant. One further trial with sleeve as maintenance therapy showed benefit for up to 6 months following comparison with electronically-stimulated lymphatic drainage.110 A further study of decongestive lymphatic therapy with or without IPC showed continued benefit with maintenance sleeve in both groups at 40 days, with more benefit in the group receiving IPC.108

Only two studies showed benefit beyond the initial treatment phase without the use of maintenance treatment. In one study of IPC versus elastic sleeve, the last assessment was only 1 week following active treatment.113 In the other study, comparing laser versus sham laser, there was lasting benefit in those patients who had received 2 cycles (each cycle being 9 sessions over 3 weeks) of laser, but not those who only underwent one cycle.33 This benefit was seen 12 weeks following the last treatment.

Question 12: What harms have been reported associated with the various treatments for lymphedema? Do any patient characteristics (e.g., demographics, comorbidities) or etiology of lymphedema increase the risk of these harms?

The value of any intervention can only be determined when benefit is balanced against potential harm. Overall, reporting of adverse events was rare. Only 17 of 30 trials reported on harms. Fourteen of the 23 RCTs with a Jadad score of 4-8 reported on adverse events.33,47,108,111-113,116-119,121-124 Three of seven lower scoring trials reported adverse events.104,106,126 In those trials which commented on adverse events, the total number of patients was 616. The majority of patient withdrawals in those studies were due to reasons such as scheduling, failing to show for visits, personal reasons, or refusal of therapy. Overall, 36 of 616 patients (6.0%) were reported as not receiving therapy as intended.116,117 33,104,106,112,118,122,123 Unfortunately, it was not possible to discern whether refusal of therapy was due to adverse events in these situations.

Other adverse events more specifically addressed were much rarer. Because the majority of trials addressed lymphedema in patients with cancer, more specifically breast cancer, the most common finding reported was recurrence of malignant disease. Overall, 11 patients (2%) were found to have recurrent disease during or shortly after the study period.33,47,112,116,117,119 Adverse events which may have been specific to therapy were less common, occurring in less than 1 percent of patients, such as infection, “skin reaction”/dermatitis,33,123 arm thrombosis,33,117 headache with elevated blood pressure,108 and arm pain.123

In a trial evaluating bandages, subjects getting high pressure bandages reported more pain and discomfort than subjects receiving low pressure bandages, although the assessment was done using an author developed scale.124 A similar scale was used in an RCT comparing kinesiology tape with short stretch bandaging: subjects reported greater wound development from usage of the tape relative to the bandage (p = 0.013).128