# Methods

## Literature Search Strategy

We conducted a comprehensive search of the literature to capture all relevant, published studies on the topic of diagnosis and treatment of secondary lymphedema. The following electronic databases were searched:

1. MEDLINE^®^ (1990 – January 19, 2010);
2. EMBASE^®^ (1990 – January 19, 2010);
3. Cochrane Central Register of Controlled Trials^®^ (1990 – January 19, 2010);
4. AMED (1990 – January 19, 2010); and
5. CINAHL (1990 – January 19, 2010).

In all of the databases, both subject headings and text word terms for ‘lymphedema’ were included in the search. Terms for complete decongestive therapy, manual lymphatic drainage and intermittent pneumatic compression were included in the search. There were no language limitations for this search. Appendix A contains a detailed description of the database search strategies.

To supplement the database search, we examined the reference lists of several recently published review articles2,8-11 and searched the bibliographies of included articles.

Inclusion/exclusion criteria. There were different sets of inclusion and exclusion criteria for the diagnostic and treatment sections of the report. For the diagnostic section, we included studies published in the English language that examined the sensitivity and specificity, or psychometric properties (e.g., reliability, validity, responsiveness), of diagnostic tests for lymphedema. Included studies had to evaluate the diagnostic test(s) on subjects with secondary lymphedema. Studies that were exploratory in nature or did not use secondary lymphedema subjects were excluded. We also excluded case series, case reports, narrative and systematic reviews, editorials, comments, letters, opinion pieces, abstracts, conference proceedings, and animal experiments.

For the treatment section of the report, we included studies published in the English language, provided they were randomized controlled trials (RCTs) or observational studies with comparison groups (e.g., cohort, case control). We excluded case series, case reports, narrative and systematic reviews, editorials, comments, letters, opinion pieces, abstracts, conference proceedings, and animal experiments. We included studies of pediatric and adult patients who received treatment for secondary lymphedema following any form of illness with the exception of filariasis infection. We also included studies with all forms of treatment for secondary lymphedema except surgery and drug therapy.

## Study Selection and Reporting

A team of trained raters applied the inclusion and exclusion criteria to the citations that were retrieved in the literature search. Guidelines and standardized forms were developed to govern the screening process. The forms were created and stored online using Systematic Review Software (SRS) v4.0 (Mobius Analytics Inc., Ottawa, Ontario, Canada). The screening process was divided into three levels. For the first two levels, two independent raters evaluated the titles and abstracts of citations that were obtained from the literature search. Citations that satisfied the inclusion criteria were advanced to the next level. Citations were also advanced if there was insufficient information to determine whether the inclusion criteria were satisfied. The complete, published manuscript was retrieved for all citations that passed through title and abstract screening. Once retrieved, the complete manuscript was screened to determine if the inclusion criteria were met (level three – full text – screening). At this stage, the raters assigned the studies to the key question or questions to which they applied.

At every stage of screening, agreement was required from both raters for a study to be promoted to the next level. Discrepancies were resolved by consensus. If consensus could not be reached, then a neutral third party reviewed the study in question and made a final decision.

Studies that passed the full text screening phase proceeded to full data extraction. The following information was extracted from each diagnosis article: type of diagnostic test, study design, sample size, inclusion and exclusion criteria, sensitivity/specificity, psychometric properties of test, and outcomes. The following information was extracted from each treatment article: type of treatment, study design, sample size, inclusion and exclusion criteria, criteria used to start and stop therapy, time of treatment initiation, time of lymphedema onset, provider of treatment, comparators in study, parameters of treatment, outcomes, length of followup, and reporting of harms.

The authors of this report reviewed the extracted data to confirm the accuracy of the work.

### Non English Language Studies

In response to peer review of the draft report, we reran the literature search a second time to identify non English language articles, which were screened at three levels as described above. The purpose was to examine whether the non English language literature was substantively different from the English language literature. We did not extract data from the non English language articles that survived the screening process. Rather, we provided a written summary of the main contents of these articles and discussed whether (and how) they differed from the English language literature.

### Quality Assessment of Included Studies

Following data extraction of English language studies, two raters independently assessed the quality of these studies. Discrepancies were resolved by consensus or third party review. The quality of diagnostic studies was assessed using the Quality Assessment of Diagnostic Accuracy Studies (QUADAS) scale.12 The QUADAS scale contains 14 questions that examine potential sources of bias in diagnostic studies. Response options are ‘yes’, ‘no’, or ‘unclear’. The general domains covered by the questions include representativeness of subjects, clear selection criteria, and appropriateness of the reference standard test. Unlike many quality instruments, the QUADAS does not award points for answers that signify ‘good quality’, nor is there a summary score.

The quality of treatment studies was assessed using two scales, the modified Jadad scale for RCTs and the Newcastle-Ottawa Scale (NOS) for cohort and case control studies. The modified Jadad scale13,14 contains six questions covering the following domains: randomization, double blinding, tracking of withdrawals and adverse effects, use of statistics, and inclusion and exclusion criteria. One point is awarded for each ‘yes’ response; zero points for ‘no’ responses. Additional points may be added or deducted if the randomization scheme and blinding are appropriate or inappropriate. The maximum score is eight points.

The NOS consists of two subscales, one for cohort and the other for case control studies.15 Both subscales measure the same three broad domains: selection of study groups, comparability of study groups, and means of ascertaining exposure or outcome. The NOS contains a 'star system' to score studies (maximum score is nine stars). Studies are rated using a checklist and stars are awarded for responses that signify the highest possible quality on each checklist item. The QUADAS, Jadad, and NOS instruments are shown in Appendix B.

The overall quality of the extracted articles was rated ‘good’, ‘fair’, or ‘poor’ in accordance with the recommendations outlined in the Agency for Healthcare Research and Quality’s methods guide.16 Quality cut off scores were not used to exclude articles. Article quality was discussed in the responses to the key questions when the authors judged that quality had an impact on the evidence.

### Answering the Key Questions

The research team used a qualitative, descriptive approach to answer the key questions. This approach included summarizing the extracted data in tables and using these summaries to address the key questions. The research team did not believe a meta analysis was feasible because the included studies contained far too much clinical and methodological heterogeneity.

### Peer Review

Prior to finalization of the report, the AHRQ submitted a draft to three peer reviewers and their comments were implemented after consideration by the research team. The report was also made available on the AHRQ website for public review; public reviewers' comments were also implemented after consideration by the research team. In situations where the research team decided not to revise the content of the report based on a reviewer's comments, a written explanation of the reason(s) for choosing not to revise have been submitted to the AHRQ.