# Introduction

## Scope and Purposes of the Technology Assessment

The Centers for Medicare and Medicaid Services (CMS) requested a technology assessment on the diagnosis and treatment (conservative, nonpharmacological) of secondary lymphedema. The purpose of the technology assessment was to provide CMS with evidence-based data to use in the consideration of coverage for these diagnostic and treatment approaches. CMS developed the key research questions listed below.

### Diagnosis

1. What is the performance of diagnostic tests for preclinical and/or clinically significant lymphedema? Consider:
  a. What inclusion criteria (including patient demographics, signs, and symptoms) were used in studies evaluating the performance of diagnostic tests of lymphedema?
  b. Is there any “gold standard” method to formally grade or measure the severity of lymphedema?
  c. What comparators were used in the studies of diagnostic tests? Was the test compared to a “gold standard”, bedside exam, radiologic investigation, or other means?
  d. What is the sensitivity and specificity of tests used to diagnose lymphedema?
  e. What are the psychometric properties (reliability, validity, responsiveness) of these diagnostic methods?
  f. How frequently and for how long should patients be measured for the development of lymphedema or its subclinical precursor? Does this vary with the diagnostic test method?
  g. Does the diagnostic test method influence the choice of lymphedema treatment or patient outcome? What outcomes were measured in studies of diagnostic tests of lymphedema?

### Treatment

For the nonpharmacologic/nonsurgical methods of treatment of all stages of lymphedema:

2 What were the patient selection criteria in the studies (inclusion and exclusion criteria)? Did they differ by treatment modality?
3 What were the criteria used to initiate treatment for lymphedema? When was treatment initiated compared to the time of onset of the lymphedema? What were the criteria used to stop therapy? Did these criteria vary with treatment modality?
4 Who provided the treatments in the studies? What information was provided on their professional training or certification in lymphedema care?
5 For Intermittent Pneumatic Compression (IPC)
  a. Was one type of pneumatic compression device and sleeve (e.g., nonsegmented compression device, sequential segmented compression, or segmented compression with calibrated gradient pressure) more effective in reducing lymphedema than another for any type of lymphedema along the continuum, or patient characteristic (e.g., demographics, comorbidities)?
  b. Did the studies of IPC for lymphedema in patients with comorbidities such as wounds, arterial and/or venous insufficiency, diabetes, congestive heart failure, infection, etc., report the need to modify their treatment protocols? Did it affect treatment outcome?
  c. Did the timing of an IPC application and/or the sequence of use of the various IPC device types (either alone or in combination with other therapies) influence outcomes either positively or negatively?
6 What protocols for single modality treatments resulted in the best outcomes of lymphedema therapy? Consider parameters such as usage schedules and characteristics of treatment such as intensity, duration, frequency and setting (self administered at home vs. professionally applied in a medical clinic), and if applicable pumping times/cycles and pressures.
7 Were there any treatments, combinations of treatment methods, or sequence of treatments shown to be more effective or ineffective for any type of lymphedema along the continuum, or patient characteristics (e.g., demographics, comorbidities)? Of particular interest: Is there evidence that the use of compression sleeves or low stretch bandaging is effective in maintaining reductions in lymphedema achieved through the use of other modalities (e.g., IPC, manual lymphatic drainage, exercise)?
8 What comparators were used in the studies? Are these comparators consistent with usual care for lymphedema?
9 What outcomes were measured in studies of lymphedema therapy? How effective were these treatment methods in reducing lymphedema?
10 Did any studies show that the time of treatment initiation (single modality or combination therapy) relative to symptom onset, any other lymphedema characteristics, or any patient characteristics influenced or predicted treatment outcome?
11 What was the length of followup in studies of lymphedema therapy? How long were the benefits of treatment maintained?
12 What harms have been reported associated with the various treatments for lymphedema? Do any patient characteristics (e.g., demographics, comorbidities) or etiology of lymphedema increase the risk of these harms?

## Background

The human circulatory system is comprised of two interacting closed systems: the arterial-venous system and the lymphatic system. The lymphatic system is a network of vessels (lymphatics) which transport lymph. Lymph is a clear fluid that contains cells and proteins and originates as interstitial fluid (fluid that occupies space between cells). The lymphatic system drains lymph into the venous blood.17

Lymphedema is a pathological condition of the lymphatic system. The normal lymphatic system has three major functions, namely to transport lymph from the periphery of the body to the large veins of the chest and neck, to maintain homeostasis, and to regulate immunity.18 Lymph flow occurs from peripheral lymphatics to the lymph nodes (distal to proximal). Peripheral lymphatics are dead ended and they originate in the distal-most tissues of the skin, muscles, visceral organs, lung, and intestine. Major lymph node bearing areas include the neck, chest, abdomen and, importantly for the following discussion, the axilla and groin.

Lymphedema is swelling (edema) that results from an accumulation of protein rich fluid in the interstitial space because of congenital or acquired damage to the lymphatic system.1

### Primary Versus Secondary Lymphedema

Primary lymphedema occurs in patients who have a congenital abnormality or dysfunction of their lymphatic system. There are different types of primary lymphedema: congenital occurring before 2 years of age; lymphedema praecox, which typically occurs at puberty; and lymphedema tarda, which has an onset after 35 years of age.2,3

Secondary lymphedema is an acquired condition resulting from the disruption or obstruction of the normal lymphatic system. Secondary lymphedema can be caused by disease, trauma, or an iatrogenic process such as surgery or radiation.2

### Staging of Lymphedema

In the United States and globally, lymphedema is currently staged by observing a patient’s physical condition (Table 1).4 Historically, there were three stages of lymphedema, although a fourth stage, Stage 0 (subclinical lymphedema), has received increased recognition. The 2009 Consensus Document of the International Society of Lymphology (ISL) states that “...a more detailed and inclusive classification system needs to be formulated in accordance with an understanding of the pathogenic mechanisms of lymphedema..and underlying genetic disturbances (p. 3)”.4 At present, such a classification system has not been developed and lymphedema is often staged as shown in Table 1 below.4,19

Table 1 Stages of Lymphedema

Stage | Description
Stage 0 | A latent or subclinical condition where swelling is not evident despite impaired lymph transport. Stage 0 may exist months or years before overt edema occurs (Stage I-III).
Stage I | Early accumulation of fluid relatively high in protein content (e.g., in comparison with ‘venous’ edema) that subsides with limb elevation. Pitting may occur. An increase in proliferating cells may be seen.
Stage II | Limb elevation alone rarely reduces tissue swelling and pitting may or may not occur as tissue fibrosis develops.
Stage III | Lymphostatic elephantiasis. Pitting is absent and trophic skin changes such as acanthosis, fat deposits, and warty overgrowths develop.

According to the ISL, within each stage “an inadequate but functional severity assessment (p.3)”4 exists that assesses severity based on limb volume increases from baseline. Physicians may also consider extent of lymphedema, inflammation, presence of erysipelas attacks and complications in their assessment of severity.4

### Pathophysiology of the Causes of Lymphedema

Primary lymphedema. Primary lymphedema results from improper lymphatic development that is not attributed to injury, trauma, illness, or disease. The damaged lymphatics cannot propel lymph in adequate quantities and fluid accumulates in the interstitial or lymphatic spaces.19

Secondary lymphedema. The exact pathophysiology of secondary lymphedema depends on its etiology. Globally, the most prevalent cause of secondary lymphedema is from infection with the nematode Wusheria Bancrofti, which leads to lymphatic filariasis. The filarial larvae enter the human host when a mosquito bites and then grow into adult worms that damage the lymphatic system, leading to a disruption of lymphatic flow. It has been estimated that more than 14 million people worldwide suffer from lymphedema and elephantiasis of the leg caused by lymphatic filariasis.20 Filariasis is not endemic to the United States (U.S.) and thus incident cases of lymphatic filariasis are rare and occurrences can usually be traced back to a visit to an endemic country.

In the U.S., the most common cause of secondary lymphedema is malignancies and their related treatment (i.e., surgery, radiation). If a malignancy or tumor is present in the lymphatic system, then it can act as a physical block to lymph flow, thereby leading to lymphedema. When lymph nodes are removed during the treatment of cancer, scarring and adhesions may develop that decrease or block lymph flow. Radiation therapy over the lymph nodes can cause further damage and scarring, which may impair lymph flow and lead to lymphedema.

Less common causes of secondary lymphedema include trauma, chronic venous insufficiency, nonfilariasis infection, and obesity. Trauma can destroy lymphatic structures contained in the skin, resulting in impaired lymph flow (e.g., severe burns).3 In chronic venous insufficiency, there is usually longstanding damage to the veins and their valves. Valve failure results in a continual backflow of blood in the veins, which increases pressure on the veins and damages the delicate surrounding lymphatic structures. When the lymphatic structures are damaged, lymphedema ensues.3 Infection in the lymphatics from a variety of sources, including possibly venipuncture, can cause lymphedema. For this reason, patients recovering from cancer treatment must be vigilant about skin care and the prevention of infection.2

Obesity has also been shown to impede the flow of lymph, leading to the accumulation of protein rich fluid in the subcutaneous tissue.1

### The Incidence of Secondary Lymphedema in Both the Upper and Lower Extremities in the United States

The incidence of secondary lymphedema for all diagnostic categories is generally poorly documented. There is great variability in the incidence rates, which results from the variety of measurement techniques and definitions used in studies that evaluate the rates of lymphedema, as well as a general lack of literature on the incidence of secondary lymphedema.2

Filariasis. The incidence of filariasis in the U.S. is essentially zero percent as filariasis is not endemic to the U.S. The rare cases that are recorded can be traced back to travel and exposure in an endemic country.21

Upper extremity lymphedema. Breast cancer accounts for the majority of upper extremity secondary lymphedema in the U.S.2 Rates of lymphedema after mastectomy have been reported between 24 to 49 percent.2 A 5 year, population based, prospective study of female U.S citizens with incident breast cancer documented a 42 percent cumulative incidence of lymphedema following treatment for breast cancer.22 Axillary node clearance and radiation therapy to the axilla have been shown to increase the incidence of lymphedema after breast cancer treatment, especially when radiation therapy is used adjunctively.2,20 Conversely, sentinel node biopsies have been shown to decrease the incidence of secondary lymphedema compared to axillary dissection.2,6

Lower extremity lymphedema. The incidence of lower extremity lymphedema is even less well documented than upper extremity lymphedema. Lymph node dissection for malignant melanoma has been shown to have an incidence risk of lymphedema as high as 80 percent, though other studies suggest an incidence between 6 to 29 percent.20 Treatment for cervical, endometrial, and vulvar malignancies has an incident rate of lymphedema between 5 and 49 percent, with a higher incidence when treatment involves radiation therapy.20 In prostate cancer, the incidence of lymphedema has been observed at 3 to 8 percent, with the use of radiation therapy augmenting the incidence by three to fourfold.20

Incident data are lacking for secondary lymphedema associated with trauma, chronic venous insufficiency, nonfilarial infection, and obesity.

### How Might the Adoption of Sentinel Lymph Node Biopsies Influence the Incidence of Secondary Lymphedema?

A sentinel lymph node is any lymph node that receives direct drainage from a tumor site. Sentinel nodes can be identified by lymphatic mapping, which is done through injection of radiocolloid or blue dye. The sentinel lymph node can then be biopsied and examined for the presence of micrometastases.5 In the event that the sentinel lymph node biopsy (SLNB) is negative, complete lymph node dissection may be avoided in certain types of cancers. SLNB is now part of the standard of care for patients with breast cancer and melanoma because it provides accurate tumor staging, equivalent cancer related outcomes and less morbidity, including a decreased incidence of lymphedema compared to full regional lymph node removal. At present, SLNB is being studied for use in patients with gynecologic, genitourinary, and gastrointestinal tumors. Cervical cancer is still very difficult to treat with SLNB alone as multiple studies have recorded unacceptable levels of false negative results.5

Though SLNB has been shown to decrease the incidence of lymphedema, researchers continue to study the amount of reduction. A 5 year, prospective trial followed 936 women with breast cancer who underwent SLNB alone or SLNB in combination with axillary lymph node dissection (ALND). The incidence of lymphedema was 5 percent in the SLNB group and 16 percent in the SLNB/ALND group.6 The Royal Australian College of Surgeons conducted an international, multicentre, randomized controlled trial that examined SLNB versus axillary dissection in women with breast cancer. The study found that women receiving SLNB had less lymphedema, less pain, and less arm dysfunction.7

### Available Methods to Diagnose Lymphedema

The diagnosis of lymphedema can usually be accomplished through clinical history and physical examination.2 It is essential to rule out other causes of edema such as deep vein thrombosis (DVT), heart failure, tumor, or infection. It is also important to determine if the lymphedema is primary or secondary in nature. If there is doubt to the nature of the lymphedema (primary versus secondary or recurrence of a tumor) or its existence (e.g. lymphedema versus venous insufficiency), lymphoscintigraphy can be performed. This test images the lymphatic system, is a form of isotope lymphography, also known as lymphangioscintigraphy. Isotope lymphography is different from its predecessor, contrast lymphography (lymphangiography). Contrast lymphography involves the injection of radio-opaque lipiodol directly into a peripheral lymph vessel and an x-ray is used to monitor the movement of lipiodol in the lymph system.3 Contrast lymphography is rarely used today as it requires surgery and has been associated with complications such as wound infection and damage to the lymphatic vessels.23 On the other hand, lymphoscintigraphy (isotope lymphography) involves the injection of a radioisotope labeled colloid into the interdigital region of the affected limb. A gamma camera is then used to track the flow of colloid as it moves towards the proximal lymph nodes. Lymphoscintigraphy is superior to contrast lymphography as it allows the practitioner to measure lymph flow and carries less risk of complications.23 Though lymphoscintigraphy is often recommended as the test of first choice for the detection of lymph flow abnormalities,3 the test lacks universal standards of application.24,25 Thus further research is warranted to refine the standards of application. When lymphoscintigraphy is not available or desired, magnetic resonance imaging (MRI) and computed tomography (CT) can be used. Both MRI and CT image lymphedema as a subcutaneous honeycomb pattern, though MRI is seen as superior to CT because it also detects excess fluid.3 Ultrasound can also be used for evaluation of lymphedema and has been used to correlate subcutaneous tissue thickness with lymphedema and fibrosis progression.26

During physical examination for lymphedema of the extremities, various methods of limb volume measurement may be employed to determine if a volume increase is present in the affected limb. These methods include limb circumference measurement, water displacement (volumetry), and perometry. Volume measurements are compared with the unaffected limb and lymphedema is often defined as a 2 cm or greater difference in girth, a 200 ml or greater difference in volume or a 10 percent or greater difference in limb volume.27 Tonometry and tissue dielectric constant may also be used to assess whether lymphedema is present in the limb.

Limb circumference measurement is used to calculate limb volume. A flexible non elastic measuring tape is employed to measure limb circumference at various anatomical landmarks or at given distances from the fingertips or toes.27-29 Limb volume is then calculated using the frustrum sign method (volume of a truncated cone) or the disk model method (summed truncated cones).30 The volume of a truncated cone is calculated by taking the circumference of the limb at two different points and using the distance between the two points to calculate volume. The disk model method divides the arm into 10 disks, each with a height of 5 cm. The volume of each disk is then calculated and all 10 volumes summed.30 On the upper limb, the typical points of measurement are at the hand, wrist and above and below the lateral epicondyle. The advantages to limb circumference measurement is that it is fairly easy to perform in a clinical setting, has a low cost and has good reliability.30,31 A drawback to limb circumference is the inability to accurately measure the volume of the hand due to its irregular shape.32

Volumetry is used to calculate limb volume by having subjects submerge their swollen limb into a cylinder filled with a known amount of water. The amount of water that is displaced by the limb is equal to its volume. To measure the amount of displaced water, one can weigh the water or measure the volume. Water displacement is a reliable method of measuring limb volume30,31 though its use is not very practical in a clinical setting because of water spillage and space considerations.

Perometry, also known as infrared optoelectric volumetry, uses infra red light to measure the volume of a limb. The limb is placed in a solid frame and the perometer scans the limb taking volume measurements at multiple segments. Limb volume is then calculated by summing the volumes of elliptical segments using a special computer program.28,30 Perometry for the upper limb using Volometer® (Bosl Medizintechnik, Aschen Germany) was shown to have excellent intrarater and interrater reliability (ICC = 0.997).30 Though shown to be reliable, perometry is expensive, which may limit its clinical application.

Tonometry measures tissue resistance and attempts to determine the extent of tissue fibrosis. Tonometry is unique in that it tracks tissue resistance instead of volume, offering a different outcome for lymphedema measurement. The original tonometer was developed at Flinders Biomedical Engineering in Australia. It consists of a 200g mass, plunger, reference plate and measurement dials. When the tonometer is placed perpendicular to the skin, the 200g mass gently pushes the plunger into the skin and the depth that the plunger descends is recorded.31,33 The disadvantage of tonometry is that it only has fair to good reliability.31

Tissue dielectric constant is an electrical parameter that can be used to measure the water content in tissue. The constant is calculated by applying an ultra high frequency electromagnetic (EM) wave to the skin through a probe and measuring levels of energy absorption and reflection. When the EM wave penetrates tissues below the skin, the wave interacts with water molecules. Water molecules absorb EM energy and if there is a greater quantity of water in a given tissue, then there will be less reflection of the EM wave. The amount of EM energy reflected is used to calculate the dielectric constant, which is directly proportional to tissue water content. The measurement of tissue dielectric constant can be used to record increases in tissue water content as seen in lymphedematous tissue.34 At present, the psychometric properties of tissue dielectric constant has not been evaluated in detail.

It is very difficult to detect subclinical lymphedema (Stage 0) with current diagnostic methods. Bioimpedance has been proposed as a method of diagnosing Stage 0 lymphedema. Bioelectrical impedance analysis measures the body’s response to an electrical current. A low level current is applied through the body and the impedance (or resistance) to flow is measured. Current flows along the path of least resistance through the body and thus follows tissues with the highest water content, thereby allowing for edema to be measured.35

In addition to the above techniques for diagnosing and measuring lymphedema, a questionnaire called the Lymphedema and Breast Cancer Questionnaire (LBCQ) has been developed to screen for lymphedema. The LBCQ requires respondents to indicate whether each of 19 symptoms (e.g., heaviness, swelling, numbness) has occurred currently (now or in the past month) or in the past year. Respondents answer ‘yes’ or ‘no’ to the current and past year questions for each symptom. Scores for total current symptoms and total symptoms in the past year are calculated, with a resulting maximum score of 38 (1 point for each ‘yes’ response).36 The authors of the LBCQ report that it has demonstrated face and content validity and that internal consistency was r = .785 for all 19 items and test-retest reliability was r = .98 when evaluated on 35 healthy women.36

### What is the Food and Drug Administration Status of any Devices Used to Diagnose Lymphedema?

The FDA regulates the marketing and use of medical devices in the U.S. The following is the FDA status of certain devices used in lymphedema diagnosis.

Lymphoscintigraphy. The FDA does not appear to have reviewed lymphoscintigraphy for the diagnosis for lymphedema.

MRI. MRI is 510k cleared by the FDA for medical imaging purposes. There are no specific details about its use in lymphedema diagnosis.37

CT. CT scan is 510k cleared for medical use, though highly regulated by the FDA due to radiation risk. The FDA does not specifically mention the use of CT for the diagnosis of lymphedema.

Ultrasound. Ultrasound, which is sometimes used to help with the diagnosis of lymphedema, has been 510k cleared by the FDA for medical imaging. There is no specific mention of the use of ultrasound in the diagnosis of lymphedema.38

Bioimpedance devices. Certain bioelectrical impedance devices have 510k clearance from the FDA. Impedimed Imp SFB7 Body Composition Analyzer has been cleared by the FDA as has the Impedimed L-Dex U400 BIS extracellular fluid analysis. The L-Dex U400 BIS has been cleared specifically for lymphedema use.39,40

Perometer. No evidence has been found for whether perometry is considered a device or if it has been cleared, either in general or specifically for lymphedema.

Tonometer. A search of the devices product classification database yielded no results for whether tonometry is considered a device or if it has been cleared, either in general or specifically for lymphedema.

Tissue dielectric constant. A search of the devices product classification database yielded no results for whether tonometry is considered a device or if it has been cleared, either in general or specifically for lymphedema.

### Nonpharmacologic/Nonsurgical Methods of Treatment for Lymphedema

Compression techniques (including multilayer bandaging techniques, self adherent wraps, and compression garments at prescribed pressure gradients). Compression techniques consist of bandaging and compression garments. Both act to restore hydrostatic pressure in the limb and improve lymph flow.41 Bandaging is performed with low stretch bandages designed to maintain a constant pressure at rest and an increased pressure with exercise, thus assisting the muscle pump effect. High stretch bandages are not recommended because their application pressure may be difficult to control at rest, thereby increasing the potential for impaired circulation. During exercise, there may be decreases in the pressure exerted by high stretch bandages, thus preventing an increase in lymph flow via the muscle pump effect.41,42

Compression garments are fitted to the individual patient and constructed with the intent of exerting a prescribed pressure on the limb. They can be of use to patients who are unable to self wrap with bandages.

Intermittent pneumatic compression. Intermittent pneumatic compression (IPC) is used in the treatment of lymphedema, as well as arterial disease, DVT, and chronic venous insufficiency.43

IPC devices consist of pneumatic cuffs connected to a pump that, when applied to human limbs, mimics the muscle pump effect that naturally occurs when muscles contract around the peripheral lymphatics.43 It is thought that compression may empty terminal lymphatics, thereby allowing drainage of fluid from the interstitium and possibly facilitate fluid flow from the interstitium to the lymphatics. It is still not known if IPC assists protein clearance from tissue.43

With IPC, a pumping action on the limb is created by an air filled bladder that fills and exerts pressure on the limb. Most pumps are electrically driven and the timing of the IPC application varies significantly between devices. Cycle time can be as short as 2 seconds or as long as 2 minutes. Typically, devices made for lymphedema contract for a longer period of time because lymph flow is slow and a longer compression time is required to move lymphedema out of the limb.43

The pressure applied from an IPC device is usually between 35 and 180mmHg, though it can be as high as 300mmHg. Compression can be applied in a uniform manner using a single chamber cuff or in a sequential manner when a multicompartment cuff is used. IPC may be combined with compression stockings between sessions to help prevent a gradual reoccurrence of edema.43

Currently there is no noninvasive method for measuring sudden changes in lymph flow, thus making it difficult to ascertain if a given cuff has actually improved lymph flow or reduced edema. This limitation inhibits the study of the efficacy of IPC devices. The inability to measure lymphatic flow and to objectively assess lymphedema reduction has also prevented the establishment of standard or ideal compression sequences and pressures.43

Decongestive therapy. Decongestive therapy, more commonly known as Complex (or Complete) Decongestive Therapy (CDT), is conducted with the intent of decreasing fluid in the lymphedematous limb, preventing infection, and improving the integrity of tissues. CDT is comprised of multiple therapies and is administered in two phases. The first phase is the intensive phase and includes manual lymphatic drainage (MLD), compression of the limb with low stretch bandages, skin care, and moderate exercise while wearing bandages. Ideally, phase one is administered one or two times a day, every day for 4 to 6 weeks. Phase two is the maintenance, self management phase. Given that lymphedema is a chronic condition, this latter phase lasts indefinitely. Phase two is similar to Phase one, but there is less use of MLD and there is an increased use of compression garments instead of bandaging, which allows patients to self treat as bandages are hard if not impossible for patients to apply on their own. Exercise and skin care continue from phase one.41,44 Some practitioners also incorporate IPC into their CDT regime.

CDT has been observed to have a significant effect on edema reduction and is recognized internationally as a successful treatment for lymphedema.41,44

Manual Lymphatic Drainage (MLD). Traditional deep tissue massage is not used for lymphedema because it can damage the delicate lymphatic system.44-46 Instead, MLD is administered using light strokes on the limb. The goal of MLD is to use these strokes to direct lymph flow away from blocked lymphatics and toward open lymphatics. The light pressure exerted on the tissues is thought to increase lymph flow without crushing the lymphatics.41,45,46

Exercise. Exercise is used regularly to treat lymphedema. Historically there was a concern that exercise might exacerbate lymphedema. This concern has subsequently been shown to be unfounded.47,48 Exercise helps increase lymph flow via the contraction of muscles around the lymphatics, which helps propel lymph proximally.42 Exercise also burns calories, which helps in the maintenance of a healthy body weight. Obesity has been shown to be a risk factor for lymphedema and thus weight control is an important part of lymphedema treatment.1

Exercise is usually prescribed in conjunction with MLD and bandaging as a part of CDT. Exercise is done at moderate intensity while wearing low stretch bandages or a compression sleeve. Aerobic, resistance, and flexibility exercises are incorporated into the program. Deep breathing exercises are often used as inspiration decreases intrathoracic pressure, thereby promoting the return of lymph to the central veins.1

Low level laser. Low level laser therapy (LLLT) has been reported to have a beneficial effect in the treatment of lymphedema.33 LLLT employs low intensity wave lengths between 650-1000nm in a scanning or spot laser form.10 It has been suggested that the mechanism of action of LLLT encourages formation of lymphatic vessels (lymphangiogenesis), promotes lymph flow and stimulates the immune system.10,33 LLLT has also been shown to break down scar tissue.49

Ultrasound (US). At present there is very little literature examining the use of US for lymphedema management. It is thought that US promotes lymph flow by way of wave propagation at the cellular level, which modifies cell metabolism and microcirculation.50 The efficacy and safety of US remains to be established.

Aquatherapy. Aquatherapy, which consists of slow water based exercises, has been tried as a therapy for lymphedema.51 The physiological rationale for the use of aquatherapy is based on the concepts of hydrostatic pressure, water temperature, and water viscosity. Hydrostatic pressure increases with the depth of water and lymphedematous limbs are thought to benefit from this pressure gradient through the direction of interstitial fluid toward the trunk.51 Aquatherapy is performed in warm water to prevent capillary vasodilatation and decreased flow that can occur at lower temperatures. Water viscosity provides resistance to movement, which is believed to assist lymph flow via the muscle pump effect and promotes muscle strengthening. At present there is very little literature examining the use or efficacy of aquatherapy for lymphedema management.

### What Method(s) of Treatment is Considered Usual Care for Lymphedema Management?

No single treatment is considered usual care for lymphedema. At present CDT, which is a combination of therapies, is suggested as the main method of conservative care for lymphedema.2,41,44 CDT includes MLD, application of compression low stretch bandages, exercise, and skin care. IPC devices are sometimes used to supplement CDT.41,44

### Who are the Health Care Professionals That Administer These Treatments? Are any Training or Certification Standards Required?

Typically, physical or occupational therapists administer lymphedema treatments, though massage therapists, nurses and physicians may also perform certain kinds of lymphedema treatment.52 Health care professionals do not require any specific training prior to administering lymphedema treatment other than a valid license to practice their profession. This being said, many practitioners seek out additional specialized training in lymphedema management. Several schools exist to offer specialized training in lymphedema care. The Lymphology Association of North America (LANA) is a non-profit corporation that offers certification exams for practitioners of lymphedema care in an attempt to regulate and improve lymphedema management.52