# Excluded Studies^1^ 1 Includes studies excluded at full text level of screening only

Adam DJ, Naik J, Hartshorne T, et al. The diagnosis and management of 689 chronic leg ulcers in a single-visit assessment clinic. Eur J Vasc Endovasc Surg. 2003;25(5):462-8. OVID-Embase. Exclude: Not a study of efficacy of secondary LE treatment. [pmid: 12713787].
Adamian AA, Gordeev VF, Zolatarevskii VI, et al. Radionuclide diagnosis of lymphodynamic disorders in the upper limb after radical mastectomy. Sov Med. 1990;(5):108-10. (Rus). OVID-Medline. Exclude: exploratory study. [pmid: 2389191].
Albert U-S, Seifart U, Hoffmann M, et al. Feasibility test: Recommendations for the diagnosis of lymphedema after breast cancer in long-term follow-up and rehabilitation. Geburtshilfe Frauenheilkd. 2007;67(5):468-74. (Ger). OVID-Embase. Exclude: no control.
American Cancer Society. Lymphedema patient page. CA Cancer Journal for Clinicians. 2009;59(1):25-6. OVID-Embase. Exclude: narrative, primary LE, editorial, conference etc.
Andersen JS. Lymfodem - nye behandlingsprincipper. Danske Fysioter. 2000;17:6-11. OVID-AMED. Exclude: not able to retrieve.
Anderson L, Hojris I, Anderson J. Treatment of breast ancer related lymphedema with or without manual lymphatic drainage: A randomized study. Eur J Cancer. 1993;35(Suppl 4):S30-S31. OVID-CCTR. Exclude: Narrative, primary LE, editorial, conference etc.
Armer JM, Henggeler MH, Brooks CW, et al. The health deviation of post-breast cancer lymphedema: symptom assessment and impact on self-care agency. Self-Care, Dependent-Care & Nursing. 2008;16(1):14-21. Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=2476&accno=2009798231; http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2009798231&site=ehost-live. EBSCO-CINAHL. Exclude: narrative, primary LE, editorial, conference etc.
Badger CM, Peacock JL, Mortimer PS. A randomized, controlled, parallel-group clinical trial comparing multilayer bandaging followed by hosiery versus hosiery alone in the treatment of patients with lymphedema of the limb. Cancer. 2000;88(12):2832-7. OVID-Medline. Exclude: Primary/Secondary not stratified or patients did not have LE (treatment). [pmid: 10870068].
Bak M. Analysis of changes in perimeters of upper limb among women after mastectomy participating in motor rehabilitation. Postepy Rehabilitacji. 2008;22(2):15-21. (Pol). OVID-Embase. Exclude: no control.
Balzarini A, Milella M, Civelli E, et al. Ultrasonography of arm edema after axillary dissection for breast cancer: a preliminary study. Lymphology. 2001;34:152-5. Exclude: Diagnostic Exploratory Study. [pmid: 11783592].
Barclay J, Vestey J, Lambert A, et al. Reducing the symptoms of lymphoedema: is there a role for aromatherapy?. Eur J Oncol Nurs. 2006;10(2):140-9. OVID-Medline. Exclude: Primary/Secondary not stratified or patients did not have LE (treatment). [pmid: 16563861].
Berard A, Zuccarelli F. Test-retest reliability study of a new improved Leg-O-meter, the Leg-O-meter II, in patients suffering from venous insufficiency of the lower limbs. Angiology. 2000;51(9):711-7. OVID-Medline. Exclude: not stratified by primary/secondary LE or no LE (diagnosis). [pmid: 10999611].
Bergan JJ, Sparks S, Angle N. A comparison of compression pumps in the treatment of lymphedema. Vasc Surg. 1998;32(5):455-62. OVID-Embase. Exclude: Primary/Secondary not stratified or patients did not have LE (treatment).
Bertelli G, Venturini M, Forno G, et al. Pneumatic compression in postmastectomy lymphedema: a phase II study. Ann-Oncol. 1990;1(Suppl):30. OVID-CCTR. Exclude: Narrative, primary LE, editorial, conference etc. [pmid: 2078483].
Boccardo FM, Ansaldi F, Bellini C, et al. Prospective evaluation of a prevention protocol for lymphedema following surgery for breast cancer. Lymphology. 2009;42(1):1-9. OVID-Embase. Exclude: prevention. [pmid: 19499762].
Bolcal C, Iyem H, Sargin M, et al. Primary and secondary lymphoedema in male patients with oedema in lower limbs. Phlebology. 2006;21(3):127-31. OVID-Embase. Exclude: Diagnostic exploratory study.
Boris M, Weindorf S, Lasinski BB. The risk of genital edema after external pump compression for lower limb lymphedema. Lymphology. 1998;31(1):15-20. OVID-Medline. Exclude: No Control Group-Treatment. [pmid: 9561507].
Box RC, Reul-Hirche HM, Bullock-Saxton JE, et al. Physiotherapy after breast cancer surgery: results of a randomised controlled study to minimise lymphoedema. Breast Cancer Research & Treatment. 2002;75(1):51-64. OVID-Medline. Exclude: Prevention LE. [pmid: 12500934].
Brauer VS, Brauer WJ. Simplified method of attenuation correction of lymphoscintigraphic function test of the leg. Lymphologie in Forschung und Praxis. 2004;8(2):66-73. (Ger). OVID-Embase. Exclude: not stratified by primary/secondary LE or no LE (diagnosis).
Brauer WJ, Weissleder H. Methods and results of lymphoscintigraphic function tests: Experience in 924 lymphedema patients. Phlebologie. 2002;31(5):118-25. (Ger). OVID-Embase. Exclude: not stratified by primary/secondary LE or no LE.
Brauer WJ, Brauer VS. Comparison of standardised lymphoscintigraphy function test and high resolution sonography of the lymphoedema of legs. Phlebologie. 2008;37(5):247-52. OVID-Embase. Exclude: Narrative, primary LE, editorial, conference etc.
Brautigam P, Hogerle S, Reinhardt M, et al. The quantitative two-compartment lymphoscintigraphy for evaluation of the lower limb edema. European Journal of Lymphology and Related Problems. 1997;6(21):47-51. (Ger). OVID-Embase. Exclude: not stratified by primary/secondary LE or no LE.
Brorson H, Svensson H, Norrgren K, et al. Liposuction reduces arm lymphedema without significantly altering the already impaired lymph transport. Lymphology. 1998;31(4):156-72. OVID-Medline. Exclude: Narrative, primary LE, editorial, conference etc. [pmid: 9949387].
Brorson H, Svensson H, et al. Liposuction combined with controlled compression therapy reduces arm lymphedema more effectively than controlled compression therapy alone. Plastic & Reconstructive Surgery. 1998;102(4):1058-67. OVID-Medline. Exclude: Narrative, primary LE, editorial, conference etc. [pmid: 9734424].
Burnand KG, McGuinness CL, Lagattolla NR, et al. Value of isotope lymphography in the diagnosis of lymphoedema of the leg. Br J Surg. 2002;89(1):74-8. OVID-Medline. Exclude: not stratified by primary/secondary LE or no LE. [pmid: 11851667].
Cambria RA, Gloviczki P, Naessens JM, et al. Noninvasive evaluation of the lymphatic system with lymphoscintigraphy: a prospective, semiquantitative analysis in 386 extremities. J Vasc Surg. 1993;18(5):773-82. OVID-Medline. Exclude: Primary/Secondary not stratified or patients did not have LE (diagnosis). [pmid: 8230563].
Cao W, Chang T, Gan J. Effects of microwave heating on systemic and local infiltrating lymphocytes in patients with chronic limb lymphedema. Chin Med J (Engl). 1999;112(9):822-7. OVID-Medline. Exclude: Primary/Secondary not stratified or patients did not have LE (treatment). [pmid: 11717954].
Cao W, Zhang D, Gan J. Microwave effect on immunological response of chronic limb lymphedema. Zhongguo xiu fu chong jian wai ke za zhi. Chinese journal of reparative and reconstructive surgery. 2000;14(2):105-9. OVID-CCTR. Exclude: not stratified by primary/secondary LE or no LE. [pmid: 11778187].
Carroll D, Rose K. Treatment leads to significant improvement. Effect of conservative treatment on pain in lymphoedema. Prof Nurse. 1992;8(1):32-3. OVID-Medline. Exclude: Not able to retrieve. [pmid: 1480641].
Casley-Smith JR. Measuring and representing peripheral oedema and its alterations. Lymphology. 1994;27(2):56-70. OVID-Medline. Exclude: not stratified by primary/secondary LE or no LE. [pmid: 8078362].
Cesarone MR, Laurora G, De Sanctis MT, et al. Edema tester. Assessment of edema of the legs. Minerva Med. 1998;89(9):309-13. (Ital). OVID-Medline. Exclude: not stratified by primary/secondary lymphedema or no LE. [pmid: 9856119].
Cesarone MR, Belcaro G, Nicolaides AN, et al. The edema tester in the evaluation of swollen limbs in venous and lymphatic disease. Panminerva Med. 1999;41(1):10-4. OVID-Medline. Exclude: not stratified by primary/secondary LE or no LE. [pmid: 10230249].
Cestari SC, Petri V, Castiglioni ML, et al. Lymphedemas of the lower limbs: a lymphoscintigraphic study. Rev Assoc Med Bras. 1994;40(2):93-100. (Port). OVID-Medline. Exclude: not stratified by primary/secondary LE or no LE. [pmid: 7820157].
Chang TS, Gan JL, Fu KD, et al. The use of 5,6 benzo-[alpha]-pyrone (coumarin) and heating by microwaves in the treatment of chronic lymphedema of the legs. Lymphology. 1996;29(3):106-11. OVID-Medline. Exclude: No Control Group-Treatment. [pmid: 8897354].
Ciocon JO, Galindo-Ciocon D, Galindo DJ. Raised leg exercises for leg edema in the elderly. Angiology. 1995;46(1):19-25. OVID-Medline. Exclude: No Control Group-Treatment. [pmid: 7818153].
Cornish BH, Ward LC, Thomas BJ. Alteration to the extra-to intracellular fluid balance measured by multiple frequency bioelectric impedence analysis for the diagnosis of lymphoedema. Nutr Res. 1194;14:717-27. Exclude: exploratory study.
Cornish BH, Chapman M, Thomas BJ, et al. Early diagnosis of lymphedema in postsurgery breast cancer patients. Ann N Y Acad Sci. 2000;904:571-5. OVID-Medline. Exclude: Diagnostic Exploratory Study. [pmid: 10865807].
Cornish BH, Thomas BJ, Ward LC, et al. A new technique for the quantification of peripheral edema with application in both unilateral and bilateral cases. Angiology. 2002;53(1):41-7. OVID-Medline. Exclude: Diagnostic Exploratory Study. [pmid: 11863308].
Cuello V, Guerola S, Lopez R. Clinical and therapeutic profile of post-mastectomy lymphedema. Rehabilitacion. 2003;37(1):22-32. OVID-AMED. Exclude: no control.
Damstra RJ, Brouwer ER, Partsch H. Controlled, comparative study of relation between volume changes and interface pressure under short-stretch bandages in leg lymphedema patients. Dermatologic Surgery. 2008;34(6):773-8. OVID-Medline. Exclude: Primary/Secondary not stratified or patients did not have LE (treatment). [pmid: 18336577].
Dimakakos E, Koureas A, Koutoulidis V, et al. Interstitial magnetic resonance lymphography: is it a new method for the diagnosis of lymphedema?. Int Angiol. 2007;26(4):367-71. OVID-Medline. Exclude: Diagnostic Exploratory Study. [pmid: 18091705].
Dimakakos E, Koureas A, Koutoulidis V, et al. Interstitial magnetic resonance lymphography: the clinical effectiveness of a new method. Lymphology. 2008;41(3):116-25. OVID-Medline. Exclude: Primary/Secondary not stratified or patients did not have LE (diagnosis). [pmid: 19013879].
Dimakakos PB, Stefanopoulos T, Antoniades P, et al. MRI and ultrasonographic findings in the investigation of lymphedema and lipedema. Int Surg. 1997;82(4):411-6. OVID-Medline. Exclude: Primary/Secondary not stratified or patients did not have LE (diagnosis). [pmid: 9412843].
Drinan KJ, Wolfson PM, Steinitz D, et al. Duplex imaging in lymphedema. J Vasc Technol. 1993;17(1):23-6. OVID-Embase. Exclude: Diagnostic Exploratory Study.
Duman I, Ozdemir A, Tan AK, et al. The efficacy of manual lymphatic drainage therapy in the management of limb edema secondary to reflex sympathetic dystrophy. Rheumatol Int. 2009;29(7):759-63. OVID-Medline. Exclude: not effectiveness of LE. [pmid: 19030864].
Durand A, Thibaut G. Microcirculation variations during lymphedema. European Journal of Lymphology and Related Problems. 2003;10(37-38):12-4. OVID-Embase. Exclude: Primary/Secondary not stratified or patients did not have LE (diagnosis).
Ferrandez J-C, Bourassin A, Debeauquesne A, et al. Prospective study on an out-patient basis of the arm after breast cancer (with reference to 76 cases). Oncologie. 2005;7(4):316-22. (Fre). OVID-Embase. Exclude: no control.
Fiaschi E, Francesconi G, Fiumicelli S, et al. Manual lymphatic drainage for chronic post-mastectomy lymphoedema treatment. Panminerva Med. 1998;40(1):48-50. OVID-Medline. Exclude: No Control Group-Treatment. [pmid: 9573754].
Florez-Garcia MT, Valverde-Carrillo MD. Effectiveness of nonpharmacological interventions in the management of lymphedema postmastectomy. Rehabilitacion. 2007;41(3):126-34. (Span). EBSCO-CINAHL. Exclude: narrative, primary LE, editorial, conference etc.
Froldi M, Piana M, De Luca S, et al. Combined salty-bromoiodic hydromassage and intermittent pneumatic compression in the treatment of lower limbs lymphedema. Medicina Clinica e Termale. 2002;14(50-51):365-73. (Ital). OVID-Embase. Exclude: no control.
Garfein ES, Borud LJ, Warren AG, et al. Learning from a lymphedema clinic: an algorithm for the management of localized swelling. Plastic & Reconstructive Surgery. 2008;121(2):521-8. OVID-Medline. Exclude: Primary/Secondary not stratified or patients did not have LE (diagnosis). [pmid: 18300971].
Giraldi E, Dalla PF, Spreafico G, et al. Lymphoscintigraphy in the diagnosis of the lower extremities lymphedema. Acta Chir Ital. 1995;51(2):143-51. (Ital). OVID-Embase. Exclude: narrative, primary LE, editorial, conference etc.
Goffin V, Pierard-Franchimont C, Pierard GE. Dermometric evaluation of edema of the lower limbs. Rev Med Liege. 1993;48(12):681-5. (Fre). OVID-Medline. Exclude: narrative, primary LE, editorial, conference etc. [pmid: 8310202].
Gonzalez V, Condon H, Lecuona N, et al. Efectividad del tratamiento del linfedema de extremidad superior mediante presoterapia neumatica secuencial multicompartimental. Rehabilitacion. 1998;32(4):234-40. OVID-AMED. Exclude: no control.
Gothard L. Phase II Randomized Study of Hyperbaric Oxygen Therapy Versus Standard Management in Women With Chronic Arm Lymphedema After Radiotherapy for Early Breast Cancer. Physician Data Query (PDQ). 2004;2004(PDQ). OVID-CCTR. Exclude: Narrative, primary LE, editorial, conference etc.
Gozza A, Del Mastro L, Dini D, et al. Pneumatic compression vs control in postmastectomy lymphedema: A phase III randomized trial. Tumori. 1996;82(Suppl):91. OVID-CCTR. Exclude: Narrative, primary LE, editorial, conference etc.
Griffin JW, Newsome LS, Stralka SW, et al. Reduction of chronic posttraumatic hand edema: a comparison of high voltage pulsed current, intermittent pneumatic compression, and placebo treatments. Physical Therapy. 1990;70(5):279-86. OVID-Medline. Exclude: narrative, primary LE, editorial, conference etc. [pmid: 2185495].
Guthrie D, Gagnon G. The Prevention and Treatment of Postoperative Lymphedema of the Arm. Ann Surg. 1946;123(5):925-35. OVID-Medline In Process. Exclude: narrative, primary LE, editorial, conference etc. [pmid: 17858786].
Hamzeh MA, Lonsdale RJ, Pratt DJ, et al. A new device producing ambulatory intermittent pneumatic compression suitable for the treatment of lower limb oedema: a preliminary report. Journal of Medical Engineering & Technology. 1993;17(3):110-3. OVID-Medline. Exclude: narrative, primary LE, editorial, conference etc. [pmid: 8263904].
Harfouche JN, Theys S, Scavee V, et al. Venous calibre reduction after intermittent pneumatic compression. Phlebology. 2005;20(1):38-42. OVID-Embase. Exclude: Primary/Secondary not stratified or patients did not have LE (treatment).
Haslett ML, Aitken MJ. Evaluating the effectiveness of a compression sleeve in managing secondary lymphoedema. Journal of Wound Care. 2002;11(10):401-4. OVID-Medline. Exclude: Narrative, primary LE, editorial, conference etc. [pmid: 12494832].
Idy-Peretti I, Bittoun J, Alliot FA, et al. Lymphedematous skin and subcutis: in vivo high resolution magnetic resonance imaging evaluation. J Invest Dermatol. 1998;110(5):782-7. OVID-Medline. Exclude: Primary/Secondary not stratified or patients did not have LE (diagnosis). [pmid: 9579546].
Jamison LJ. Aquatic therapy for the patient with lymphedema. Journal of Aquatic Physical Therapy. 2005;13(1):9-12. EBSCO-CINAHL. Exclude: Not able to retrieve.
Janbon C, Ferrandez JC, Vinot JM, et al. A comparative lympho-scintigraphic evaluation of manual lymphatic drainage and pressotherapy in edema of the arm following treatment of a breast tumor. J Mal Vasc. 1990;15(3):287-8. (Fre). OVID-Medline. Exclude: not effectiveness of LE. [pmid: 2212876].
Jonsson C, Johansson K. Pole walking for patients with breast cancer-related arm lymphedema. Physiother Theory Pract. 2009;25(3):165-73. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010268915&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=945&accno=2010268915. EBSCO-CINAHL. Exclude: no control. [pmid: 19384736].
Kafejian-Haddad AP, Garcia AP, Mitev AG, et al. Lymphoscintigraphic evaluation of lower limb lymphedema. Correlation with clinical findings in 34 patients. Jornal Vascular Brasileiro. 2005;4(3):283-9. (Port). OVID-Embase. Excluded: narrative, primary LE, editorial, conference etc.
Karges JR, Mark BE, Stikeleather SJ, et al. Assessing the relationship between water displacement and circumferential measurements in determining upper extremity volume in women with lymphedema. Phys Ther. 1997;77:S109-S110. Exclude: not able to retrieve.
Karmazanovskii GG, Savchenko TV. Computed tomographic symptomatology of lymphedema of the lower extremities. Vestn Rentgenol Radiol. 1991;(6):42-50. (Rus). OVID-Medline. Exclude: not stratified by primary/secondary LE or no LE. [pmid: 1796542].
Kasseroller RG. Alginat-short stretch bandages as an alternative to regular lymphological compression bandages. Lymphologie in Forschung und Praxis. 2007;11(2):88-91. (Ger). OVID-Embase. Exclude: narrative, primary LE, editorial, conference etc.
Kataoka M, Kawamura M, Hamada K, et al. Quantitative lymphoscintigraphy using 99Tcm human serum albumin in patients with previously treated uterine cancer. Br J Radiol. 1991;64(768):1119-21. OVID-Medline. Exclude: Diagnostic Exploratory Study. [pmid: 1773271].
Kim W, Chung SG, Kim TW, et al. Measurement of soft tissue compliance with pressure using ultrasonography. Lymphology. 2008;41(4):167-77. OVID-Medline. Exclude: not stratified by primary/secondary LE or no secondary LE. [pmid: 19306663].
King TI, Droessler JL. Physical properties of short-stretch compression bandages used to treat lymphedema. American Journal of Occupational Therapy. 2001;55(5):573-6. OVID-Medline. Exclude: Narrative, primary LE, editorial, conference etc. [pmid: 14601819].
Kniazeva TA, Minenkov AA, Kul’chitskaia DB, et al. Effect of physiotherapy on the microcirculation in patients with lymphedema of lower extremities. Vopr Kurortol Fizioter Lech Fiz Kult. 2003;(1):30-2. (Rus). OVID-Medline. Exclude: not stratified by primary/secondary LE or no LE. [pmid: 12698704].
Koshima I, Inagawa K, Etoh K, et al. Supramicrosurgical lymphaticovenular anastomosis for the treatment of lymphedema in the extremities. Nippon Geka Gakkai Zasshi. 1999;100(9):551-6. (Jap). OVID-Medline. Exclude: narrative, primary LE, editorial, conference etc. [pmid: 10516971].
Larcos G, Foster DR. Interpretation of lymphoscintigrams in suspected lymphoedema: contribution of delayed images. Nucl Med Commun. 1995;16(8):683-6. OVID-Medline. Exclude: Primary/Secondary not stratified or patients did not have LE (diagnosis). [pmid: 7491181].
Lefevre F. Special report: comparative efficacy of different types of pneumatic compression pumps for the treatment of lymphedema. BlueCross and BlueShield Technology Evaluation Center (TEC) Assessment. 1998;13(2):42-3. OVID-Medline. Exclude: Narrative, primary LE, editorial, conference etc. [pmid: 10183361].
Letellier M, Towers A, Cohen R. Aqualymphatic exercise as an alternative therapy for lympedema management following breast cancer: a randomized controlled pilot study…. 17th International Congress on Palliative Care. September 23-26, 2008. Palais Des Congres, Montreal, Canada. Journal of Palliative Care. 2008;24(3):215. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010064750&site=ehost-live;Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=549&accno=2010064750. EBSCO-CINAHL. Exclude: narrative, primary LE, editorial, conference etc.
Lette J. A simple and innovative device to measure arm volume at home for patients with lymphedema after breast cancer. Journal of Clinical Oncology. 2006;24(34):5434-40. OVID-Medline. Exclude: Primary/Secondary not stratified or patients did not have LE (diagnosis). [pmid: 17135645].
Li W-M, Chen W-A, Rao G-H, et al. Diagnostic value of radionuclide lymphoscintigraphy in extremity lymphedema. Chinese Journal of Medical Imaging Technology. 2008;24(9):1462-4. (Chin). OVID-Embase. Exclude: not stratified by primary/secondary LE or no LE.
Li X-J, Wang L. Radioisotope scanning evaluation on the improvement of post-mastectomy upper extremity lymphedema in breast cancer patients following compression therapy. Journal of Clinical Rehabilitative Tissue Engineering Research. 2007;11(22):4329-32. (Chin). OVID-Embase. Exclude: No control group.
Liu N, Wang C, Sun M. Noncontrast three-dimensional magnetic resonance imaging vs lymphoscintigraphy in the evaluation of lymph circulation disorders: A comparative study. J Vasc Surg. 2005;41(1):69-75. OVID-Medline. Exclude: not stratified by primary/secondary LE or no LE (diagnosis). [pmid: 15696047].
Lohrmann C, Kautz O, Speck O, et al. Chronic lymphedema: Detected with high-resolution magnetic resonance lymphangiography. J Comput Assist Tomogr. 2006;30(4):688. OVID-Medline. Exclude: Narrative, primary LE, editorial, conference etc. [pmid: 16845303].
Marotel M, Cluzan R, Pascot M, et al. CT staging in 150 cases of lower limb lymphedema. J Radiol. 1998;79(11):1373-8. (Fre). OVID-Embase. Exclude: exploratory study. [pmid: 9846290].
Marshall M, Schwahn-Schreiber C. Lymphedema, lipedema and venous edema. Differential diagnostic clarification using high-resolution duplex sonography. Gefasschirurgie. 2008;13(3):204-12. (Ger). OVID-Embase. Exclude: narrative, primary LE, editorial, conference etc.
Matthews KL, Smith JG. Effectiveness of modified complex physical therapy for lymphoedema treatment. Australian Journal of Physiotherapy. 1996;42(4):323-8. OVID-Embase. Exclude: Primary/Secondary not stratified or patients did not have LE (treatment). [pmid: 11676665].
Mayrovitz HN, Sims N, Litwin B, et al. Foot volume estimates based on a geometric algorithm in comparison to water displacement. Lymphology. 2005;38(1):20-7. OVID-Medline. Exclude: Primary/Secondary not stratified or patients did not have LE (diagnosis). [pmid: 15856683].
Mayrovitz HN, Sims N, Brown-Cross D, et al. Transcutaneous oxygen tension in arms of women with unilateral postmastectomy lymphedema. Lymphology. 2005;38(2):81-6. OVID-Medline. Exclude: No Control Group-Treatment. [pmid: 16184817].
Mayrovitz HN, Sims N, Hill CJ, et al. Hand volume estimates based on a geometric algorithm in comparison to water displacement. Lymphology. 2006;39(2):95-103. OVID-Medline. Exclude: Primary/Secondary not stratified or patients did not have LE (diagnosis). [pmid: 16910100].
Mayrovitz HN. Assessing local tissue edema in postmastectomy lymphedema. Lymphology. 2007;40(2):87-94. OVID-Medline. Exclude: Diagnostic Exploratory Study. [pmid: 17853619].
Mayrovitz HN, Weingrad DN, Davey S. Local tissue water in at-risk and contralateral forearms of women with and without breast cancer treatment-related lymphedema. Lymphatic Research & Biology. 2009;7(3):153-8. OVID-Medline. Exclude: not stratified by primary/secondary LE or no secondary LE. [pmid: 19778203].
McLaughlin SA, Van Zee KJ. Lymphedema 5 years after SLNB or ALND for breast cancer: objective measurements, patient perceptions, and precautionary behaviors. American Journal of Hematology/Oncology. 2009;8(6):303-6. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010330882&site=ehost-live; Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=3258&accno=2010330882. EBSCO-CINAHL. Exclude: incidence/prevalence of secondary LE.
McNeely ML, Campbell KL, Courneya KS, et al. Effect of acute exercise on upper-limb volume in breast cancer survivors: a pilot study. Physiotherapy Canada. 2009;61(4):244-51. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010473067&site=ehost-live; Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=311&accno=2010473067. EBSCO-CINAHL. Exclude: no control. [pmid: 20808486].
Miasnikova MO, Sedov VM, Katsev VM, et al. Lymphoscintigraphy in the diagnosis and prognosis of post-mastectomy edema of the extremities. Vopr Onkol. 2003;49(1):85-7. (Rus). OVID-Medline. Exclude: exploratory study. [pmid: 12715377].
Mondry TE, Johnstone PA. Manual lymphatic drainage for lymphedema limited to the breast. J Surg Oncol. 2002;81(2):101-4. OVID-Medline. Exclude: Narrative, primary LE, editorial, conference etc. [pmid: 12355412].
Monnin-Delhom ED, Gallix BP, Achard C, et al. High resolution unenhanced computed tomography in patients with swollen legs. Lymphology. 2002;35(3):121-8. OVID-Medline. Exclude: Primary/Secondary not stratified or patients did not have LE (diagnosis). [pmid: 12363222].
Moretti B, Lanzisera R, Moretti L, et al. Manual lymph drainage of post-mastectomy “big arm”. G Ital Med Lav Ergon. 2005;27(2):160-4. (Ital). OVID-Medline. Exclude: no control. [pmid: 16124524].
Nesvold IL, Fossa SD, Naume B, et al. Kwan’s arm problem scale: psychometric examination in a sample of stage II breast cancer survivors. Breast Cancer Research & Treatment. 2009;117(2):281-8. OVID-Medline. Exclude: not stratified by primary/secondary LE or no secondary LE (diagnosis). [pmid: 19112616].
O’Neill J, Beatus J. The effects of complete decongestive physical therapy treatment on edema reduction, quality of life, and functional ability of persons with upper extremity lymphedema. Journal of Women’s Health Physical Therapy. 2006;30(1):5-10. Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=3031&accno=2009174609;http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2009174609&site=ehost-live. EBSCO-CINAHL. Exclude: No Control Group-Treatment.
O’Toole J, Russell T, Specht M, et al. Prospective evaluation of arm volume in breast cancer patients: determining a threshold for intervention. Rehabilitation Oncology. 2009;27(1):25-6. http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2010324841&site=ehost-live. EBSCO-CINAHL. Exclude: not able to retrieve.
Ogawa Y, Hayashi K. 99mTc-DTPA-HSA lymphoscintigraphy in lymphedema of the lower extremities: diagnostic significance of dynamic study and muscular exercise. Kaku Igaku - Japanese Journal of Nuclear Medicine. 1999;36(1):31-6. (Jap). OVID-Medline. Exclude: not able to retrieve. [pmid: 10087763].
Ohkuma M. Lymphedema treated by microwave and elastic dressing. Int J Dermatol. 1992;31(9):660-3. OVID-Medline. Exclude: Primary/Secondary not stratified or patients did not have LE (treatment). [pmid: 1459769].
Oliel VS, Holt M. Lymfodembehandling - det fysioterapeutiske aspekt. Danske Fysioter. 1999;22:26-4. OVID-AMED. Exclude: not able to retrieve.
Orhan J, Levavasseur O. Pneumatic pressure therapy of lymphedema in the lower limbs. Phlebologie. 250. 43(2):243-50. (Fre). OVID-Medline. Exclude: narrative, primary LE, editorial, conference etc. [pmid: 2236234].
Pantiushenko TA, Bel’tran M. The classification of postmastectomy edema of the upper extremity by a volumetric method. Vopr Onkol. 1990;36(6):714-7. (Rus). OVID-Medline. Exclude: exploratory study. [pmid: 2378092].
Pecking AP, Alberini JL, Wartski M, et al. Relationship between lymphoscintigraphy and clinical findings in lower limb lymphedema (LO): toward a comprehensive staging. Lymphology. 2008;41(1):1-10. OVID-Medline. Exclude: Primary/Secondary not stratified or patients did not have LE (diagnosis). [pmid: 18581953].
Petlund CF, Aas M. Lymphedema and lymphangioscintigraphy. Tidsskr Nor Laegeforen. 2000;120(19):2279-82. (Nor). OVID-Medline. Exclude: not stratified by primary/secondary LE or no LE. [pmid: 10997088].
Piller NB, Swdborg I, Wilking N, et al. Short-term manual lymph drainage treatment and maintenance therapy for post-mastectomy lymphoedema. Lymphology. 1994;27(suppl):589-92. Exclude: no control group.
Piller NB, Thelander A. Low level laser therapy: A cost effective treatment to reduce post mastectomy lymphoedema. Lymphology. 1996;29(suppl 1):297-300. Exclude: no control group.
Pohjola RT, Pekanmaki K, Kolari PJ. Intermittent pneumatic compression of lymphoedema: Evaluation of two clinical methods. Eur J Lymphology Relat Probl. 1995;5(19):87-90. OVID-Embase. Exclude: Not stratified by primary/secondary LE or no LE (treatment).
Preisler VK, Hagen R, Hoppe F. Pros and cons of the manual lymphdrainage treatment for secondary lymphedema of the head and neck. Laryngorhinootologie. 1998;77(4):207-12. (Ger). OVID-Embase. Exclude: not effectiveness of LE treatment. [pmid: 9592754].
Proby CM, Gane JN, Joseph AE, et al. Investigation of the swollen limb with isotope lymphography. Br J Dermatol. 1990;123(1):29-37. OVID-Medline. Exclude: Diagnostic exploratory study. [pmid: 2390494].
Richards TB, McBiles M, Collins PS. An easy method for diagnosis of lymphedema. Ann Vasc Surg. 1990;4(3):255-9. OVID-Medline. Exclude: Diagnostic exploratory study. [pmid: 2340247].
Rijke AM, Croft BY, Johnson RA, et al. Lymphoscintigraphy and lymphedema of the lower extremities. J Nucl Med. 1990;31(6):990-8. OVID-Medline. Exclude: Primary/Secondary not stratified or patients did not have LE (diagnosis). [pmid: 2348245].
Rudat CH. Die Lymphe - die reinigende Flussigkeit unseres Korpers. Natur und Heilen. 1999;76(9):548-52. (Ger.). OVID-AMED. Exclude: narrative review.
Sagen A, Karesen R, Risberg MA. The reliability of a simplified water displacement instrument: a method for measuring arm volume. Archives of Physical Medicine & Rehabilitation. 2005;86(1):86-9. Publisher URL: www.cinahl.com/cgi-bin/refsvc?jid=123&accno=2005084545; http://search.ebscohost.com/login.aspx?direct=true&db=cin20&AN=2005084545&site=ehost-live. EBSCO-CINAHL. Exclude: not stratified by primary/secondary LE or no LE. [pmid: 15640996].
Sander AP, Hajer NM, Hemenway K, et al. Upper-extremity volume measurements in women with lymphedema: a comparison of measurements obtained via water displacement with geometrically determined volume. Physical Therapy. 2002;82(12):1201-12. OVID-Medline. Exclude: Primary/Secondary not stratified or patients did not have LE (diagnosis). [pmid: 12444879].
Sawan S, Mugnai R, Lopes AB, et al. Lower-limb lymphedema and vulval cancer: feasibility of prophylactic compression garments and validation of leg volume measurement. International Journal of Gynecological Cancer. 2009;19(9):1649-54. OVID-Medline In Process. Exclude: prevention. [pmid: 19955953].
Schmitz KH, Troxel AB, Cheville A, et al. Physical activity and lymphedema (the PAL trial): Assessing the safety of progressive strength training in breast cancer survivors. Contemporary Clinical Trials. 2009;30(3):233-45. OVID-Embase. Exclude: companion to 15036. [pmid: 19171204].
Seifart U, Albert US, Heim ME, et al. Lymphedema in patients with breast cancer--a consensus regarding diagnostics and therapy in patients with postoperative lymphedema after primary breast cancer. Rehabilitation (Stuttg). 2007;46(6):340-8. (Ger). OVID-Medline. Exclude: narrative, primary LE, editorial, conference etc. [pmid: 18188805].
Sitzia J, Sobrido L. Measurement of health-related quality of life of patients receiving conservative treatment for limb lymphoedema using the Nottingham Health Profile. Qual Life Res. 1997;6(5):373-84. OVID-Medline. Exclude: No Control Group-Treatment. [pmid: 9290304].
Smirnov AS, Bubnova NA, Blokhina MV, et al. The sanatorium-health resort treatment of patients with lymphedema of the legs. Vopr Kurortol Fizioter Lech Fiz Kult. 1992;(1):38-40. (Rus). OVID-Medline. Exclude: not stratified by primary/secondary LE or no LE. [pmid: 1533476].
Stoberl C, Partsch H, Wruhs M. Diagnostic value and criteria for evaluating indirect lymphography in lymphedema. Vasa. 1990;19(3):212-7. (Ger). OVID-Medline. Exclude: not stratified by primary/secondary LE or no LE. [pmid: 2238815].
Stoberl C. Indirect lymphography--possibilities and limits of roentgen diagnosis of the lymphatic system. Wien Med Wochenschr. 1999;149(2-4):92-4. (Ger). OVID-Medline. Exclude: narrative, primary LE, editorial, conference etc. [pmid: 10378334].
Suga K, Kume N, Matsunaga N, et al. Assessment of leg oedema by dynamic lymphoscintigraphy with intradermal injection of technetium-99m human serum albumin and load produced by standing. Eur J Nucl Med. 2001;28(3):294-303. OVID-Medline. Exclude: Diagnostic Exploratory Study. [pmid: 11315596].
Szolnoky G, Lakatos B, Keskeny T. Advantage of combined decongestive lymphatic therapy over manual lymph drainage: A pilot study. Lymphology. 2002;35(Suppl 1):277-82. Exclude: Narrative, primary LE, editorial, conference etc.
Szuba A. Literature watch. The addition of manual lymph drainage to compression therapy for breast cancer related lymphedema: a randomized controlled trial. Lymphatic Research & Biology. 2005;3(1):36-41. OVID-Medline. Exclude: Narrative, primary LE, editorial, conference etc. [pmid: 15770084].
Ter SE, Alavi A, Kim CK, et al. Lymphoscintigraphy. A reliable test for the diagnosis of lymphedema. Clin Nucl Med. 1993;18(8):646-54. OVID-Medline. Exclude: not stratified by primary/secondary LE or no LE. [pmid: 8403693].
Tidhar D, Drouin J, Shimony A. Aqua lymphatic therapy in managing lower extremity lymphedema. J Support Oncol. 2007;5(4):179-83. OVID-Medline. Exclude: Narrative, primary LE, editorial, conference etc. [pmid: 17500505].
Tsai HJ, Liu YX, Tsauo JY. Reliability study of lymphadema measurement. Formosan Journal of Physical Therapy. 2005;30:124-31. Exclude: not able to retrieve.
Unno N, Inuzuka K, Suzuki M, et al. Preliminary experience with a novel fluorescence lymphography using indocyanine green in patients with secondary lymphedema. J Vasc Surg. 2007;45(5):1016-21. OVID-Medline. Exclude: Diagnostic Exploratory Study. [pmid: 17391894].
Val Gomez MM, Llaneza FP. Isotopic lymphography in the lymphedema of inferior extremities. Rev Esp Med Nucl. 1991;10(2):41-5. (Span). OVID-Embase. Exclude: narrative, primary LE, editorial, conference etc.
Venturini M, Forno G, Bertelli G, et al. Compression therapy in postmastectomy lymphedema (PML): results of our phase II-III studies and future research lines. Breast Cancer Research & Treatment. 1990;16(2):188. OVID-CCTR. Exclude: Narrative, primary LE, editorial, conference etc.
Venturini M, Dini D, Forno G, et al. Electrically stimulated drainage (ESD) versus control: a randomized study of treatment for mild post mastectomy lymphedema (PML). Journal of Cancer Research & Clinical Oncology. 1990;116(Suppl):55. OVID-CCTR. Exclude: Narrative, primary LE, editorial, conference etc.
Verlooy H, Biscompte JP, Nieuborg L, et al. Noninvasive evaluation of lympho-venous anastomosis in upper limb lymphedema. Value of quantitative lymphoscintigraphic examinations. Eur J Lymphology Relat Probl. 1997;6(21):27-33. OVID-Embase. Exclude: exploratory study.
Ward LC, Czerniec S, Kilbreath SL. Quantitative bioimpedance spectroscopy for the assessment of lymphoedema. Breast Cancer Research & Treatment. 2009;117(3):541-7. OVID-Medline. Exclude: not stratified by primary/secondary LE or no secondary LE (diagnosis). [pmid: 19082708].
Warren AG, Janz BA, Slavin SA, et al. The use of bioimpedance analysis to evaluate lymphedema. Ann Plast Surg. 2007;58(5):541-3. OVID-Medline. Exclude: not stratified by primary/secondary LE or no LE (diagnosis). [pmid: 17452840].
Watanabe K, Noikura T, Yamashita S, et al. Phase III trial of 99mTc-rhenium Colloid for lymphoscintigraphy. Kakuigaku. 1992;29(8):979-90. (Jap). OVID-Embase. Exclude: not able to retrieve.
Wheatley DC, Wastie ML, Whitaker SC, et al. Lymphoscintigraphy and colour Doppler sonography in the assessment of leg oedema of unknown cause. Br J Radiol. 1996;69(828):1117-24. OVID-Medline. Exclude: Diagnostic Exploratory Study. [pmid: 9135466].
Wienert V, Gerlach H, Gallenkemper G, et al. Medical compression stocking (MCS). JDDG - Journal of the German Society of Dermatology. 2008;6(5):410-5. (Ger). OVID-Embase. Exclude: Narrative, primary LE, editorial, conference etc.
Woods M. An audit of swollen limb measurements. Nursing Standard. 1994;9(5):24-6. EBSCO-CINAHL. Exclude: Not able to retrieve. [pmid: 7999565].
Yuan Z, Chen L, Luo Q, et al. The role of radionuclide lymphoscintigraphy in extremity lymphedema. Ann Nucl Med. 2006;20(5):341-4. OVID-Medline. Exclude: Primary/Secondary not stratified or patients did not have LE (diagnosis). [pmid: 16878705].