# Data Extraction Forms

Full Text Screening Questions

DATA ABSTRACTION FORM FOR DIAGNOSTIC STUDIES

DATA ABSTRACTION FORM FOR TREATMENT STUDIES

QUALITY SCORE FOR JADAD SCALE AND FOR MODIFIED JADAD SCALE

Newcastle-Ottawa Scale (NOS)

QUADAS – Quality Assessment Tool for Diagnosis papers

QUADAS – Quality Assessment Tool for Reliability Diagnosis papers

QUADAS – Quality Assessment Tool for Validity Diagnosis papers