# Abbreviations

Adj: adjusted for cardiovascular risk factors, including lipids and/or triglycerides
AHRQ: Agency for Healthcare Research and Quality
ApoB: apoprotein B
Assns: associations
ATP III: Adult Treatment Panel III (3^rd^ report of the National Cholesterol Education Program Expert Panel)
AUC: area under the curve
BMI: body mass index
CABG: coronary artery bypass graft
CAC: coronary artery calcification
CAD: coronary artery disease
CC: case control studies
CDC: Centers for Disease Control and Prevention
CerebroVD: cerebrovascular disease
CHD: coronary heart disease
CI: confidence interval
CITP: capillary isotachophoretic method
CK: creatine kinase
CLIA: Clinical Laboratory Improvement Act
CMS: Centers for Medicare and Medicaid Services
hsCRP: high sensitivity C reactive protein
CV: coefficient of variation
CVD: cardiovascular heart disease
DBP: diastolic blood pressure
DGUC: density gradient ultracentrifugation
DM: diabetes mellitus
ECG: electrocardiogram
EPC: Evidence-based Practice Center
ESRD: end stage renal disease
FH: familial (hereditary) hypercholesterolemia (homozygous or heterozygous)
FHx: family history
FPG: fasting plasma glucose
Fram Sc: Framingham score
GE: gel electrophoresis
HDL: high density lipoprotein
HDL-c: HDL cholesterol
HPLC: high performance gel filtration (liquid) chromatography
HTN: hypertension
IMT: intima-media thickness
Inter: intermediate
JNC 7: The 7^th^ Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure
LDL: low density lipoprotein
LDL-c: LDL cholesterol
LDLSF score: LDL subfraction score
LOA: Bland-and-Altman limits of agreement
MI: myocardial infarction
MLD: minimum lumen diameter (coronary arteries)
MRI: magnetic resonance imaging
N: sample size
nCC: nested case control studies
nd: no data
NMR: nuclear magnetic resonance
No.: number
OR: odds ratio
P btw: P value for difference between treatment and control
P Cohort: prospective cohort (cross-sectional) studies
P Long: prospective longitudinal studies
PTCA: percutaneous transluminal coronary angioplasty
py: pack-year
r: correlation coefficient
RCT: randomized controlled trial
Ref Std: reference standard
Rf: ratio of distance moved by band relative to marker
RR: relative risk
SBP: systolic blood pressure
SD: standard deviation
sd LDL: small dense LDL
TC: total cholesterol
Tg: triglycerides
TIA: transient ischemic attacks
UC: ultracentrifugation
UI: Medline unique identifier
Unadj: unadjusted for lipids and/or triglycerides
VAP: Vertical Auto Profile
WHO: World Health Organization
XS: cross-sectional