# References

1 American Heart Association. Heart Disease and Stroke Statistics. 2008 Update At-a-glance. 2008. www.americanheart.org/downloadable/heart/1200078608862HS_Stats%202008.final.pdf.
2 Expert Panel on Detection Evaluation and Treatment of High Blood Cholesterol in Adults. Executive Summary of The Third Report of The National Cholesterol Education Program (NCEP) Expert Panel on Detection, Evaluation, And Treatment of High Blood Cholesterol In Adults (Adult Treatment Panel III). JAMA. 2001;285:2486-2497. [pmid: 11368702].
3 Grundy SM. United States Cholesterol Guidelines 2001: expanded scope of intensive low-density lipoprotein-lowering therapy. American Journal of Cardiology. 2001;88:23J-27J. [pmid: 11423053].
4 Blumenthal RS, Michos ED, Nasir K. Further improvements in CHD risk prediction for women. JAMA. 2007;297:641-643. [pmid: 17299201].
5 Ridker PM, Buring JE, Rifai N, Cook NR. Development and validation of improved algorithms for the assessment of global cardiovascular risk in women: the Reynolds Risk Score. JAMA. 2007;297:611-619. [pmid: 17299196].
6 Wang TJ, Gona P, Larson MG, et al. Multiple biomarkers for the prediction of first major cardiovascular events and death. New England Journal of Medicine. 2006;355:2631-2639. [pmid: 17182988].
7 Ware JH. The limitations of risk factors as prognostic tools. New England Journal of Medicine. 2006;355:2615-2617. [pmid: 17182986].
8 Krauss RM. Dense low density lipoproteins and coronary artery disease. American Journal of Cardiology. 1995;75:53B-57B. [pmid: 7801864].
9 Krauss RM. Dietary and genetic effects on low-density lipoprotein heterogeneity. Annual Review of Nutrition. 2001;21:283-295.
10 Chapman MJ, Guerin M, Bruckert E. Atherogenic, dense low-density lipoproteins. Pathophysiology and new therapeutic approaches. European Heart Journal. 1998;19. Suppl-30.
11 Sacks FM, Campos H. Clinical review 163: Cardiovascular endocrinology: Low-density lipoprotein size and cardiovascular disease: a reappraisal. Journal of Clinical Endocrinology & Metabolism. 2003;88:4525-4532. [pmid: 14557416].
12 Brunzell JD, Davidson M, Furberg CD, et al. Lipoprotein management in patients with cardiometabolic risk: consensus statement from the American Diabetes Association and the American College of Cardiology Foundation. Diabetes Care. 2008;31:811-822. [pmid: 18375431].
13 Chobanian AV, Bakris GL, Black HR, et al. The Seventh Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure: the JNC 7 report. JAMA. 2003;289:2560-2572. [pmid: 12748199].
14 Shahrul BS, Faridah AR. Simplified gradient gel electrophoresis for quantification of low-density lipoprotein subclass. Clin Chim Acta. 2003;336:145-147. [pmid: 14500048].
15 Hirany SV, Othman Y, Kutscher P, Rainwater DL, Jialal I, Devaraj S. Comparison of low-density lipoprotein size by polyacrylamide tube gel electrophoresis and polyacrylamide gradient gel electrophoresis. American Journal of Clinical Pathology. 2003;119:439-445. [pmid: 12669713].
16 Austin MA, Hokanson JE, Brunzell JD. Characterization of low-density lipoprotein subclasses: methodologic approaches and clinical relevance. [Review] [65 refs]. Current Opinion in Lipidology. 1994;5:395-403. [pmid: 7712044].
17 Ensign W, Hill N, Heward CB. Disparate LDL phenotypic classification among 4 different methods assessing LDL particle characteristics. Clinical Chemistry. 2006;52:1722-1727. [pmid: 16740651].
18 Clendenen, Faith Oakland CA US Boggess Christopher Cambridge MA US Ruderman Frank San Rafael CA US. Method for quantitatively determining the LDL particle number in a distribution of LDL cholesterol subfractions. http://www.freepatentsonline.com/20070072302.html . 2007. Berkeley HeartLab, Inc. 6-16-2008.
19 Jeyarajah EJ, Cromwell WC, Otvos JD. Lipoprotein particle analysis by nuclear magnetic resonance spectroscopy. Clinics in Laboratory Medicine. 2006;26:847-870. [pmid: 17110242].
20 Scheffer PG, Bakker SJ, Heine RJ, Teerlink T. Measurement of low-density lipoprotein particle size by high-performance gel-filtration chromatography. Clinical Chemistry. 1997;43:1904-1912. [pmid: 9342011].
21 Scheffer PG, Bakker SJ, Heine RJ, Teerlink T. Measurement of LDL particle size in whole plasma and serum by high performance gel-filtration chromatography using a fluorescent lipid probe. Clinical Chemistry. 1998;44:2148-2151. [pmid: 9761248].
22 Otvos JD, Jeyarajah EJ, Cromwell WC. Measurement issues related to lipoprotein heterogeneity. American Journal of Cardiology. 2002;90:22i-29i.
23 Hirano T, Ito Y, Yoshino G. Measurement of small dense low-density lipoprotein particles. Journal of Atherosclerosis & Thrombosis. 2005;12:67-72. [pmid: 15942115].
24 Rizzo M, Berneis K. Low-density lipoprotein size and cardiovascular risk assessment. Qjm. 2006;99:1-14. [pmid: 16371404].
25 Stein EA. Are measurements of LDL particles ready for prime time?. Clinical Chemistry. 2006;52:1643-1644. [pmid: 16940463].
26 Bland JM, Altman DG. Statistical methods for assessing agreement between two methods of clinical measurement. Lancet. 1986;1:307-310. [pmid: 2868172].
27 Blake GJ, Otvos JD, Rifai N, Ridker PM. Low-density lipoprotein particle concentration and size as determined by nuclear magnetic resonance spectroscopy as predictors of cardiovascular disease in women. Circulation. 2002;106:1930-1937. [pmid: 12370215].
28 Davies IG, Graham JM, Griffin BA. Rapid separation of LDL subclasses by iodixanol gradient ultracentrifugation. Clinical Chemistry. 2003;49:1865-1872. [pmid: 14578318].
29 Dormans TP, Swinkels DW, de GJ, Hendriks JC, Stalenhoef AF, Demacker PN. Single-spin density-gradient ultracentrifugation vs gradient gel electrophoresis: two methods for detecting low-density-lipoprotein heterogeneity compared. Clinical Chemistry. 1991;37:853-858. [pmid: 2049850].
30 Hoefner DM, Hodel SD, O'Brien JF, et al. Development of a rapid, quantitative method for LDL subfractionation with use of the Quantimetrix Lipoprint LDL System. Clinical Chemistry. 2001;47:266-274. [pmid: 11159775].
31 Witte DR, Taskinen MR, Perttunen-Nio H, van TA, Livingstone S, Colhoun HM. Study of agreement between LDL size as measured by nuclear magnetic resonance and gradient gel electrophoresis. Journal of Lipid Research. 2004;45:1069-1076. [pmid: 14993238].
32 O'Neal D, Harrip P, Dragicevic G, Rae D, Best JD. A comparison of LDL size determination using gradient gel electrophoresis and light-scattering methods. Journal of Lipid Research. 1998;39:2086-2090. [pmid: 9788255].
33 Adler L, Hill JS, Frohlich J. Chemical precipitation of apolipoprotein B-containing lipoproteins facilitates determination of LDL particle size. Clinical Biochemistry. 2000;33:187-190. [pmid: 10913516].
34 Barzilai N, Atzmon G, Schechter C, et al. Unique lipoprotein phenotype and genotype associated with exceptional longevity. JAMA. 2003;290:2030-2040. [pmid: 14559957].
35 El Harchaoui K, van der Steeg WA, Stroes ES, et al. Value of low-density lipoprotein particle number and size as predictors of coronary artery disease in apparently healthy men and women: the EPIC-Norfolk Prospective Population Study. Journal of the American College of Cardiology. 2007;49:547-553. [pmid: 17276177].
36 Freedman DS, Otvos JD, Jeyarajah EJ, Barboriak JJ, Anderson AJ, Walker JA. Relation of lipoprotein subclasses as measured by proton nuclear magnetic resonance spectroscopy to coronary artery disease. Arteriosclerosis, Thrombosis & Vascular Biology. 1998;18:1046-1053.
37 Kuller L, Arnold A, Tracy R, et al. Nuclear magnetic resonance spectroscopy of lipoproteins and risk of coronary heart disease in the cardiovascular health study. Arteriosclerosis, Thrombosis & Vascular Biology. 2002;22:1175-1180.
38 Mackey RH, Kuller LH, Sutton-Tyrrell K, Evans RW, Holubkov R, Matthews KA. Lipoprotein subclasses and coronary artery calcium in postmenopausal women from the healthy women study. American Journal of Cardiology. 2002;90:71i-76i.
39 Mora S, Szklo M, Otvos JD, et al. LDL particle subclasses, LDL particle size, and carotid atherosclerosis in the Multi-Ethnic Study of Atherosclerosis (MESA). Atherosclerosis. 2007;192:211-217. [pmid: 16765964].
40 Otvos JD, Collins D, Freedman DS, et al. Low-density lipoprotein and high-density lipoprotein particle subclasses predict coronary events and are favorably changed by gemfibrozil therapy in the Veterans Affairs High-Density Lipoprotein Intervention Trial. Circulation. 2006;113:1556-1563. [pmid: 16534013].
41 Rosenson RS, Otvos JD, Freedman DS. Relations of lipoprotein subclass levels and low-density lipoprotein size to progression of coronary artery disease in the Pravastatin Limitation of Atherosclerosis in the Coronary Arteries (PLAC-I) trial. American Journal of Cardiology. 2002;90:89-94. [pmid: 12106834].
42 Soedamah-Muthu SS, Chang YF, Otvos J, Evans RW, Orchard TJ. Pittsburgh Epidemiology of Diabetes Complications Study. Lipoprotein subclass measurements by nuclear magnetic resonance spectroscopy improve the prediction of coronary artery disease in Type 1 diabetes. A prospective report from the Pittsburgh Epidemiology of Diabetes Complications Study. Diabetologia. 2003;46:674-682. [pmid: 12743701].
43 Inukai T, Yamamoto R, Suetsugu M, et al. Small low-density lipoprotein and small low-density lipoprotein/total low-density lipoprotein are closely associated with intima-media thickness of the carotid artery in Type 2 diabetic patients. Journal of Diabetes & its Complications. 2005;19:269-275. [pmid: 16112502].
44 Kullo IJ, Bailey KR, McConnell JP, et al. Low-density lipoprotein particle size and coronary atherosclerosis in subjects belonging to hypertensive sibships. American Journal of Hypertension. 2004;17:845-851. [pmid: 15363830].
45 Kwon SW, Yoon SJ, Kang TS, et al. Significance of small dense low-density lipoprotein as a risk factor for coronary artery disease and acute coronary syndrome. Yonsei Medical Journal. 2006;47:405-414. [pmid: 16807992].
46 Landray MJ, Sagar G, Muskin J, Murray S, Holder RL, Lip GY. Association of atherogenic low-density lipoprotein subfractions with carotid atherosclerosis. Qjm. 1998;91:345-351. [pmid: 9709468].
47 Mohan V, Deepa R, Velmurugan K, Gokulakrishnan K. Association of small dense LDL with coronary artery disease and diabetes in urban Asian Indians - the Chennai Urban Rural Epidemiology Study (CURES-8). Journal of the Association of Physicians of India. 2005;53:95-100. [pmid: 15847025].
48 Park JS, Park J, Kim CS, et al. Relationship of low-density lipoprotein particle size to insulin resistance and intima-media thickness in nondiabetic Koreans. Metabolism: Clinical & Experimental. 2006;55:1610-1615. [pmid: 17142132].
49 Rajman I, Kendall MJ, Cramb R, Holder RL, Salih M, Gammage MD. Investigation of low density lipoprotein subfractions as a coronary risk factor in normotriglyceridaemic men. Atherosclerosis. 1996;125:231-242. [pmid: 8842354].
50 Yoon Y, Song J, Park HD, Park KU, Kim JQ. Significance of small dense low-density lipoproteins as coronary risk factor in diabetic and non-diabetic Korean populations. Clinical Chemistry & Laboratory Medicine. 2005;43:431-437. [pmid: 15899660].
51 Williams PT, Superko HR, Haskell WL, et al. Smallest LDL particles are most strongly related to coronary disease progression in men. Arteriosclerosis, Thrombosis & Vascular Biology. 2003;23:314-321.
52 Austin MA, Rodriguez BL, McKnight B, et al. Low-density lipoprotein particle size, triglycerides, and high-density lipoprotein cholesterol as risk factors for coronary heart disease in older Japanese-American men. American Journal of Cardiology. 2000;86:412-416. [pmid: 10946034].
53 Campos H, Moye LA, Glasser SP, Stampfer MJ, Sacks FM. Low-density lipoprotein size, pravastatin treatment, and coronary events. JAMA. 2001;286:1468-1474. [pmid: 11572739].
54 Gardner CD, Fortmann SP, Krauss RM. Association of small low-density lipoprotein particles with the incidence of coronary artery disease in men and women. JAMA. 1996;276:875-881. [pmid: 8782636].
55 Mykkanen L, Kuusisto J, Haffner SM, Laakso M, Austin MA. LDL size and risk of coronary heart disease in elderly men and women. Arteriosclerosis, Thrombosis & Vascular Biology. 1999;19:2742-2748.
56 Ruotolo G, Ericsson CG, Tettamanti C, et al. Treatment effects on serum lipoprotein lipids, apolipoproteins and low density lipoprotein particle size and relationships of lipoprotein variables to progression of coronary artery disease in the Bezafibrate Coronary Atherosclerosis Intervention Trial (BECAIT). Journal of the American College of Cardiology. 1998;32:1648-1656. [pmid: 9822092].
57 St-Pierre AC, Cantin B, Dagenais GR, et al. Low-density lipoprotein subfractions and the long-term risk of ischemic heart disease in men: 13-year follow-up data from the Quebec Cardiovascular Study. Arteriosclerosis, Thrombosis & Vascular Biology. 2005;25:553-559.
58 Stampfer MJ, Krauss RM, Ma J, et al. A prospective study of triglyceride level, low-density lipoprotein particle diameter, and risk of myocardial infarction. JAMA. 1996;276:882-888. [pmid: 8782637].
59 Howard BV, Robbins DC, Sievers ML, et al. LDL cholesterol as a strong predictor of coronary heart disease in diabetic individuals with insulin resistance and low LDL: The Strong Heart Study. Arteriosclerosis, Thrombosis & Vascular Biology. 2000;20:830-835.
60 Lamarche B, St-Pierre AC, Ruel IL, Cantin B, Dagenais GR, Despres JP. A prospective, population-based study of low density lipoprotein particle size as a risk factor for ischemic heart disease in men. Canadian Journal of Cardiology. 2001;17:859-865. [pmid: 11521128].
61 Zhao XQ, Kosinski AS, Barnhart HX, Superko HR, King SB III. Prediction of native coronary artery disease progression following PTCA or CABG in the Emory Angioplasty Versus Surgery Trial. Medical Science Monitor. 2003;9:CR48-CR54. [pmid: 12601286].
62 Watts GF, Mandalia S, Brunt JNH, Slavin BM, Coltart DJ, Lewis B. Independent associations between plasma lipoprotein subfraction levels and the course of coronary artery disease in the St. Thomas' Atherosclerosis Regression Study (STARS). Metabolism, Clinical and Experimental. 1993;42:1461-1467. [pmid: 8231842].
63 Miller BD, Alderman EL, Haskell WL, Fair JM, Krauss RM. Predominance of dense low-density lipoprotein particles predicts angiographic benefit of therapy in the Stanford Coronary Risk Intervention Project. Circulation. 1996;94:2146-2153. [pmid: 8901665].
64 Mack WJ, Krauss RM, Hodis HN. Lipoprotein subclasses in the Monitored Atherosclerosis Regression Study (MARS). Treatment effects and relation to coronary angiographic progression. Arteriosclerosis, Thrombosis & Vascular Biology. 1996;16:697-704.
65 Jang Y, Kim OY, Koh SJ, et al. The Val279Phe variant of the lipoprotein-associated phospholipase A2 gene is associated with catalytic activities and cardiovascular disease in Korean men. Journal of Clinical Endocrinology & Metabolism. 2006;91:3521-3527. [pmid: 16787988].
66 Campos H, Genest JJ Jr, Blijlevens E, et al. Low density lipoprotein particle size and coronary artery disease. Arteriosclerosis & Thrombosis. 1992;12:187-195. [pmid: 1543692].
67 Koba S, Hirano T, Kondo T, et al. Significance of small dense low-density lipoproteins and other risk factors in patients with various types of coronary heart disease. American Heart Journal. 2002;144:1026-1035. [pmid: 12486427].
68 Alabakovska SB, Labudovi DD, Tosheska KN, Todorova BB. Low density lipoprotein particle size phenotyping in healthy persons and patients with myocardial infarction. Croatian Medical Journal. 2002;43:290-295. [pmid: 12035134].
69 Koba S, Hirano T, Ito Y, et al. Significance of small dense low-density lipoprotein-cholesterol concentrations in relation to the severity of coronary heart diseases. Atherosclerosis. 2006;189:206-214. [pmid: 16414053].
70 Koba S, Hirano T, Yoshino G, et al. Remarkably high prevalence of small dense low-density lipoprotein in Japanese men with coronary artery disease, irrespective of the presence of diabetes. Atherosclerosis. 2002;160:249-256. [pmid: 11755944].
71 Erbey JR, Robbins D, Forrest KY, Orchard TJ. Low-density lipoprotein particle size and coronary artery disease in a childhood-onset type 1 diabetes population. Metabolism: Clinical & Experimental. 1999;48:531-534. [pmid: 10206450].
72 Kamigaki AS, Siscovick DS, Schwartz SM, et al. Low density lipoprotein particle size and risk of early-onset myocardial infarction in women. American Journal of Epidemiology. 2001;153:939-945. [pmid: 11384949].
73 Austin MA, Breslow JL, Hennekens CH, Buring JE, Willett WC, Krauss RM. Low-density lipoprotein subclass patterns and risk of myocardial infarction. JAMA. 1988;260:1917-1921. [pmid: 3418853].
74 Sherrard B, Simpson H, Cameron J, Wahi S, Jennings G, Dart A. LDL particle size in subjects with previously unsuspected coronary heart disease: relationship with other cardiovascular risk markers. Atherosclerosis. 1996;126:277-287. [pmid: 8902153].
75 Coresh J, Kwiterovich PO Jr, Smith HH, Bachorik PS. Association of plasma triglyceride concentration and LDL particle diameter, density, and chemical composition with premature coronary artery disease in men and women. Journal of Lipid Research. 1993;34:1687-1697. [pmid: 8245719].
76 Campos H, Roederer GO, Lussier-Cacan S, Davignon J, Krauss RM. Predominance of large LDL and reduced HDL2 cholesterol in normolipidemic men with coronary artery disease. Arteriosclerosis, Thrombosis & Vascular Biology. 1995;15:1043-1048.
77 Griffin BA, Freeman DJ, Tait GW, et al. Role of plasma triglyceride in the regulation of plasma low density lipoprotein (LDL) subfractions: relative contribution of small, dense LDL to coronary heart disease risk. Atherosclerosis. 1994;106:241-253. [pmid: 8060384].
78 Miwa K. Low density lipoprotein particles are small in patients with coronary vasospasm. International Journal of Cardiology. 2003;87:193-201. [pmid: 12559540].
79 Crouse JR, Parks JS, Schey HM, Kahl FR. Studies of low density lipoprotein molecular weight in human beings with coronary artery disease. Journal of Lipid Research. 1985;26:566-574. [pmid: 4020295].
80 Okazaki M, Usui S, Fukui A, Kubota I, Tomoike H. Component analysis of HPLC profiles of unique lipoprotein subclass cholesterols for detection of coronary artery disease. Clinical Chemistry. 2006;52:2049-2053. [pmid: 16990425].
81 Hitsumoto T, Yoshinaga K, Aoyagi K, et al. Association between preheparin serum lipoprotein lipase mass and acute myocardial infarction in Japanese men. Journal of Atherosclerosis & Thrombosis. 2002;9:163-169. [pmid: 12226547].
82 Barbagallo CM, Rizzo M, Noto D, et al. Accumulation of apoE-enriched triglyceride-rich lipoproteins in patients with coronary artery disease. Metabolism: Clinical & Experimental. 2006;55:662-668. [pmid: 16631444].
83 Karpe F, Tornvall P, Olivecrona T, Steiner G, Carlson LA, Hamsten A. Composition of human low density lipoprotein: effects of postprandial triglyceride-rich lipoproteins, lipoprotein lipase, hepatic lipase and cholesteryl ester transfer protein. Atherosclerosis. 1993;98:33-49. [pmid: 8457249].
84 Tilly-Kiesi M, Syvanne M, Kuusi T, Lahdenpera S, Taskinen MR. Abnormalities of low density lipoproteins in normolipidemic type II diabetic and nondiabetic patients with coronary artery disease. Journal of Lipid Research. 1992;33:333-342. [pmid: 1569383].
85 Hallman DM, Brown SA, Ballantyne CM, Sharrett AR, Boerwinkle E. Relationship between low-density lipoprotein subclasses and asymptomatic atherosclerosis in subjects from the Atherosclerosis Risk in Communities (ARIC) Study. Biomarkers. 2004;9:190-202. [pmid: 15370875].
86 Hulthe J, Bokemark L, Wikstrand J, Fagerberg B. The metabolic syndrome, LDL particle size, and atherosclerosis: the Atherosclerosis and Insulin Resistance (AIR) study. Arteriosclerosis, Thrombosis & Vascular Biology. 2000;20:2140-2147.
87 Hulthe J, Wiklund O, Bondjers G, Wikstrand J. LDL particle size in relation to intima-media thickness and plaque occurrence in the carotid and femoral arteries in patients with hypercholesterolaemia. Journal of Internal Medicine. 2000;248:42-52. [pmid: 10947880].
88 Hayashi Y, Okumura K, Matsui H, et al. Impact of low-density lipoprotein particle size on carotid intima-media thickness in patients with type 2 diabetes mellitus. Metabolism: Clinical & Experimental. 2007;56:608-613. [pmid: 17445534].
89 Liu ML, Ylitalo K, Nuotio I, Salonen R, Salonen JT, Taskinen MR. Association between carotid intima-media thickness and low-density lipoprotein size and susceptibility of low-density lipoprotein to oxidation in asymptomatic members of familial combined hyperlipidemia families. Stroke. 2002;33:1255-1260. [pmid: 11988600].
90 Watanabe T, Koba S, Kawamura M, et al. Small dense low-density lipoprotein and carotid atherosclerosis in relation to vascular dementia. Metabolism: Clinical & Experimental. 2004;53:476-482. [pmid: 15045695].
91 Skoglund-Andersson C, Tang R, Bond MG, de FU, Hamsten A, Karpe F. LDL particle size distribution is associated with carotid intima-media thickness in healthy 50-year-old men. Arteriosclerosis, Thrombosis & Vascular Biology. 1999;19:2422-2430.
92 Raal FJ, Pilcher GJ, Waisberg R, Buthelezi EP, Veller MG, Joffe BI. Low-density lipoprotein cholesterol bulk is the pivotal determinant of atherosclerosis in familial hypercholesterolemia. American Journal of Cardiology. 1999;83:1330-1333. [pmid: 10235090].
93 Kato T, Inoue T, Yamagishi S, Morooka T, Okimoto T, Node K. Low-density lipoprotein subfractions and the prevalence of silent lacunar infarction in subjects with essential hypertension. Hypertension Research - Clinical & Experimental. 2006;29:303-307.
94 Campbell DJ, Neal BC, Chalmers JP, et al. Low-density lipoprotein particles and risk of intracerebral haemorrhage in subjects with cerebrovascular disease. European Journal of Cardiovascular Prevention & Rehabilitation. 2007;14:413-418. [pmid: 17568241].
95 Zambon A, Hokanson JE, Brown BG, Brunzell JD. Evidence for a new pathophysiological mechanism for coronary artery disease regression: hepatic lipase-mediated changes in LDL density. Circulation. 1999;99:1959-1964. [pmid: 10208998].