# Discussion

Measurement of LDL subfractions is an increasingly studied tool for cardiovascular risk status. Although the clinical value of the tool relative to other known cardiovascular risk factors has yet to be ascertained, it is available as part of the panel of risk factors being tracked by clinicians and patients. While the ATP III guidelines do not recommend measurement of small LDL particles in routine practice, they do provide guidance on how to consider altering treatment based on elevated levels (www.nhlbi.nih.gov/guidelines/cholesterol/atp3full.pdf, accessed Feb 19, 2008; page II-21-2).

The large majority of research on LDL subfractions as a potential cardiovascular risk factor has been performed with measurement methods that are either expensive, time-consuming, or resource-intensive. In addition, the methods do not use FDA cleared medical devices. Relatively few studies have been performed using tests that are available for clinical use. As described in the results sections for Questions 1, 2 and 3, there is not yet a standard method of subfraction measurement that can be used as a reference standard, has been demonstrated to be superior to other methods, or has been demonstrated to be accurate and reliable. Each of the three major methods for measuring LDL subfractions – GE, NMR, and ultracentrifugation – describes and measures the subfractions differently. Even within a specific general type of measurement tool (eg, GE) or even within a specific test (LipoPrint^®^ GE or NMR, all performed by LipoScience^®^) there is not standardization for defining or describing the LDL subfractions. A variety of outcomes are used including size (which correlate but do not agree among methods), LDL subfraction concentrations or proportions, and different patterns, among others. In addition, different researchers use different thresholds to differentiate a wide range of different numbers of LDL subfractions.

## LDL subfraction methodology

The studies comparing different methods of measuring LDL subfractions are incomplete in terms of adequately comparing each of the methods. In part, this is due to the research goals of the study authors. Only a single study (Ensign 2006 17) compared all major test methods (NMR, LipoPrint^®^ GE, other GE, and ultracentrifugation). It was common that studies performed their analyses for the purpose of establishing that a given (often unique or new) method of measuring LDL subfractions provides similar results to other methods. Overall, the studies support fair to good correlation among the different methods; however, some studies found only low levels of agreement between LipoPrint^®^ GE compared to other GE to classify LDL subfractions and ultracentrifugation compared to GE (LipoPrint^®^ or other). One study found that NMR measurement of LDL sizes are on average about 54 Å smaller than measurements based on GE, with wide limits of agreement.31 This is consistent with a widely quoted review paper in which the authors stated the fact that NMR LDL particle sizes are referenced to diameters measured by electron microscopy, which are consistently smaller by approximately 50 to 60 Å than those estimated by the gradient gel electrophoresis referencing method.19

It is important to note, though, that comparisons of methods based on agreement in size or phenotypes are necessary, but not sufficient, to evaluate whether the different methods are measuring the same LDL subfraction analytes. Since different combinations of physicochemical properties are used to separate lipoproteins with different methods (eg, density, size, electrophoretic mobility) the correlation between methods will inevitably be imperfect. Development of reference materials are necessary to allow for descriptions of the similarities and differences of the various measurements produced by the different methods. A reference method needs to be widely accepted as appropriate, accurate and reliable. However, even with a consensus reference method, it may not be possible to standardize or harmonize all of the methods because their measurement principles are so different. Possible approaches to reference measurements would include developing reference materials that are at a minimum are characterized and defined by composition, density and size.

No study reported day-to-day variability in individuals. Four studies reported on intra- and interassay variability (measures of the same serum sample). In three studies, variability was small, up to 0.2 percent for intraassay variability and up to 1.4 percent for interassay variability; though one study found a interassay variability of 13 percent among 19 samples assayed over a week. A possible reason for the larger variability of the interassay test (where the same sample is being run on different days after storage at −70° C) is that storage of the samples may have altered their characteristics. However, given that only a small subset of studies evaluated variability, it is difficult to assessed their generalizability to other studies.

A major limitation of the studies comparing methodologies and assessing the tests’ variability is the small number of studies; thus the accuracy of their findings is hard to assess. In addition, many of the studies evaluated only small numbers of patients (or serum samples) and they frequently did not adequately describe the subjects who donated samples. Furthermore, regarding the variability, the studies tested variability as a secondary analysis, with the purpose of demonstrating the accuracy of the test that is being studied for a different purpose. Therefore, the reporting of the analyses tended to be brief and incomplete.

## Association between LDL subfractions and CVD

A large number of studies have evaluated the putative association between LDL subfractions and CVD. However, relatively few of these have been performed with either of the clinically available methods of measuring LDL subfractions. In addition, overall, most studies have compared LDL subfractions to prevalent disease. Together, these issues limit the applicability of the studies to address the question of whether there is clinical value of measuring LDL subfractions for helping clinicians and patients to assess both cardiovascular risk and potential need for treatment. The studies were clinically heterogeneous in terms of age – where generally the large majority of patients were under age 65 years – sex ratio, smoking status, comorbidities and other past medical history. Overall, the applicability of these studies to the Medicare population may be somewhat limited, particularly if age, comorbidities, or other factors alter any associations between LDL subfraction and CVD.

None of the studies of LipoPrint^®^ GE, only six studies of NMR, and only one study of gradient GE performed at HeartLab^®^ evaluated incident CVD or progression of CVD. These evaluated a wide range of CVD outcomes including CAD death, new CAD diagnosis, MI, stroke, change in minimum lumen diameter of the coronary arteries, and concurrent rate of coronary artery stenosis. They also evaluated a wide range of LDL subfraction measures including two or three subfractions with size thresholds at 180 Å or 183 Å for the lower limit, 197 Å and 212 Å or 213 Å for between-subfraction thresholds, and 227 Å or 230 Å for the upper size limit; LDL particle concentration, and LDL particle size. The studies of incident CVD using NMR to measure LDL subfractions used considerably more uniform specific methods of measuring subfraction than across the other studies (primarily GE). These studies generally found that LDL particle concentration and particle numbers (NMR-specific measurements) are associated with incident CVD, but LDL particle size and small LDL particle fraction were not as consistently associated with incident disease. Among four out of the five studies, LDL particle concentration remained significantly associated with CVD events after adjustment for LDL or other traditional cardiovascular risk factors. An important caveat, though, is that each study used different methods (where reported) for choosing which other risk factors to adjust for and thus adjusted for different risk factors. Where reported, LDL size or small LDL were not significantly associated with incident disease after adjustment. The one Berkeley HeartLab^®^ gradient GE study found an association between the smallest LDL subfraction (IVb, 220–233 Å) and progression of coronary artery stenosis; however, this study is difficult to interpret clinically since the investigators used an average of baseline and year 4 lipid levels instead of baseline data alone as a predictor. Notably, though, the association was stronger for artery segments with less than 30 percent stenosis at baseline.

Among the studies that evaluated the clinically available methods of measuring LDL subfraction and prevalent CVD (including all the studies of LipoPrint^®^ GE) findings were mixed with about half finding a statistically significant association after adjustment for LDL and/or other risk factors but half not. These studies were likewise varied in their specific measures of LDL subfractions and in which prevalent CVD were evaluated.

These findings held for the analyses of all the different methods for measuring LDL subfractions. Only LDL particle concentration, as measured by NMR, was consistently found to be associated with incident CVD after adjustment for lipids (and other risk factors) in four studies. A wide range of other specific measures of LDL subfraction (primarily by GE or ultracentrifugation) have been found to be associated with incidence or progression of CVD by only a minority of studies (6 of 20 studies). Among the 6 “positive” studies that found associations between LDL subfraction measures (other than particle concentration), no consistent measure or outcome differentiated these from the remaining 14 “negative” studies.

LDL subfraction data, most commonly from LipoPrint^®^ or other GE, was more commonly associated with prevalent CVD, though the studies were very heterogeneous in their measurements and outcomes. Overall, though, about two-thirds of studies found some statistically significant association between LDL subfraction measures (usually pattern) and prevalent CVD. The clinical utility of this association, however, is unclear. These studies fail to address whether the abnormal LDL subfraction profile is related to the development of CVD or whether it is a response to the presence of CVD. Furthermore, its only potential clinical value would be as a treatable risk factor for incident or progressing CVD.

The question of the relative or incremental value of LDL subfraction measurement as a predictor for CVD compared to traditional risk factors (such as lipoprotein cholesterol, blood pressure, demographics, smoking, and comorbidities) was not a specific question of interest of any of the evaluated studies. No study evaluated any cardiovascular risk assessment technologies and measured the incremental increase in diagnostic performance. At best, studies reported sufficient details from baseline (unadjusted) or adjusted models for cardiovascular outcomes that relative strengths of associations could be gleaned. Only three studies, two using NMR and one using GE, came closest to directly addressing the question of relative value by reporting on the association between cardiovascular risk factors and incident disease in a multivariable model together with LDL subfraction data. All found that other CVD risk factors had stronger associations with incident coronary disease than LDL subfraction. Among the remaining less clinically relevant analyses (univariable analyses or prevalent CVD), about equal numbers of studies found that LDL subfraction was most strongly associated with CVD, was similarly associated as more traditional risk factors, or were less strongly (or not) associated with CVD, regardless of the specific CVD outcome. Overall, the data do not adequately answer the question of how strongly LDL subfraction information is associated with CVD, in relation to other known and putative risk factors. In summary, none of the LDL subfraction measurements have definitively been demonstrated to add to the ability to discriminate between individuals who are at higher versus lower risks of cardiovascular events compared to commonly used predictors, such as LDL and HDL cholesterol.

Close to 300 articles provide some data on the effect of various treatments or regimens on LDL subfraction profiles (this number, though, is likely to be a high estimate, as these articles were not thoroughly screened). Only seven of these studies also reported CVD outcomes. All were secondary analyses of randomized trials of lipid reduction interventions or (in one trial) a multifactorial cardiovascular risk reduction regimen. All were aimed at secondary prevention in specific groups of patients at increased risk of second CVD events or with abnormal lipoprotein cholesterol patterns. Based on demographics – particularly age – and comorbidities, these trials are all of relatively limited applicability to the Medicare population. Furthermore, as discussed in depth in the preface and results for Question 4.4, none of the analyses directly addressed the question of whether treatment based on LDL subfractions is associated with reduction in cardiovascular events or improvement in clinical severity. A single study, though, found that patients with small dense LDL had reduced progression of carotid MLD on intensive therapy compared to usual care, in contrast with those with more buoyant LDL Three of the studies may suggest that the risk of CVD that is associated with abnormal LDL subfractions may be mitigated by pravastatin or more general risk reduction, but this finding is inconclusive at best. The studies were inconsistent regarding whether changes in LDL subfractions are associated with improved CVD outcomes; these analyses were also hampered by their failure to stratify their analyses based on intervention, so that it is unclear whether the treatments played a role in risk reduction.

## Limitations

There were several limitations to the review process beyond the limitations of the evidence itself. As described, the principle portions of this review focus on two methods available for clinical use for measuring LDL subfractions. This approach was agreed upon with CMS and AHRQ, though it may provide undue emphasis on two commercial entities, while minimizing potentially unique features of tests run with other tests. It is unclear how the financial interests of these two companies may have impacted on the studies that have been performed or published using these methods. Ideally, to reduce bias, or at a minimum the perception of bias, it would be preferable to have truly independent studies of these methods. To the best of our understanding from the literature and documents available on the internet, the LipoPrint^®^ GE kit is clinically available and can be used by any research laboratory. Notably, the studies that used this kit all evaluated prevalent CVD, used a variety of different definitions for LDL subfractions, and found a mix of statistically significant and nonsignificant associations. In contrast, again to the best of our understanding, all of the studies that used NMR sent their samples to LipoScience^®^ for processing. It is not clear whether bias due to availability of this test may have been introduced. This approach had the advantage of having more consistent definitions for LDL subfractions, but notably, this test provided the only subfraction measurement that consistently was found to be significantly associated with incident CVD. Across studies, though, we were unable to adequately judge the nuances of the different methods based on the reported (or unreported) technical details. We therefore could not evaluate how these differences may have impacted the differences of results across the studies.

However, except for the issue of potential publication bias, these issues may be of relatively minor importance compared to the large degree of heterogeneity in test methods and measures, populations evaluated, and outcomes assessed. From the perspective of assessing whether these tests may be of value for CVD risk assessment in the general population, the details of the tests and the changes (potentially advances) in the techniques are of lesser interest than a determination of whether any of the test measures could be useful predictors of CVD risk and potential treatment targets.

## Future research

Given the large number of studies that have evaluated LDL subfractions, it is unfortunate that it remains true that future research is needed to address the questions posed for this systematic review. In part, this conclusion is based on the difficulties encountered in summarizing the evidence due to the large heterogeneity of the methods used to measure LDL subfractions and on the relative paucity of studies of clinically relevant CVD incidence or progression. Of the clinically available methods, only NMR-based particle concentration has consistently been found to be associated with incident CVD, but only in four disparate studies. The lack of consistent associations among other measures is partly due to lack of data (ie, LipoPrint^®^ GE as a predictor of incident disease) or the great heterogeneity of measurement methods (among other studies). Even among the NMR studies and the LipoPrint^®^ GE studies (of prevalent disease) researchers do not consistently use the same types or definitions of measures. In part this may be due to each research laboratory attempting to determine what is the “best” measure (or threshold) for predicting an outcome, but this has the effect that achieving consensus across studies is difficult, if not impossible.

With the exception of research into bringing a new LDL subfraction measurement technique (or kit) to market, currently there is little clinical value to testing a methodology that is not available for clinical use or that can be performed only in the setting of a research study. There are many such studies that find (or fail to find) an association with a specific CVD outcome. The addition of more studies of measurement techniques that are not clinically available will not assist clinicians, patients, payers, or regulators to determine whether measurement of LDL subfractions is worthwhile. Likewise, further research into whether LDL subfractions are associated with prevalent disease is of limited clinical value. There are adequate data that such an association may exist (despite the majority of studies finding no such association) and future research should focus only on CVD incidence (both primary or secondary prevention) and progression. Since LDL subfractions, like other risk factors, would not be used to diagnose a patient with CVD, it is unlikely that small dense LDL subfractions would be sufficiently predictive of prevalent disease to instigate an investigation for CVD in the absence of signs of symptoms of disease.

Current research has adequately found a potential association between LDL subfractions and CVD (both heterogeneously defined), but this is insufficient for clinical use. Thus future research regarding the putative association of LDL subfractions and CVD should focus on uniformly (and universally) defined measures of subfractions using available tests for CVD incidence or progression. From a clinical perspective (as opposed to a laboratory perspective), it is more important that a given laboratory measurement that is common and standardized across laboratories is a good predictor of the clinical outcome of interest. It is less important whether that laboratory measurement is correlated to other available (or unavailable) measurements. We are not in a position to provide specific recommendations for how the best measurement is chosen, how it is standardized, or how it is characterized, except to suggest that the clinical utility (its strength as a predictor of CVD) is most important. An update of this systematic review should likewise focus on these clinically relevant questions.

Under the assumption that LDL subfractions are associated with progression or incidence of CVD, research is needed into its relative and incremental value as a risk factor. Various risk factors, including the Framingham score, are currently used to assess people’s future risk of CVD. Several of these factors, such as LDL cholesterol, blood pressure, obesity, and smoking are amenable to intervention. The available data provide little insight into whether the addition of LDL subfraction information would affect intervention decisions (whether they have incremental value) or would ultimately result in better outcomes. The few secondary analyses of randomized trials of CVD risk factor interventions do not address whether treatment based on, or specific to, LDL subfractions would result in improved clinical outcomes compared to current standard practice. An additional aspect that may be necessary to clarify whether LDL subfraction measurement might be clinically useful is research into whether putative associations with incidence or severity of CVD exist in specific groups of individuals (such as those with abnormal glucose tolerance, kidney disease, or normal LDL cholesterol concentrations).

There are relatively few studies comparing different methods for measuring LDL subfractions. From a clinical perspective, it would be helpful to have some additional studies that directly compare the two clinically available methods. The primary purpose of these studies should be to assess whether classification or other standard measure of LDL subfractions are comparable when measured with either test. In particular, the finding in Ensign 2006 17 of an approximately 50 Å difference in size measurement between NMR and GE needs to be confirmed (or refuted) before definitive size thresholds are established. If the differential is confirmed, it may be necessary to adjust the (calculated) size of the NMR measurements to conform more to GE measurements. This study also provided some evidence that the size differential may not be consistent across populations. This requires further investigation. However, from a clinical perspective, the important question remains which (if any) of the methods is the most useful in predicting CVD. From this perspective, the question of the agreement of methods regarding specific test metrics may be less important, except to help standardize the tests.

The remaining area covered by this review that requires further research is on the within-subject variability of LDL subfractions. The potential variability may be due either to day-to-day changes within individuals or to laboratory variability. If there is a large degree of variability within individuals then different approaches may be necessary to testing patients and measuring the associations with CVD. Batched or repeated measures may be necessary. If the within-subject variability is large this might in part explain the lack of consistency across studies as to the strength of associations with CVD. Several studies, in different populations, that are designed specifically to address this question are needed. Additional studies evaluating the within-sample (intraassay and interassay) variability would also be helpful to confirm the findings of a small number of studies in relatively few subjects. Improved reporting of the subject characteristics are needed to properly evaluate the studies.

## Summary

In summary, despite a large number of studies evaluating the association of LDL subfractions and CVD (that have led to a very large number of studies of potential interventions to alter subfraction patterns), the clinically useful evidence regarding whether measurement of LDL subfractions may be a helpful tool for assessing cardiovascular risk (or altering treatment of cardiovascular risks) is lacking. This is largely due to the relative paucity of studies that have evaluated clinically available tests and their associations with incidence or progression of CVD.

Only one measure (LDL particle concentration measured by NMR) was consistently significantly associated with CVD events, after adjustment for lipoproteins and other cardiovascular risk factors. The strength of the associations varied, with RR or OR ranging from 1.11 to 2.90. Other NMR measures were not consistently associated with incident or progressive disease. LipoPrint^®^ GE, the other clinically available test, has not been tested as a predictor for incident or progressive CVD. Studies of the remaining (not clinically available) tests are inconsistent, but mostly find no association with incident CVD (before or after adjustment for lipoproteins and other risk factors). More well-conducted research is needed. Future studies should focus on the clinically available tests and incidence or progression of CVD, and should aim to use standard test metrics and classifications to allow for comparison across studies. The current evidence suggests that LDL subfractions is not a consistently strong predictor of CVD compared to other known risk factors, but this question has not been properly evaluated by any study.

The small number of trials of cardiovascular interventions that have been secondarily analyzed to evaluate LDL subfractions suggest a possible role for the subfractions in predicting outcomes with treatment, but fail to address the clinical question of whether treating patients based on LDL subfractions would reduce their risk of CVD.

The small number of studies that directly compared different tests generally found fair to good agreement, though not all studies consistently agreed. These studies need to be reproduced to assess their validity. This is particularly true for the one study that found a difference in size measurements between NMR and GE since this is frequently cited among other studies. Within-subject and within-sample variability have not been adequately evaluated to definitely determine the tests’ accuracy. It is possible that the day-to-day variability found by one study may partly account for the heterogeneity of results regarding the value of the test as a predictor of CVD.