# Results

## Literature Search

The literature search yielded 6373 unique citations from Medline (n=5996), CAB Abstracts (n=326), the Cochrane clinical trial registry (n=47), and the Cochrane database of systematic reviews (n=4). Of these, 457 full text articles were retrieved. As described further below, 9 articles provided information for Question 1, 9 studies were eligible for Question 2, 5 studies were eligible for Question 3 (two of which were also eligible for Question 2), and 65 studies were eligible for Question 4 (one of which was also eligible for Question 2).

Among the 374 rejected articles, 270 evaluated possible treatments for abnormal LDL subfractions but did not evaluate CVD outcomes (see Appendix C). Among the remaining rejected articles 54 had no relevant information, 12 did not evaluate LDL subfractions, 9 did not evaluate a clinical CVD outcome (for Question 4), 7 were duplicate publications, and 22 were rejected for other reasons (see Appendix B).

## Question 1

### What are the methods that have been proposed to be used routinely to measure LDL subfractions? Is there a method that is considered the reference standard?

Among the studies evaluated below for Question 4, four general methods for separating and measuring LDL subfractions were identified: gel electrophoresis (GE), nuclear magnetic resonance (NMR), ultracentrifugation, and high pressure liquid chromatography (HPLC). The most common methods reported for measuring LDL subfractions involve either GE or ultracentrifugation methods.

#### Gel electrophoresis

The large majority of studies that have implemented GE used specific methods that were particular to the research laboratories. The researchers created their own gels and used techniques that may have been based on previous researcher's work, but were not standardized. They also tended to use definitions of LDL subfractions that were unique to their laboratories or were otherwise not standardized. LDL subfractions quantified by GE are frequently classified into either pattern A, pattern B, or an intermediate pattern. Investigators may also use different algorithms for the classifications of LDL patterns. GE can also determine the LDL subfraction sizes by comparisons with calibrators that included particles and/or LDL lyophilized standards with known sizes. A drawback of these methods is the lengthy labor intensive nature of the experimental procedures some of which require more than a day for sample analysis. There is also a practical restriction to the number of samples that can be analyzed at any one time, which may limit applications of these methods for routine clinical use.14 Another limitation of these GE methods was due to limits in thickness of the gradient gels as related to ensuring reproducibility of the gradient gels, which in turn may affect comparability of LDL particle separation from laboratory to laboratory. Moreover, the visualization of the protein bands requires the removal of the gel from its casing, incubation with a staining solution followed by destaining and scanning, again, a labor intensive process that can introduce variability.

LipoPrint^®^ (Quantimetrix Corp.) is a GE system that is available to clinical laboratories for testing of LDL subfractions in patients. The system includes specific equipment and reagents and a standard method for defining LDL subfractions. It uses a loading gel that is polymerized with fluorescent light. This method permits separation of LDL into seven subfractions within 60 minutes. Multiple samples can be run simultaneously. Because the gels are prepared by the company, it is technically simpler, less expensive, and more conducive to routine laboratory testing than traditional GE.15 LDL particles are separated by size and to a lesser extent charge, and migration distance is quantified by densitometric scanning. According to LipoPrint^®^ product insert describing the manufacturer's instruction for the analytic procedure and producing quantitative results (http://www.4qc.com/products/lipoprint/index.html), a typical Lipoprint^®^ profile consists of 1 VLDL band, 3 midbands (comprising primarily IDL), up to 7 LDL bands, and 1 HDL band. After the electrophoresis is completed, the various stained lipoprotein fractions (bands) present in the sample are identified by their mobility (Rf) using VLDL as the starting reference point (VLDL=0) and HDL as the leading reference point (HDL=1). The relative area for each lipoprotein band is determined and multiplied by the total cholesterol concentration of the sample to yield the amount of cholesterol for each band in mg/dL. The lipoprotein subfraction profiles can also be classified into Type A (normal) and Type B (abnormal) based on the average particle size of the LDL particles described in a paper by Austin and associates.16 Use of the Lipoprint^®^ to determine particle sizes or LDL scores or any other form of classification is not recommended by the manufacturer of the kit. However, as will be noted below, research laboratories using Lipoprint^®^ frequently have not used the recommended LDL subfraction definitions.

Berkeley HeartLab^®^ uses LDL Segmented Gradient Gel Electrophoresis (LDL-S_3_GGE™).17 This technique separates LDL particles into 7 LDL subfractions (LDL I, IIa, IIb, IIIa, IIIb, IVa, and IVb) based on particle size and shape. LDL-S_3_GGE™ gel kit provides a method (a computer algorithm) for calculating the number of particles in an LDL subfraction.18 The LDL particle number is determined by assuming a physiological 1:1 ratio between apo B and LDL particles. In published literature, investigators use the S_3_GGE™ gel kit for classifying LDL subfractions as pattern A, AB, or B based on LDL size cutoffs.17

#### Ultracentrifugation

Similar to GE, the studies that have implemented ultracentrifugation used a variety of instruments, specific methods, and definitions of LDL subfractions in their laboratories. Ultracentrifugation is likewise labor intensive, particularly sequential flotation, which may require more than a day for sample analysis. An arbitrary selection of density ranges is often used. LDL subfractions quantified by ultracentrifugation are frequently classified into either pattern A, pattern B, or an intermediate pattern. Investigators also used different algorithms for the classifications of LDL subfractions.

As best we could determine, the University of Washington's Northwest Lipid Research Lab (http://depts.Washington.edu/nwlrl/) uses an ultracentrifugation method and is available to run clinical samples.

#### Nuclear magnetic resonance

The NMR method measures the signal from the aggregate number of terminal methyl groups in the lipid within the particle. The number of methyl groups is reflected in the amplitude of the methyl NMR signal. The amplitude of each lipoprotein particle signal serves as a measure of the concentration of that lipoprotein. Using standard assumptions concerning lipoprotein diameter and lipid content, the NMR data can be transformed (through calculations) into subfraction concentrations. Other quantitative subtraction information, such as LDL size and patterns, can also be derived through additional calculations.19 NMR is available to patients and clinicians by sending samples to a small number of clinical laboratories that have the equipment.

The concept of using proton NMR spectroscopy to measure plasma lipoprotein particle concentrations was introduced in the early 1990s and was commercialized for clinical research in 1997.^19^ NMR can quantify the numbers of lipoprotein subclass particles based on two phenomena. First VLDL, LDL, and HDL subclasses of different sizes in plasma simultaneously emit distinctive NMR signals whose individual amplitudes can be accurately and reproducibly measured. Second, the measured subclass signal amplitudes are directly proportional to the numbers of subclass particles emitting the signal, irrespective of variation in particle lipid composition. Therefore, NMR spectroscopy can provide simultaneous measurements of LDL particle number and size (through calculations), as well as measurement of high density and very low density lipoprotein (HDL and VLDL) subfractions. There are, however, several assumptions for NMR measurements of lipoprotein subfractions. The NMR method is calibrated by its library of over 30 signal envelopes from size-characterized purified fractions. It is assumed that every sample analyzed and the NMR spectra deconvoluted by the NMR method software has components encompassed closely enough by this calibration library, and all NMR spectral components of a given sample are unique to lipoproteins (ie, no spectral interferences). There are many layers of assumptions within the NMR software, which is proprietary. Some of the unknown assumptions, calibration and validation issues have been addressed19 but some remain to be fully evaluated.

#### High performance liquid chromatography (HPLC)

The original HPLC method for measuring LDL size monitors the column effluent at 280 nm of the isolated LDL subfraction by ultracentrifugation. The retention time of the LDL peak is then used to calculate the LDL diameter.20 A drawback of this method is the necessity of LDL isolation by ultracentrifugation prior to chromatography. A modified HPLC method that is based on selective detection of lipoproteins by postcolumn labeling with parinaric acid (a fluorescent lipid probe) permits direct measurement of LDL size in whole plasma or serum.21 Notably, though, despite a positive report of the method's comparability to GE, as described below, the method has only rarely been used over the past decade by researchers of LDL subfractions and CVD risk.

#### Methods submitted to the Food & Drug Administration (FDA)

The CLIA database contains the marketed in vitro test systems categorized by the FDA since January 31, 2000 and tests categorized by the Centers for Disease Control and Prevention (CDC) prior to that date. A search on the CLIA database for all listed analyte names with “lipoprotein fractions” returned a total 31 records meeting this search criterion. All documents and internet links associated with these 31 records were examined for the relevance to the methods of measuring or separating LDL subfractions. Seven devices were identified: Helena Laboratories REP HDL/LDL-30 Electrophoresis System, Helena Laboratories REP Ultra HDL, VLDL/LDL Cholesterol System, Isolab LDL–Direct, Isolab LDL–Direct Plus, LipoPrint^®^, LFS Lipogel System^®^ (Zaxis, Inc.), and Hydragel K20 System with HYDRASYS^®^ (Sebia, Inc). These devices are also categorized under the device classification name of “electrophoretic separation, lipoproteins”. The first four devices (by Helena Laboratories and Isolab) did not have any other associated documents posted on the CLIA database except for the standard report from the database search. There are summaries/statements of the 510(k) notification in concordance of the Safe Medical Devices Act (SMDA) posted for the latter three devices (LipoPrint^®^, LFS Lipogel System^®^, and Hydragel K20 System).

From evaluation of the summaries/statements of the 510(k) notification, we concluded that, all of these devices that have been used to measure LDL subfractions or sizes in the literature were cleared by FDA for the use of separating or measuring LDL fraction (ie, separating LDL cholesterol from other cholesterol-containing lipoprotein particles), not for the use of measuring LDL subfractions or sizes. According to the summary/statement of the 510(k) notification, Quantimetrix LipoPrint^®^ System classifies LDL subfractions as Mid-C, Mid-B, Mid-A, and LDL-1 through 7. The sum of all subfractions constitutes total LDL cholesterol. The intended use of Quantimetrix LipoPrint^®^ System declared in the summary/statement of the 510(k) notification of FDA was “to measure lipoprotein cholesterol (for lipoprotein fractions and subfractions from VLDL to HDL) in fasting serum or plasma with a total cholesterol concentration ≥ 100 mg/dL.” The performance characteristics comparing Quantimetrix LipoPrint^®^ System to direct HDL or LDL cholesterol methods were also provided. These data confirmed that the LipoPrint^®^ LDL Test System performs comparably to the direct HDL or LDL cholesterol methods in a clinical setting. The device was therefore found to be substantially equivalent to legally marketed devices by FDA, and was permitted to proceed to the market.

The search of the FDA CLIA database for “nuclear magnetic resonance/NMR” test systems or LipoScience/LipoMed manufacturer resulted in no records found. According to the information provided by LipoScience, Inc., all tests are performed using FDA cleared reagents and methods. The current FDA cleared LDL cholesterol measurement system of NMR LipoProfile^®^ is Beckman Synchron CX 4 system (reagents and methods) measuring LDL cholesterol in human serum or plasma. A search of the FDA CLIA database for Beckman Synchron CX 4 resulted in eight records with effective dates from 1995 to 2000.

We did not identify any federal documents by FDA or other government agencies that discuss possible reference standards for measuring LDL subfractions.

#### Narrative reviews

To provide greater insight into what methods may be used routinely to measure LDL subfractions and whether any method is considered a reference standard, we systematically searched for review articles and editorials that discussed potential routine use of any method or suggested a reference standard. An important caveat is that some of those reviews were written by authors who were actively involved in bench research of LDL subfractions and had either a professional or financial stake in the use of a given methodology.

Ultracentrifugation has been described as the “original gold standard” to which subsequent methods have been calibrated and validated.11 James Otvos and Elias Jeyarajah, who with others developed NMR analysis of LDL subfractions, also described that the NMR measures were calibrated against ultracentrifugation-derived reference data on isolated lipid subfractions.22 However, ultracentrifugation is time-consuming and available only at some research laboratories.11

As described by several review articles, and also as evidenced by the studies eligible for Question 4 below, GE is the most commonly used procedure in research laboratories.23,24 Researchers use many different specific measurements or methods of analyzing the data from GE; however, among the more consistent measurements is the assignment of phenotypes into larger more buoyant LDL phenotype A and smaller dense LDL phenotype B (and A/B or intermediate phenotypes). However, as we also found in our review for Question 4, there is not complete consistency in the definition of the particle diameter threshold to distinguish phenotypes A and B, or how to analyze those with intermediate phenotypes. Quantimetrix has commercialized the LipoPrint^®^ GE method for LDL subfractionation. However as we describe below (Questions 2 and 4) and as commentators have noted,25 there does not appear to be harmonization by researchers of the measurements derived from the test or clear validation of the method against other methods.

NMR measurement of LDL subfractions has been commercialized and has been described as the most rapid and convenient method for determining LDL size and subfraction concentration, though questions remain about its calibration and validation.11 Despite its commercial availability, it has been described as not being a popular measurement method due to the requirement for expensive specialized laboratory equipment which is “too difficult to use in daily clinical practice.”23 Nevertheless, an advantage ascribed to NMR (by Drs Jeyarajah and Otvos) is that it has the “unique ability to quantify lipoprotein particle numbers, even in the face of significant variation in the cholesterol composition of subfraction particles among individuals.”19

#### Summary

There is currently no generally accepted reference standard for measuring LDL subfractions. The most common methods for measuring LDL subfractions involve either GE or ultracentrifugation methods. However the lengthy experimental procedures and heterogeneity in the algorithms to classify LDL patterns or sizes limit their application for routine clinical practice. Furthermore, all current gel electrophoresis devices in the FDA database have been used to measure LDL subfractions or sizes in the literature were based on substantial equivalence to legally marketed devices for measuring LDL cholesterol, not LDL subfractions. LipoPrint^®^ is the only FDA-cleared devices that declared its intent to measure LDL subfractions as the primary use. NMR measurement of LDL subfractions has been commercialized and has been described as the most rapid and convenient method for determining LDL size and subfraction concentration, though questions remain about its calibration and validation. HPLC has rarely been reported in research studies over the past decade.

## Question 2

### How do different methods of measuring LDL subfractions compare in terms of test performance?

In this section, we review primary studies that compared different methods of measuring LDL subfractions. The methods examined include NMR, LipoPrint^®^ GE, other GE methods (bench methods), ultracentrifugation, and others. Studies had to use adult serum samples from at least 10 individuals for each method. We excluded studies that evaluated only incremental or technical changes to the methods (eg, comparison of LDL particle size determination by GE using two different approaches; comparison of LDL particle size by HPLC with ultraviolet light detection to a modified method based on selective detection of lipoproteins by postcolumn labeling with a fluorescent lipid probe).

We allowed any method of comparing test performance, including sensitivity/specificity, Bland-Altman plot (or bias and limit of agreement), correlation (r), or measures of concordance or agreement between tests. We reviewed all statistical approaches acknowledging that different methods of comparing test performance make different statistical assumptions and have different interpretations of the results:

- Sensitivity and specificity measure the clinical diagnostic test performance. Their calculations require a “gold” or “reference standard” that is presumed to have no measurement errors. Sensitivity is the proportion of people with the “disease” (or a positive reference standard) who are identified by the test. Specificity is the proportion of people with a negative reference standard who also have a negative test result.
- Correlation coefficient (r) measures the correlation of one diagnostic test to another, but does not provide any information about the clinical utility of the test. Correlation coefficient is inadequate for comparing a new method of measuring LDL subfractions with an established one for several reasons: First, r measures the strength of a relation between two variables, not the agreement between them. Two variables are in perfect agreement not only if the points from the scatter plot lie along the line of equality (the diagonal line of a scatter plot), but also if the points lie along any straight line. Second, r depends on the range of values in the sample. If the range is wide, the correlation is likely to be greater than if it is narrow. Third, correlation ignores bias (or the systematic difference between methods) and it measures relative rather than absolute agreement.26 Thus, interpretations of test accuracy using correlation coefficients may be misleading. A high correlation does not necessarily imply that there is good agreement between the two methods.
- Bland-Altman bias and limits of agreement measure the absolute agreement between two tests, assuming there are measurement errors in both tests (ie, neither test is a “gold standard”).26 Bland-Altman bias and limits of agreement do not provide any information about the clinical utility of the diagnostic test. A Bland-Altman plot plots the mean of the results from the compared tests (x-axis) against the difference between the two tests (y-axis). The accuracy is assessed by evaluating how close the data points are to zero on the y-axis (difference between tests; the limits of agreement) and whether there is a trend as the value on the x-axis (mean value) increases (or bias). Zero bias and narrow limits of agreement indicate a good agreement between the two methods. In addition, ideal tests would have consistent limits of agreement across wide range of testing populations.
- Kappa is a measure of agreement between two tests taking into account agreement that could occur by chance. Kappa does not provide any information about the clinical utility of the diagnostic test. A kappa value of one indicates the two tests have perfect agreement, and a kappa value of zero indicates the two tests have no agreement.

Nine articles provided data on the comparison of different methods.15,17,20,27–31 Four articles reported five comparisons of NMR and GE, three articles compared LipoPrint^®^ and other GE, four articles reported five comparisons of ultracentrifugation and GE, and one article compared HPLC and GE (Table 1). Only one study (Witte 2004) used a random sample of the study populations and blinding of the investigators for the alternate test results.31 Therefore, this was the only good quality study. All other studies used convenience samples; half reported that the test results were assessed in blinded fashion in relation to alternate test results. Seven studies were of fair quality. The one poor quality study gave an inadequate description of the tests compared.28

#### Nuclear magnetic resonance (NMR) vs. gel electrophoresis (GE)

Four articles reported five comparisons of NMR and GE involving 436 subjects (Table 1, NMR vs. GE) 17,27,30,31 Witte 2004 randomly selected patients with type 1 diabetes and people without diabetes from the general population. Ensign 2006 and Blake 2002 enrolled a convenience sample of healthy people. Hoefner 2001 did not describe how the study population was selected. The lipid profiles of all 436 subjects across studies were heterogeneous.

Although there was a good correlation between NMR-assessed and GE-assessed LDL particle sizes in 21 apparently healthy men (r=0.89, P<.001),27 Bland-Altman limits of agreement analyses in 324 men and women with and without type 1 diabetes showed that the mean difference between measured LDL size on NMR and peak LDL size on GE was 53.8 Å (with NMR being smaller).31 The 95 percent limits of agreement were 39.7 and 67.9 Å, indicating the 95 percent of the differences between the two methods can be expected to fall within this range. The difference and the strength of the relation between LDL size according to NMR and GE were also different across different subgroups of the study population, suggesting inconsistent agreements between NMR and GE across populations. The mean difference was larger for patients with type 1 diabetes, women, and those with lower triglyceride concentrations.

Two studies involving a total of 90 subjects showed a fair to good concordance or agreement between NMR-assessed and LipoPrint^®^ or nonstandardized GE-assessed LDL patterns (ranging from 51 to 94 percent).17,30 The wide range of agreement may be partly explained by the heterogeneity in the classifications of LDL patterns between the different methods. Studies using NMR classified LDL patterns (ie, pattern A, intermediate, or pattern B) based on absolute size cutoffs. Studies that utilized GE to measure LDL subfractions used the same classification scheme but different cutoffs were chosen. Studies using LipoPrint^®^ classified LDL patterns based on complicated LDL scores using area under the curve at various predefined electrophoretic mobility (R_f_) values. The concordance rates between NMR-assessed and GE-assessed LDL patterns also varied according to the LDL phenotypes.

#### LipoPrint^®^ GE vs. other GE methods

Three articles compared LipoPrint^®^ and other methods of GE LDL subfraction separation involving a total of 188 subjects (Table 1, LipoPrint^®^ vs. GE).15,17,30 Ensign 2006 enrolled a convenience sample of healthy people. Hirany 2003 and Hoefner 2001 did not describe how the study populations were selected. The lipid profiles of all 188 subjects across studies were heterogeneous.

All three studies evaluated the concordance or agreement between LipoPrint^®^-assessed and GE-assessed LDL patterns.15,17,30 However, the Lipoprint^®^ kit was not used according to the manufacturer's instructions. Each of the three investigators created its own criteria to evaluate and classify the results of the Lipoprint^®^ test. Hirany 2003 classified LDL subfractions into small, intermediate or large based on electrophoretic mobility (Rf) cutoffs (ie, small LDL: Rf>0.40, intermediate LDL: Rf=0.38-0.40, large LDL: Rf<0.38). Ensign 2006 classified LDL subfractions into pattern A, AB, and B based on the LDL subfraction score (LDLFS) that was developed and used in Hoefner 2001 paper (ie, normal or pattern A: LDLSF score <5.5, Intermediate or pattern AB: 5.5-8.5; atherogenic or pattern B: >8.5) The concordance rates between LipoPrint^®^-assessed and GE-assessed LDL patterns varied according to the LDL phenotypes.

Hirany 2003 reported a good agreement between LipoPrint^®^ and an alternate GE method after evaluating the data using kappa statistics (weighted kappa = 0.78; 95% CI, 0.68-0.87). LipoPrint^®^ had an agreement of 92 percent concordance for classification of the small LDL subfraction compared with GE. For large LDL subfraction, LipoPrint^®^ had an agreement of 77 percent concordance compared with GE.

Hoefner 2001 reported 84, 64, and 24 percent agreement for classification of the small, intermediate, and large LDL subfraction, respectively, for LipoPrint^®^ and GE. Ensign 2006 showed only 40 percent agreement in the classification of LDL patterns between LipoPrint^®^ and GE.

#### Ultracentrifugation vs. GE

Four articles reported five comparisons of ultracentrifugation and GE methods involving a total of 152 subjects (Table 1, Ultracentrifugation vs. GE).17,28,29,32 Dormans 2001, Ensign 2006, and Davies 2003 enrolled a convenience sample of healthy people. O'Neal 1998 enrolled a convenience sample of patients with type 2 diabetes (26 percent) or from the general population. The lipid profiles of these 152 subjects across studies varied greatly although the data were incompletely reported in most studies.

There was no uniform ultracentrifugation or GE methodology across studies. Therefore, the results from these five comparisons are evaluated individually.

Dormans 2001 showed that migration distance of the predominant LDL subfraction from GE correlated strongly with the density of the predominant LDL band from ultracentrifugation (r=0.85, P<0001) in 41 healthy individuals.

Ensign 2006 reported 41 percent agreement for classification of LDL patterns between ultracentrifugation vertical auto profile and GE, and 11 percent agreement for classification of LDL patterns between ultracentrifugation vertical auto profile and LipoPrint^®^.

O'Neal 1998 showed a good correlation (r=0.78, P<.0001) when comparing vertical ultracentrifugation and light-scattering methodology with GE for determining LDL particle size. However, the mean LDL size obtained by vertical ultracentrifugation was smaller than those obtained by GE (231 vs. 261 Å, P<0.0001).

Davies 2003 examined the diagnostic test performance of an LDL peak density of > 1.025 kg/L and area under the LDL profile (> 1.028 kg/L) by iodixanol ultracentrifugation in predicting a predominance of small dense LDL III (pattern B) as determined by GE or salt ultracentrifugation. This study was graded poor due to inadequate description of the reference standard. An area under the LDL profile of over 51 percent (density>1.028 kg/L) was shown to give 100 percent specificity and sensitivity in differentiating a predominance of small dense LDL III (pattern B). This was reported to be “marginally better” as a predictor of small dense LDL III than the cutoff density of 1.028 kg/L alone (94 percent sensitivity; 92 percent specificity).

#### High performance gel filtration chromatography (HPLC) vs. GE

One article compared HPLC with GE involved 60 patients with type 2 diabetes (Table 1, HPLC vs. GE).20 The total cholesterol and triglyceride concentrations ranged from 135 to 315 mg/dL and 45 to 509 mg/dL, respectively.

LDL size as measured by HPLC and GE was highly correlated (r=0.88, P<.0001). Bland-Altman limits of agreement analyses showed that the mean difference between LDL size on HPLC and on GE was 2.5 Å (with HPLC being larger). The 95 percent limits of agreement were −6 and +10 Å, indicating that 95 percent of the differences between the two methods can be expected to fall within this range.

#### Summary

A wide range of agreement (described as fair to good agreement) was reported for the comparison of NMR-assessed with GE-assessed LDL patterns and for Lipoprint^®^-assessed versus other GE-assessed LDL patterns. The differences between the methods, though, varied across different prespecified populations. One study found that NMR measurements of LDL size are on average about 54 Å smaller than measurements based on GE, with wide limits of agreement, implying that size measurements made with the different methods are not interchangeable. The measured size difference was larger for patients with type 1 diabetes, women, and those with lower triglyceride concentrations, suggesting inconsistent limits of agreements between NMR and GE across testing populations. The studies comparing ultracentrifugation and GE methods used different techniques and measurements; therefore the agreements between ultracentrifugation and GE methods for assessing LDL patterns are each unique to the individual study. One study compared HPLC and GE; it found good agreement between HPLC-assessed and GE-assessed LDL sizes but, on average, HPLC measurement of LDL sizes are 2.5 Å larger than measurements based on GE, implying that size measurements made with the different methods are not interchangeable.

## Question 3

### Question 3.1

#### How much variability is there in measures of LDL subfractions from day to day?

To answer this question, studies must have drawn serum samples from the same volunteers on multiple days within a short period of time (we did not set a strict upper limit on the time frame). No study addressed this question.

### Question 3.2

#### How much variability is there in measures of LDL subfractions within the same individual (measure to measure)?

For Question 3.2, studies must have measured the same serum samples using the same method at least twice. Five studies reported data on the intraassay variability (or the reproducibility) and/or the interassay variability (or the imprecision of test by analyzing stored samples on different days) using repeated measures by the same test (Table 2).19–21,30,33 No study described how the subsample was selected from the study population and none was primarily designed to address this question.

Hoefner 2001 took two plasma samples from the study population and measured their LDL subfraction scores using LipoPrint^®^ GE. The intraassay coefficients of variations for patient samples analyzed 10 times in duplicate were 4.6 and 4.3 percent at LDL subfraction scores of 3.4 and 13.3, respectively. Interassay precision was determined using plasma from 19 subjects with LDL scores ranging from 2.9 to 16.5 assayed on 3 days over a 1 week period. The mean interassay coefficient of variation (CV) was 13 percent, although how the blood samples were stored during the 1 week period was not reported.

Scheffer 1997 took a subset of the study population and measured their LDL size using GE and HPLC methods. Between-run reproducibility for particle diameter was determined by repeatedly analyzing an isolated LDL sample stored in aliquots at −70° C. GE and HPLC reproducibility, expressed as coefficients of variation (CV) determined over an 8 week period, were 0.6 percent (n=14) and 0.2 percent (n=12), respectively. Within-run reproducibility for LDL size measurements was assessed only for the HPLC method. For the sample of 10 patients with type 2 diabetes, the CV for two different LDL samples was less than 0.1 percent. In a subsequent study, Scheffer et al. modified the HPLC method and compared the test performance of the modified method to the original HPLC method for measuring LDL sizes. Using isolated LDL and whole plasma samples from 10 subjects, Scheffer 1998 reported that the within-run CV of the modified HPLC method were 0.14 and 0.22 percent, respectively. Using isolated LDL samples stored in aliquots at −86° C they reported that between-run CVs calculated from measurements performed on different days was 0.21 percent.

Adler 2000 compared LDL particle size determination by GE with two additional methods for LDL fractionation: ultracentrifugation using a density range of 1.019 and 1.063 g/mL, and precipitation of apo B-containing lipoproteins from plasma. This study was graded poor quality due to inadequate reporting of the study population and statistical analyses for the test variability. Peak particle diameter was reproducible with a CV of 1.2 percent for LDL samples separated by ultracentrifugation and 1.4 percent for LDL samples separated by apo B precipitation in six separate gels. It was also reported that “the intraassay variation (within a single gel) was 0.2 percent”, although it was unclear how many samples and which separation method were used for this calculation.

In a review article by Jeyarajah 2006,^19^ data on the intraassay and interassay precision of NMR lipoprotein measurements were reported. This study was graded poor quality due to inadequate reporting of the study population and methods for sample handling (although the authors stated that all procedures were following “standard protocol”). Two plasma pools were used, one with nominally “high triglycerides and low HDL” and the other with “low triglycerides and high HDL.” For the plasma pool with “high triglycerides and low HDL”, the intraassay and the interassay precision for total LDL particle concentration were 2.4 percent CV and 2.1 percent CV, respectively. For the same plasma pool, the intraassay and the interassay precision for LDL size were 0.4 percent CV and 0.5 percent CV, respectively. For the other plasma pool with “low triglycerides and high HDL”, the intraassay and the interassay precision for total LDL particle concentration were 4.0 percent CV and 4.3 percent CV, respectively. For the same plasma pool, the intraassay and the interassay precision for LDL size were 0.5 percent CV and 0.6 percent CV, respectively.

##### Summary

The test variability is substantially greater when analyzing LDL patterns (ie, pattern A, intermediate, or pattern B) than when analyzing LDL sizes. The intraassay variability was relatively small (ranging from <0.1 to 0.22 percent) compared to the interassay variability (ranging from 0.2 to 1.4 percent in four studies, with a fifth study having 13 percent variability) within the same method for measuring LDL sizes. In one study, it was shown that the intraassay variability was greater, as assessed by HPLC, when whole plasma was used compared to isolated LDL (0.22 vs. 0.14 percent).

Table 1 Comparison of different methods for measuring LDL subfractions

Author, Year Country UI | N | Mean (range), mg/dL | | | Population | Tests | | Concordance or Agreement | | Quality
Author, Year Country UI | N | LDL-c | TC | Tg | Population | Test 1 (Metric) | Test 2 or “Ref Std” (Metric) | r (P Value) | LOA (95%CI) or Other Results | Quality
NMR vs. GE
Witte, 2004^31^ Netherlands 14993238 | 324 | nd | nd | ≤545 | Case: diabetes (type 1) Control: general | NMR (size, nm) | GE (size, nm) | nd | All (n=324): −5.38 (−6.79, −3.97) Type 1 DM (n=152): −5.49 (−7.31, −3.68) No DM (n=172): −5.27 (−6.96, −3.60) Men (n=156): −5.20 (−6.86, −3.53) Women (n=168): −5.55 (−7.41, −3.68) Tg<79 mg/dL (n=108): −5.73 (−7.54, −3.92) Tg 79–118 (n=109): −5.41 (−6.94, −3.89) Tg>118 (n=107): −4.99 (−6.61, −3.37) | A
Hoefner, 2001^30^ US 11159775 | 51 | 120 | 213 | 217 | nd | NMR (pattern A, intermediate, pattern B based on absolute size cutoffs) A | LipoPrint™ (pattern A, intermediate, pattern B based on LDLSF score) B | −0.67 (<.001) | Concordance: Pattern A=94% Intermediate=7% Pattern B=67% | B
Ensign, 2006^17^ US 16740651 | 37–40 | (58–820) | nd | (37–479) | General | NMR (pattern A or B) | GE (pattern A, AB, or B) C | Agreement = 70% (28/40) Agreement when GE pattern AB combined with pattern A =80% (32/40) | | B
Ensign, 2006^17^ US 16740651 | 37–40 | (58–820) | nd | (37–479) | General | NMR (pattern A or B) | LipoPrint™ (pattern A, AB, or B) D | Agreement = 51% (19/37) Agreement when GE pattern AB combined with pattern A =54% (20/37) | | B
Blake, 2002^27^ US 12370215 | 21 | 111 | 117 | 164 | General | NMR (size, nm) | GE (size, nm) | 0.89 (<.001) | nd | C
LipoPrint^®^ vs. other GE
Hirany, 2003^15^ US 12669713 | 102 | 125 (42–452) | 219 (113–563) | 270 (61–617) | nd | LipoPrint^®^ GE (small, intermediate; large based on Rf cutoff values) E | GE (small, intermediate; large based on absolute size cutoffs) F | Weighted kappa= 0.78 (0.68–0.87) Concordance: Small=92% Intermediate=33% Large=77% | | B
Hoefner, 2001^30^ US 11159775 | 51 | 120 | 213 | 217 | nd | LipoPrint^®^ GE (pattern A, intermediate, pattern B based on LDLSF score) B | GE-Zaxis (pattern A & B per Berkley HeartLab cutpoints) | Concordance: Pattern A=88% Intermediate=64% Pattern B=24% | | B
Ensign, 2006^17^ US 16740651 | 35 | (58–820) | nd | (37–479) | General | LipoPrint^®^ GE (pattern A, AB, or B) D | GE (pattern A, AB, or B) C | Agreement = 40% (14/35) | | B
Ultracentrifugation vs. GE
Dormans, 2001^29^ Netherlands 2049850 | 41 | nd | 213 | 143 | General | DGUC (LDL-1, LDL-2 or LDL-3, g/mL) | GE (migration distance, mm) | 0.85 (<.001) | nd | B
Ensign, 2006^17^ US 16740651 | 37 | (58–820) | nd | (37–479) | General | UC-VAP-II (pattern A, AB, or B) G | GE (pattern A, AB, or B) C | Agreement = 41% (15/37) | | B
Ensign, 2006^17^ US 16740651 | 37 | (58–820) | nd | (37–479) | General | UC-VAP-II (pattern A, AB, or B) G | LipoPrint™ (pattern A, AB, or B) D | Agreement = 11% (4/37) | | B
O’Neal, 1998^32^ Australia 9788255 | 27 | nd | nd | (61–213) | Both general & diabetes (type 2) | Vertical DGUC with light-scattering methodology (size, nm) | GE (size, nm) | 0.78 (<.0001) | Mean size obtained by vertical DGUC were smaller (23.1 vs. 26.1 nm, p<0.0001) than those obtained by GE | B
Davies, 2003^28^ UK 14578318 | 47 | nd | nd | nd | General | Iodixanol DGUC (>51% AUC LDL density >1.028 kg/L) | GE or salt DGUC H (sd LDL-III, or LDL subfraction pattern B) | Sensitivity = 100% Specificity = 100% | | C
Davies, 2003^28^ UK 14578318 | 47 | nd | nd | nd | General | Iodixanol DGUC (peak density >1.028 kg/L) | GE or salt DGUC H (sd LDL-III, or LDL subfraction pattern B) | Sensitivity = 94% Specificity = 92% | | C
HPLC vs. GE
Scheffer, 1997^20^ Netherlands 9342011 | 60 | nd | 231 (135–315) | 209 (45–509) | Diabetes (type 2) | HPLC (size, nm) | GE (size, nm) | 0.88 (<.001) | 0.25 (−0.6 to 1.0) | B

A Pattern A: 20.6–22.0 nm; Intermediate: 20.4–20.5; Pattern B: 19.0–20.3 nm

B Pattern A: LDLSF score <5.5; Intermediate: 5.5–8.5; Pattern B: >8.5

C Large LDL (pattern A): 26.35–28.5 nm; Intermediate LDL (pattern AB): 25.75–26.34 nm; Small LDL (pattern B): 22.0–25.74 nm

D Normal (pattern A): LDLSF score <5.5, Intermediate (pattern AB): 5.5–8.5, Atherogenic (pattern B): >8.5

E Small LDL: Rf>0.40, Intermediate LDL: Rf=0.38–0.40, Large LDL: Rf<0.38

F Small LDL: <25.8 nm, Intermediate LDL: 25.8–26.3 nm, Large LDL: >26.3 nm

G LDL1 (most buoyant) through LDL 6 (most dense): LDL1 and LDL2 comprise pattern A; LDL3 and LDL4 comprise pattern B

H The authors used both salt DGUC and GE as the reference standard in the calculation of the test (iodixanol DGUC) performance

Table 2 Test Variability (or Imprecision)

Author, Year Country UI | N | Population | Tests | N repeated measurements per patient (N selected samples) | Test Variability | | Quality
Author, Year Country UI | N | Population | Tests | N repeated measurements per patient (N selected samples) | How much variability is there in measures of LDL subfractions from day to day? | How much variability is there in measures of LDL subfractions within the same individual (measure to measure)? | Quality
Hoefner, 2001^30^ US 11159775 | 51 | nd | LipoPrint™ (pattern A, intermediate, pattern B based on LDLSF score) B | nd (19) A | | Mean CV = 13% | B
Hoefner, 2001^30^ US 11159775 | 51 | nd | LipoPrint™ (pattern A, intermediate, pattern B based on LDLSF score) B | 10 C (2) | | Intraassay CVs of 4.6% and 4.3% at LDLSF scores of 3.4 and 13.3, respectively | B
Scheffer, 1997^20^ Netherlands 9342011 | 60 | Diabetes (type 2) | GE | n/a (14) D | nd | Between-run CV (or reproducibility), over an 8-week period = 0.6% | B
Scheffer, 1997^20^ Netherlands 9342011 | 60 | Diabetes (type 2) | HPLC (size, nm) | n/a (12) D | nd | Between-run CV (or reproducibility), over an 8-week period = 0.2% | B
Scheffer, 1997^20^ Netherlands 9342011 | 60 | Diabetes (type 2) | HPLC (size, nm) | 2 (10) | nd | Within-run CV <0.1% | B
Scheffer, 1998^21^ Netherlands 9761248 G | 56 | Both general & diabetes (type 2) | HPLC-isolated LDL samples (size, nm) | nd (10) | nd | Between-run CV (or reproducibility) within 4 days E = 0.21% | B
Scheffer, 1998^21^ Netherlands 9761248 G | 56 | Both general & diabetes (type 2) | HPLC-isolated LDL samples (size, nm) | nd (10) | nd | Within-run CV = 0.14% | B
Scheffer, 1998^21^ Netherlands 9761248 G | 56 | Both general & diabetes (type 2) | HPLC-whole plasma samples (size, nm) | nd (10) | nd | Within-run CV = 0.22% | B
Adler, 2000^33^ Canada 10913516 G | 41 | nd | GE-samples separated by UC (peak particle diameter, nm) | n/a (6) | nd | Between-run CV (or reproducibility) = 1.2% | C
Adler, 2000^33^ Canada 10913516 G | 41 | nd | GE-samples separated by UC (peak particle diameter, nm) | n/a (6) | nd | “The intra-assay variation (within a single gel) was 0.2%” F | C
Adler, 2000^33^ Canada 10913516 G | 41 | nd | GE-samples separated by Apo B precipitation (peak particle diameter, nm) | n/a (6) | nd | Between-run CV (or reproducibility) = 1.4% | C
Adler, 2000^33^ Canada 10913516 G | 41 | nd | GE-samples separated by Apo B precipitation (peak particle diameter, nm) | n/a (6) | nd | “The intra-assay variation (within a single gel) was 0.2%” F | C
Jeyarajah, 2006^19^ US 17110242 | nd | Plasma pool A: “high Tg and low HDL” Plasma pool B: “low Tg and high HDL” (pool B) | NMR- aliquoted and frozen samples (LDL concentrations, nmol/L) | Inter-assay precision: 20 consecutive days across 6 different NMR analyzers Intra-assay precision: thawing and analyzing 20 replicates on 1 NMR analyzer | nd | Plasma pool A - total LDL particles (nmol/L): Intra-assay CV = 2.4% Inter-assay CV = 2.1% | C
Jeyarajah, 2006^19^ US 17110242 | nd | Plasma pool A: “high Tg and low HDL” Plasma pool B: “low Tg and high HDL” (pool B) | NMR- aliquoted and frozen samples (LDL concentrations, nmol/L) | Inter-assay precision: 20 consecutive days across 6 different NMR analyzers Intra-assay precision: thawing and analyzing 20 replicates on 1 NMR analyzer | nd | Plasma pool B - total LDL particles (nmol/L): Intra-assay CV = 4.0% Inter-assay CV = 4.3% | C
Jeyarajah, 2006^19^ US 17110242 | nd | Plasma pool A: “high Tg and low HDL” Plasma pool B: “low Tg and high HDL” (pool B) | NMR- aliquoted and frozen samples (LDL sizes, nm) | Inter-assay precision: 20 consecutive days across 6 different NMR analyzers Intra-assay precision: thawing and analyzing 20 replicates on 1 NMR analyzer | nd | Plasma pool A - LDL size (nm): Intra-assay CV = 0.5% Inter-assay CV = 0.4% | C
Jeyarajah, 2006^19^ US 17110242 | nd | Plasma pool A: “high Tg and low HDL” Plasma pool B: “low Tg and high HDL” (pool B) | NMR- aliquoted and frozen samples (LDL sizes, nm) | Inter-assay precision: 20 consecutive days across 6 different NMR analyzers Intra-assay precision: thawing and analyzing 20 replicates on 1 NMR analyzer | nd | Plasma pool B - LDL size (nm): Intra-assay CV = 0.5% Inter-assay CV = 0.6% | C

A 19 subjects with LDL scores ranged from 2.9 to 16.5, assayed on 3 days over a 1-week period

B Pattern A: LDLSF score <5.5; Intermediate: 5.5–8.5; Pattern B: >8.5

C Samples were analyzed in duplication of 10

D Between-run reproducibility for particle diameter was determined by repeatedly analyzing an isolated LDL sample stored in aliquots at −70° C over an 8-week period

E Between-run CVs calculated from measurements performed on different days (not defined but all samples were analyzed within 4 days), using isolated LDL sample stored in aliquots at −86° C

F Unclear how many samples and which separation method were used for the intra-assay variation

G The studies only included for the questions on test variability, not for the comparison of different methods for measuring LDL subfractions

## Question 4

### Question 4.1

#### What is the relationship between LDL subfractions and outcome measures related to CVD?

We evaluated all studies that analyzed the association between LDL subfractions and cardiovascular outcomes. We performed detailed analysis of the studies that used the methods available for clinical use for measuring LDL subfractions. For this section, we searched for and, where available, included eligible studies that used NMR; a specific kit for GE that is available for clinical use (LipoPrint^®^); a specific gradient GE method used at the Berkeley HeartLab^®^; the current method used at the Northwest Lipid Research Lab; and the Vertical Auto Profile^®^ method used by Atherotech.

Ten studies examined the relationships between NMR measured LDL subfractions and cardiovascular outcomes.27,34–42 All NMR studies had their samples run by a single set of researchers at LipoScience^®^ or its precursors. (We do not repeatedly name this company, as is necessary to distinguish the proprietary GE tests, since “NMR” is sufficiently descriptive.)

Eight studies examined the relationships between LipoPrint^®^ GE measured LDL subfractions and cardiovascular outcomes.43–50

One study had their samples analyzed by the Berkeley HeartLab^®^ using what we concluded were the same methods that are available clinically.51

No study that met eligibility criteria used the Vertical Auto Profile^®^. We concluded that none of the studies had their samples performed at the University of Washington's Northwest Lipid Research Laboratory using the currently clinically available methods.

##### NMR measured LDL subfractions

Five nested case-control studies,27,35,37,40,42 four cross-sectional studies,34,36,38,39 and one prospective longitudinal study41 reported on the association between NMR measured LDL subfractions and cardiovascular outcomes. Four studies were of good methodological quality and six were of fair methodological quality. The number of subjects in these studies ranged from 118 to 5538. Many of the studies have slightly different definitions of the LDL size subfractions (eg, one study defined small LDL as 18.3 to 19.7 nm,27 while another study defined small LDL as 18.0 to 21.2 nm40). Some studies enrolled only women (eg, Women's Health Study27) and some studies enrolled only men (eg, VA HDL Intervention Tria I40). Some studies enrolled healthy subjects at baseline and some studies enrolled only patients with diabetes or low HDL cholesterol concentrations. Half of the studies enrolled 40 percent or more patients older than 65 years.

###### Incidence or progression of CVD

Five studies evaluated the association between NMR-measured LDL subfractions and incident CVD or progression of CVD (Tables 3a & 3b).27,35,37,40,42

###### Fatal or nonfatal CVD events

Both good quality nested case-control studies found that LDL particle number was associated with the risk of incident fatal or nonfatal coronary artery disease, or stroke (Blake 2002: adjusted OR 4^th^ quartile compared to 1^st^ quartile = 2.90 (1.16-7.30), P=0.03; El Harchaoui 2007: adjusted OR 4^th^ quartile compared to 1^st^ quartile = 1.37 (1.04-1.83), P=0.02). While the LDL particle size showed unadjusted significant differences between cases and control in these studies, the relative risk comparing different quartiles of particle size failed to demonstrate statistical significance after adjustment for baseline lipid variables. One fair quality study found statistically significant differences between cases (incident myocardial infarction or angina) and control in LDL particle concentration and size in women, but not in men.37 After a bivariate analysis including LDL-cholesterol in the calculation, LDL particle concentration (OR 1.11 per 100 nmol/L, 1.03-1.09) remained significantly different between case and control. The other fair quality study found similar relationships between LDL particle number and the risk of incident myocardial infarction or deaths from coronary artery disease (OR 1.20 (95% CI 1.05-1.37) per 1-SD increment of LDL particle number) in men. The authors reported that adjustment for baseline lipid variables did not “appreciably change these relations” but the actual data were not shown.40

###### Diagnosis of CVD

One fair quality study reported unadjusted significant differences between cases (incident coronary artery disease) and controls in LDL particle size, medium and small LDL. Small and medium size LDL failed to predict incident coronary artery disease in multivariate analysis.42

###### Change in minimum lumen diameter

One fair quality prospective study reported an association between LDL particle size and small LDL with worsening in minimum lumen diameter (Table 4).41 The study reported adjusted ORs of 0.2 (95% CI 0.1- 0.9) for particle size (above vs. below median size) and 9.1 (95% CI 2.1-39) for small LDL (above vs. below median concentration).41

###### Prevalent CVD

Four studies evaluated the association between NMR-measured LDL subfractions and prevalence of CVD (Tables 5a & 5b).34,36,38,39

###### Diagnosis of CVD

One poor quality study found a statistically significant difference between healthy subjects and subjects with CVD in the proportion of large LDL particle (66.5% vs. 43.3%, P=0.001) and particle size (21.4 nm vs. 20.8 nm, P=0.001).34 This study did not report adjustment for differences in baseline lipid measurements.

###### Intermediate markers of CVD

Three fair quality cross-sectional studies analyzed the relationships between LDL subfractions and intermediate markers of prevalent CVD. The first study found that large and small LDL particles were associated with carotid IMT (Change in IMT in microns per one SD = 30.3 for large, and 34.8 for small, both P = 0.001).39 The second study found that there was no association between small LDL with reduction in lumen diameter.36 The third study found that LDL particle number, size, and small LDL were associated with coronary calcification (adjusted OR 1.44 (95% CI 1.04-1.99); 0.55 (95% CI 0.31- 0.99); 1.36 (95% CI 1.04-1.77); respectively, per 1-SD increase in lipoprotein subclass).38

##### Summary

Results from the good and fair quality case-control studies suggest that LDL particle concentration and particle number (as measured by NMR spectroscopy) are associated with incident cardiovascular outcomes. But the association between LDL particle size and incident cardiovascular outcomes is inconsistent; two good and one fair quality case-control studies did not find associations while one fair quality study reported an association in women, but not men.

Two fair quality cross-sectional studies with a total of 5696 patients suggest that small LDL particles are associated with intermediate markers of prevalent CVD while one fair quality study that analyzed 158 patients did not find this association. One fair quality longitudinal study did find an association between small LDL and changes in minimum lumen diameter.

##### LipoPrint^®^ GE-measured LDL subfractions

It is important to note that the intended use for the Lipoprint^®^ test as stated in the manufacturer's product insert is to measure the amount of cholesterol in each of the large buoyant and small dense LDL subfractions. Use of the Lipoprint^®^ kit to determine particle sizes or LDL scores or any other form of classification is not recommended by the manufacturer of the kit. Despite this disclaimer from the manufacturer, the studies cited in the report used the Lipoprint^®^ test to determine CVA risk by measuring lipoprotein subfraction by particle size or complicated LDL scores.

###### Incidence or progression of CVD

No studies evaluated the association between LipoPrint^®^ GE-measured LDL subfractions and incident CVD or progression of CVD.

###### Prevalent CVD

Two case-control studies43,50 (Tables 6a & 6b) and six cross-sectional studies44–49 (Tables 7a & 7b) reported on the association between LipoPrint^®^ GE-measured LDL subfractions and prevalent CVD. Six studies were of fair methodological quality and two were of poor methodological quality. The number of subjects in these studies ranged from 27 to 792. Many of the studies have different definitions of small LDL subfractions (eg, one study defined pattern B as LDL <255 Å,50 while another study defined pattern B as LDL <265 Å45). One study enrolled only men.49 Some studies enrolled subjects without clinical CVD at baseline and some studies enrolled patients with established CVD. Half of the studies enrolled 40 percent or more patients older than 65 years.

###### Diagnosis of CVD

One fair quality case-control study found that LDL pattern B (<255 Å), compared to pattern A or I (intermediate), was associated with prevalent coronary artery disease (recent myocardial infarction or angina) after adjusting for other lipid variables (adjusted OR 4.4 (1.2-16.1), P=0.03).50 A poor quality study on patients with type 2 diabetes found that small LDL was an independent factor in determining the average carotid IMT in a multivariate analysis that included other lipid variables. This multivariate analysis that included a total of 17 variables had only 27 patients.43

Three fair and one poor quality cross-sectional studies analyzed the relationships between LDL subfractions and prevalent CVD. The first study found that there was a statistically significant variation in LDL score (“the relative percentage of the area under the curve of each LDL band was multiplied by its band number, then the sum of all LDL bands present was calculated to produce a final LDL score”) between the subjects who had prevalent coronary artery disease (>50% stenosis in ≥1 major epicardial arteries) and the subjects who did not (P<0.001), after adjusting for triglyceride.49 The second study found that small dense LDL was an independent risk factor for prevalent coronary artery disease (>50% stenosis in ≥1 coronary artery branches) in a multiple logistic regression that included low and high HDL-cholesterol.45 The third study found that LDL score was significantly different between patients who had prevalent carotid atherosclerosis and those who did not in an unadjusted analysis (1.56 vs. 1.26, P=0.04), but a stepwise logistic regression that included other lipid variables rendered the association non-significant (adjusted OR 2.20 (95% CI 0.91-5.29); the odds of higher LDL score in patients with carotid atherosclerosis; the exact units of the OR were not reported).46 The last study found that in patients with type 2 diabetes, those with a history of coronary artery disease (myocardial infarction and/or nitrates, revascularization, or EKG changes) had statistically significantly different small LDL profile (LDL 3 and above) than the patients who did not (overall sum of LDL3 to 5: 16.7 vs. 11.1, P<0.05) in an unadjusted analysis.47

###### Intermediate markers of CVD

Two fair quality cross-sectional studies analyzed the relationships between LDL subfractions and intermediate markers of prevalent CVD. The first study did not find an association between LDL particle size and the measurement of coronary artery calcium (CAC) after adjustment for other lipid variables in a multiple regression.44 The second study did not find an association between LDL particle size and carotid IMT (Pearson correlation r = -0.172, P=0.075).48

##### Summary

Three fair quality studies found an association between small LDL (as measured by LipoPrint^®^ GE) and prevalent CVD or intermediate markers in adjusted analyses. Three fair quality studies did not find such an association. The study populations, definitions of small LDL subfraction, and outcomes evaluated were heterogeneous.

##### Berkeley HeartLab^®^ gradient GE measured LDL subfractions

One fair quality study evaluated the association between gradient GE performed at the Berkeley HeartLab^®^ and cardiovascular outcomes.51 The investigators evaluated the “usual care” arm of a randomized trial of men under age 75 with known coronary artery disease (Table 8). The only outcome evaluated was annual progression, over 4 years, of coronary artery stenosis. They found that the percentage of LDL in the IVb category (220-233 Å) was the strongest predictor of progression among subfractions (including HDL and IDL), also adjusting for lipoprotein concentrations. When LDL IVb was above 5.2 percent, the rate of progression was about six times faster than when LDL IVb was below 2.5 percent. Notably, this association was stronger for patients with baseline stenosis below 30 percent, and the association did not hold for patients with baseline stenosis at or above 30 percent. However, a major caveat to this study is that the LDL subfraction estimates used in the regressions are an average of the baseline and the fourth year data. Thus, the study does not evaluate whether LDL subfractions are a predictor of future coronary artery disease progression, but instead evaluate a difficult to interpret association between LDL subfractions over time and coronary artery stenosis over the same period of time.

##### Summary

One study of men with coronary artery disease found that the average LDL IVb percentage over a 4 year period was associated with an increased rate of coronary artery stenosis over that same period, particularly in artery segments with less than 30 percent stenosis at baseline.

Table 3a Characteristics of the nested case-control studies of incident CVD and NMR-measured LDL subfractions

Author, Year Country UI | Population | Mean Age, A years | >65, A,B % | Male, A % | DM, A % | Smoke, A % | Mean LDL-c, A mg/dL
Blake, 2002^27^ US 12370215 | Women’s Health Study: RCT of aspirin vs. vitamin E vs. placebo. Subjects had baseline blood sample with subsequent cardiovascular event | 60 | ~30 | 0 | 11 | 59 | 129
El Harchaoui, 2007^35^ UK 17276177 | European Prospective Investigation into Cancer and Nutrition (EPIC), age between 45 and 79 years | 65 | ~50 | 64 | 6 | 16 | 164
Kuller, 2002^37^ US 12117734 | Cardiovascular Health Study, Age ≥65 years, noninstitutionalized, 95% White | 73 | 100 | 56 | nd | nd | 129
Otvos, 2006^40^ US 16534013 | Veterans Affairs HDL Intervention Trial (VA-HIT) (gemfibrozil vs. placebo), age <74 years, established CHD, HDL-c≤40 mg/dL, LDL-c≤140 mg/dL, Tg≤300 mg/dL | 64 | ~45 | 100 | 37 | 22 | 113
Soedamah-Muthu, 2003^42^ US 12743701 | Pittsburgh Epidemiology of Diabetes Complications (EDC) study, type 1 DM diagnosed before age 17 years | 35 | 0 | 28 | 100 | 31 | 126

A Of cases in case-control or cross-sectional studies (when reported separately); Data at baseline

B ~ = estimated from mean and standard deviation, otherwise reported value (rounded to nearest 5%)

Table 3b Nested case-control studies of incident CVD and NMR-measured LDL subfractions

Author Year Country UI | Population | Definitions | Cases | Control | P | Other results | Quality
Blake 2002^27^ US 12370215 | Women’s Health Study | Case=death due to CAD, nonfatal MI, or stroke | n=130 | n=130 | | Risks of event (adjusted for Tg and TC/HDL-c) 4^th^ quartile compared to 1^st^ quartile: | A
Blake 2002^27^ US 12370215 | Women’s Health Study | Large: 213–227 Å | 886 A (nmol/L) | 1001 | 0.50 | | A
Blake 2002^27^ US 12370215 | Women’s Health Study | Medium: 198–212 Å | 201 | 126 | .008 | | A
Blake 2002^27^ US 12370215 | Women’s Health Study | Small: 183–197 Å | 0 | 0 | .80 | | A
Blake 2002^27^ US 12370215 | Women’s Health Study | LDL particle concentration | 1597 | 1404 | <.001 | RR=2.90 (1.16, 7.30) P=.03 | A
Blake 2002^27^ US 12370215 | Women’s Health Study | LDL particle size, Å | 215 | 218 | .046 | RR=1.20 (0.51, 2.82) P=.70 | A
El Harchaoui, 2007^35^ UK 17276177 | EPIC (European prospective cancer and nutrition study) | Case=fatal or nonfatal CAD | n=1003 | n=1885 | | Adjusted risks of event, per quartile of risk factor | A
El Harchaoui, 2007^35^ UK 17276177 | EPIC (European prospective cancer and nutrition study) | Large: 212–230 Å | 43 (nmol/L) | 36 | .003 | | A
El Harchaoui, 2007^35^ UK 17276177 | EPIC (European prospective cancer and nutrition study) | Medium: nd | 568 | 572 | 0.60 | | A
El Harchaoui, 2007^35^ UK 17276177 | EPIC (European prospective cancer and nutrition study) | Small: 180–212 Å | 999 | 885 | <.0001 | | A
El Harchaoui, 2007^35^ UK 17276177 | EPIC (European prospective cancer and nutrition study) | LDL particle concentration | 1640 | 1525 | <.0001 | OR=1.37 (1.04, 1.83) P=.02 adjusted for HDL-c, Tg | A
El Harchaoui, 2007^35^ UK 17276177 | EPIC (European prospective cancer and nutrition study) | LDL particle size, Å | 210 | 211 | .002 | OR= 0.86 (0.65, 1.15) P=.50 adjusted for LDL particle concentration | A
Kuller, 2002^37^ US 12117734 | CV Health Study | Case=incident MI & no stroke before MI; incident angina & no stroke or MI | Women n=191 | Women n=182 | | Risks of event, adjusted for age, race, LDL-c, per quartile of risk factor | B
Kuller, 2002^37^ US 12117734 | CV Health Study | Large: 213–230 Å | 96 (mg/dL cholesterol) | 104 | NS | | B
Kuller, 2002^37^ US 12117734 | CV Health Study | Medium: 198–212 Å | 8.2 | 6.8 | NS | | B
Kuller, 2002^37^ US 12117734 | CV Health Study | Small: 183–197 Å | 7.1 | 0 | <.05 | | B
Kuller, 2002^37^ US 12117734 | CV Health Study | LDL particle concentration | 1680 | 1501 | <.05 | OR=1.11 (1.03, 1.09) per 100 nmol/L P<.05 | B
Kuller, 2002^37^ US 12117734 | CV Health Study | LDL particle size, Å | 213 | 216 | <.05 | nd | B
Kuller, 2002^37^ US 12117734 | CV Health Study | | Men n=243 | Men n=67 | | | B
Kuller, 2002^37^ US 12117734 | CV Health Study | Large: 213–230 Å | 57.3 | 58 | NS | | B
Kuller, 2002^37^ US 12117734 | CV Health Study | Medium: 198–212 Å | 36 | 34.5 | NS | | B
Kuller, 2002^37^ US 12117734 | CV Health Study | Small: 183–197 Å | 25.7 | 22.7 | NS | | B
Kuller, 2002^37^ US 12117734 | CV Health Study | LDL particle concentration | 1676 | 1597 | NS | nd | B
Kuller, 2002^37^ US 12117734 | CV Health Study | LDL particle size, Å | 209 | 210 | NS | nd | B
Otvos, 2006^40^ US 16534013 | VA patient with CHD; LDL-c≤140 mg/dL; HDL-c≤40 mg/dL; Tg≤300 mg/dL | Case=New nonfatal MI or CHD death | n=364 | n=697 | | Risks of event, adjusted for treatment group, age, HTN, smoking, BMI and DM; Adjustment for LDL-c, HDL-c, and Tg did not “appreciably change these relations [nd]).” per 1 SD increase in parameter | B
Otvos, 2006^40^ US 16534013 | VA patient with CHD; LDL-c≤140 mg/dL; HDL-c≤40 mg/dL; Tg≤300 mg/dL | Large: 212–230 Å | | | nd | OR=1.08 (0.95–1.23) NS | B
Otvos, 2006^40^ US 16534013 | VA patient with CHD; LDL-c≤140 mg/dL; HDL-c≤40 mg/dL; Tg≤300 mg/dL | Small: 180–212 Å | | | nd | OR=1.11 (0.98–1.27) NS | B
Otvos, 2006^40^ US 16534013 | VA patient with CHD; LDL-c≤140 mg/dL; HDL-c≤40 mg/dL; Tg≤300 mg/dL | LDL particle concentration | | | nd | OR=1.20 (1.05–1.37) P<.05 | B
Otvos, 2006^40^ US 16534013 | VA patient with CHD; LDL-c≤140 mg/dL; HDL-c≤40 mg/dL; Tg≤300 mg/dL | LDL particle size, Å | | | nd | OR=0.97 (0.85–1.10) NS | B
Soedamah-Muthu 2003^42^ US 12743701 | Prospective study of type 1 DM | Case=CAD | n=59 (nmol/L cholesterol) | n=59 | | Small, medium and total LDL particle concentration failed to predict CAD independently in multivariate analysis (included Tg, HDL particle number in analysis). | B
Soedamah-Muthu 2003^42^ US 12743701 | Prospective study of type 1 DM | Large: 213–230 Å | 603 | 688 | NS | Small, medium and total LDL particle concentration failed to predict CAD independently in multivariate analysis (included Tg, HDL particle number in analysis). | B
Soedamah-Muthu 2003^42^ US 12743701 | Prospective study of type 1 DM | Medium: 198–212 Å | 120 | 111 | ≤.01 | Small, medium and total LDL particle concentration failed to predict CAD independently in multivariate analysis (included Tg, HDL particle number in analysis). | B
Soedamah-Muthu 2003^42^ US 12743701 | Prospective study of type 1 DM | Small: 183–197 Å | 800 | 526 | ≤.001 | Small, medium and total LDL particle concentration failed to predict CAD independently in multivariate analysis (included Tg, HDL particle number in analysis). | B
Soedamah-Muthu 2003^42^ US 12743701 | Prospective study of type 1 DM | LDL particle size, Å | 206 | 210 | ≤.01 | Small, medium and total LDL particle concentration failed to predict CAD independently in multivariate analysis (included Tg, HDL particle number in analysis). | B

A median

Table 4 Longitudinal study of NMR-measured LDL subfractions and progression of CVD

Author Year Country UI | Population | Mean Age, A years | >65, A,B % | Male, A % | DM, A % | Smoke, A % | Mean LDL-c, A mg/dL
Rosenson 2002 41 US 12106834 | Pravastatin Limitation of Atherosclerosis in the Coronary Arteries (PLAC-I) trial, completed 3 years in the RCT, frozen plasma and coronary angiogram at baseline Patients with CAD in RCT of pravastatin (n=130) vs. placebo (n=111) | 58 | ~20 | 76 | nd | nd | 163
Rosenson 2002 41 US 12106834 | | Outcome | Definitions | Results | | | Quality
Rosenson 2002 41 US 12106834 | | Change in minimum lumen diameter (MLD) over 3 years n=241 | | Spearman correlations, adjusted for LDL-c, HDL-c, Tg and other factors | | | B
Rosenson 2002 41 US 12106834 | | Change in minimum lumen diameter (MLD) over 3 years n=241 | Large: 213–230 Å | 0.03 (NS) | | | B
Rosenson 2002 41 US 12106834 | | Change in minimum lumen diameter (MLD) over 3 years n=241 | Medium: 198–212 Å | nd | | | B
Rosenson 2002 41 US 12106834 | | Change in minimum lumen diameter (MLD) over 3 years n=241 | Small: 183–197 Å | −0.17 (P<0.01) | | | B
Rosenson 2002 41 US 12106834 | | Progression of MLD: ↓MLD>0.07 mm/y, over 3 years n=111 (placebo arm only) | | Risk of progression, adjusted for LDL-c, HDL-c, Tg and other factors | | | B
Rosenson 2002 41 US 12106834 | | Progression of MLD: ↓MLD>0.07 mm/y, over 3 years n=111 (placebo arm only) | Large: 213–230 Å | ≥84 mg/dL vs.<84 mg/dL OR=0.4 (0.1–1.4) NS | | | B
Rosenson 2002 41 US 12106834 | | Progression of MLD: ↓MLD>0.07 mm/y, over 3 years n=111 (placebo arm only) | Small: 183–197 Å | ≥30 mg/dL vs.<30 mg/dL OR=9.1 (2.1–39) P<.05 | | | B
Rosenson 2002 41 US 12106834 | | Progression of MLD: ↓MLD>0.07 mm/y, over 3 years n=111 (placebo arm only) | LDL particle concentration | ≥1825 vs.<1825 OR= 1.4 (0.3–6.7) NS | | | B
Rosenson 2002 41 US 12106834 | | Progression of MLD: ↓MLD>0.07 mm/y, over 3 years n=111 (placebo arm only) | LDL particle size | ≥200 vs <200 Å OR=0.2 (0.10.9) P<.05 | | | B

A Of cases in case-control or cross-sectional studies (when reported separately); Data at baseline

B ~ = estimated from mean and standard deviation, otherwise reported value (rounded to nearest 5%)

Table 5a Characteristics of patients in the cross-sectional studies of prevalent CVD and NMR-measured LDL subfractions

Author Year Country UI | Population | Mean Age, A years | >65, A,B % | Male, A % | DM, A % | Smoke, A % | Mean LDL-c, A mg/dL
Mora 2007^39^ US 16765964 | Multi-Ethnic Study of Atherosclerosis (MESA), age 45–84 years, no self-reported CHD, from 6 centers | 61 | ~40 | 47 | 12 | 14 | 120
Freedman 1998^36^ US 9672064 | Men admitted for coronary angiogram (severe or unstable angina, myocardial ischemia after MI, recurrent chest pain of unknown origin), did not use cholesterol-lowering medications, Tg<400 | 63 | ~40 | 100 | 20 | nd | 129
Mackey 2002^38^ US 12419483 | Women 8 years postmenopause; were premenopausal when enrolled into the Healthy Women Study (HWS) | 62 | ~5 | 0 | nd | 13 | 128
Barzilai 2003^34^ US 14559957 | Offspring and spouses of offspring of Ashkenazi Jews with exceptional longevity (mean age 98 years) | 69 | nd | 44 | nd | nd | nd

A Of cases in case-control or cross-sectional studies (when reported separately); Data at baseline

B ~ = estimated from mean and standard deviation, otherwise reported value (rounded to nearest 5%)

Table 5b Cross-sectional studies of NMR-measured LDL subfractions and prevalent CVD outcomes

Author Year Country UI | Population | Outcome | Definitions | Results | Quality
Mora 2007^39^ US 16765964 | No self-reported CVD n=5538 | Carotid IMT | | Association, adjusted for LDL subfractions, age, sex, race, HTN, smoking, LDL-c, HDL-c, and Tg ΔIMT per one SD of parameter | B
Mora 2007^39^ US 16765964 | No self-reported CVD n=5538 | Carotid IMT | Large: 212–230 Å | +30.3 (11.9, 48.7) P<.05 | B
Mora 2007^39^ US 16765964 | No self-reported CVD n=5538 | Carotid IMT | Small: 180–212 Å | +34.8 (15.0, 54.6) P<.05 | B
Freedman 1998^36^ US 9672064 | Admitted for angiography n=158 | Coronary lumen diameter (occlusion score) | | Association, adjusted for age, LDL-c, HDL-c, Tg | B
Freedman 1998^36^ US 9672064 | Admitted for angiography n=158 | Coronary lumen diameter (occlusion score) | Large: 230–300 Å (including IDL) | Correlation with occlusion score: −0.12 (NS) (also adjusted for age in addition to lipid variables) | B
Freedman 1998^36^ US 9672064 | Admitted for angiography n=158 | Coronary lumen diameter (occlusion score) | Small: 180–205 Å | <20 vs. ≥20 mg/dL OR=1.8 NS | B
Mackey 2002^38^ US 12419483 | Postmenopausal n=286 | Coronary calcification (CAC category) | | Risk of a higher CAC category, adjusted for LDL-c and Tg, per 1 SD increase in parameter | B
Mackey 2002^38^ US 12419483 | Postmenopausal n=286 | Coronary calcification (CAC category) | Large: 213–230 Å | OR=1.03 (0.77–1.39) NS | B
Mackey 2002^38^ US 12419483 | Postmenopausal n=286 | Coronary calcification (CAC category) | Medium: 198–212 Å | OR=0.78 (0.60–1.02) NS | B
Mackey 2002^38^ US 12419483 | Postmenopausal n=286 | Coronary calcification (CAC category) | Small: 183–197 Å | OR=1.36 (1.04–1.77) P<.05 | B
Mackey 2002^38^ US 12419483 | Postmenopausal n=286 | Coronary calcification (CAC category) | LDL particles | OR=1.44 (1.04–1.99) P<.05 | B
Mackey 2002^38^ US 12419483 | Postmenopausal n=286 | Coronary calcification (CAC category) | LDL size | OR=0.55 (0.31–0.99) P<.05 | B
Barzilai 2003^34^ US 14559957 | Offspring of Ashkenazi Jews with longevity n=229 | Prevalent CVD | | Unadjusted associations (Cases, n=20 vs healthy, n=209) | C
Barzilai 2003^34^ US 14559957 | Offspring of Ashkenazi Jews with longevity n=229 | Prevalent CVD | Large: 213–230 Å | 66.5% vs 43.3% P=.001 | C
Barzilai 2003^34^ US 14559957 | Offspring of Ashkenazi Jews with longevity n=229 | Prevalent CVD | Medium: 198–212 Å | nd | C
Barzilai 2003^34^ US 14559957 | Offspring of Ashkenazi Jews with longevity n=229 | Prevalent CVD | Small: 183–197 Å | nd | C
Barzilai 2003^34^ US 14559957 | Offspring of Ashkenazi Jews with longevity n=229 | Prevalent CVD | Particle size, Å | 214 vs 208 P=.001 | C

Table 6a Characteristics of case-control studies of prevalent CVD and LipoPrint GE-measured LDL subfractions

Author Year Country UI | Population | Mean Age A, years | >65, A,B % | Male, A % | DM, A % | Smoke, A % | Mean LDL-c A (mg/dL)
Yoon 2005^50^ S. Korea 15899660 | Consecutive patients who underwent coronary angiogram, age <80 years, not on lipid-lowering drugs, recent MI or angina, with or without type 2 DM, blood sample obtained 2 months after MI | 59 | ~20 | 72 | 26 | 29 | 122
Inukai 2005^43^ Japan 16112502 | Type 2 DM, 26% on statin | 63 | ~40 | 52 | 100 | nd | 118

A Of cases in case-control or cross-sectional studies (when reported separately); Data at baseline

B ~ = estimated from mean and standard deviation, otherwise reported value (rounded to nearest 5%)

Table 6b Case-control studies of LipoPrint GE-measured LDL subfractions and prevalent CVD

Author Year Country UI | Population | Definitions | Cases | | Controls | Unadjusted P Value | Other Results (Including Multivariable Analyses) | Quality
Yoon 2005^50^ S. Korea 15899660 | CHD ± type 2 DM | | CHD only (n=100) | CHD with DM (n=35) | n=88 | | Association with prevalent CHD, adjusted for TC, HDL-c, LDL-c, Tg and other factors | B
Yoon 2005^50^ S. Korea 15899660 | CHD ± type 2 DM | Pattern B prevalence | 54% | 62% | 10% | <0.05 | OR=4.4 (1.2, 16) P=.03 (vs. pattern A) | B
Yoon 2005^50^ S. Korea 15899660 | CHD ± type 2 DM | Mean±SD LDL size, Å | 252±14 | 249±16 | 262±14 | <0.05 | nd | B
Inukai 2005^43^ Japan 16112502 | Type 2 DM | | Increased average IMT (≥1 mm) (n=16) | | Normal average IMT (<1 mm) (n=11) | | Independent risk factors for determining average IMT, adjusted for Tg, HDL-c, LDL-c and other variables; unit of analysis not reported | C
Inukai 2005^43^ Japan 16112502 | Type 2 DM | Small LDL (mg/dL): subfractions 3–7 | 107±28 | | 68±21 | <0.01 | OR=1.61 P=.01 | C
Inukai 2005^43^ Japan 16112502 | Type 2 DM | Mean±SD Small LDL / Total LDL | 0.81±0.13 | | 0.69±0.11 | <0.05 | OR=1.59 P=.03 | C

Table 7a Characteristics of patients in the cross-sectional studies of prevalent CVD and LipoPrint GE-measured LDL subfractions

Author Year Country UI | Population | Mean Age A, years | >65, A,B % | Male, A % | DM, A % | Smoke, A % | Mean LDL-c A (mg/dL)
Kullo 2004^44^ US 15363830 | Genetic Epidemiology Network of Arteriopathy (GENOA) study, community-based, Sibships with ≥2 full siblings with essential HTN before the age of 60; measurement of coronary artery calcium (CAC), excluded those with history of CABG or PTCA (previous MI or stroke okay) | 62 | ~40 | 41 | 16 | 49 | 119
Rajman 1996^49^ UK 8842354 | Men who had coronary angiogram, Tg≤204 mg/dL, no lipid lowering drugs, no DM, no kidney disease, no MI or CABG within 6 weeks prior to angiogram | 61 | ~30 | 100 | 0 | 16 | 160
Park 2006^48^ Korea 17142132 | Subjects who visited a health screening program, no CVD, no DM, not on treatments with cardiovascular medications (not defined) that might interfere with measurements | 52 | ~5 | 35 | 0 | 22 | 119
Kwon 2006^45^ S. Korea 16807992 | Patients who underwent coronary angiogram, no MI, no ESRD, no liver failure, excluded those who had previous coronary angiograms | 60.4 | ~45 | nd | 22 | 34 | 106
Landray 1998^46^ UK 9709468 | Patients with stroke, TIA, amaurosis fugax, or presyncope referred for carotid ultrasonography | 62.4 | ~40 | 65 | 18 | 72 | nd
Mohan 2005^47^ India 15847025 | Study sample randomly drawn from Chennai Urban Rural Epidemiology Study (CURES), type 2 DM with or without CAD (history of MI and/or nitrates or revascularization or ECG changes) | 57 | ~20 | 50 | 100 | nd | 131

A Of cases in case-control or cross-sectional studies (when reported separately); Data at baseline

B ~ = estimated from mean and standard deviation, otherwise reported value (rounded to nearest 5%)

Table 7b Cross-sectional studies of LipoPrint GE-measured LDL subfractions and prevalent CVD

Author Year Country UI | Population | Outcome | Definitions | Results | Quality
Kullo 2004^44^ US 15363830 | Sibships with ≥2 full siblings with essential HTN before age 60 years n=792 | Coronary artery calcium (CAC) | | Associations with CAC, unit not defined | B
Kullo 2004^44^ US 15363830 | Sibships with ≥2 full siblings with essential HTN before age 60 years n=792 | Coronary artery calcium (CAC) | LDL particle size | Unadjusted Women: OR=0.94 (0.90, 0.99) P=.008 Men: OR=1.02 (0.97, 1.07) NS | B
Kullo 2004^44^ US 15363830 | Sibships with ≥2 full siblings with essential HTN before age 60 years n=792 | Coronary artery calcium (CAC) | LDL particle size | Adjusted for HDL-c, Tg, and conventional risk factors Women: OR=0.98 (0.92,1.04) NS Men: OR=1.02 (0.96, 1.08) NS | B
Rajman 1996^49^ UK 8842354 | Men who had coronary angiogram n=68 | Prevalent CAD | LDL score A | Correlation, r = 0.49 P<0.001 Score: 1.48 (CAD) vs 0.96 (no CAD) P<.001 Adjusted for Tg, P<.001 | B
Rajman 1996^49^ UK 8842354 | Men who had coronary angiogram n=68 | No. of diseased vessels | LDL score A | Correlation, r = 0.46 P<0.001 | B
Rajman 1996^49^ UK 8842354 | Men who had coronary angiogram n=68 | History of MI | LDL score A | Compared to no history of MI, NS (data not shown). | B
Park 2006^48^ S. Korea 17142132 | Preclinical nondiabetic patients n=136 | Carotid IMT | LDL particle size | Pearson correlation = −0.172 P=0.08 | B
Kwon 2006^45^ S Korea 16807992 | Subjects who had angiogram n=504 (262 cases, 242 controls) | Prevalent CAD | Pattern B | 49% (cases) vs 26% (controls) P<.001 | B
Kwon 2006^45^ S Korea 16807992 | Subjects who had angiogram n=504 (262 cases, 242 controls) | Prevalent CAD | Small dense LDL: subtypes 3–7 divided by subtypes 1–7 | 18% (cases) vs 12% (controls) P<.001 Adjusted for LDL-c, HDL-c, and other risk factors, vs. less dense LDL: OR=2.3 (1.5, 3.5) P<.001 | B
Kwon 2006^45^ S Korea 16807992 | Subjects who had angiogram n=504 (262 cases, 242 controls) | Prevalent CAD | LDL particle size, Å | 264.1 (cases) vs 267.3 (controls) P<.001 | B
Landray 1998^46^ UK 9709468 | Stroke, TIA, presyncope or amaurosis fugax referred for ultrasonography n=79 | Carotid atherosclerosis | LDL Score B | 1.56 (disease) vs 1.26 (no disease) P=.04 Adjusted for TC, Tg, OR=2.20 (0.91–5.29) NS, unit of analysis not reported | B
Mohan 2005^47^ India 15847025 | Type 2 DM N=60 | Prevalent CAD | LDL 3 | 12.2 (CAD) vs 9.6 mg/dL NS | C
Mohan 2005^47^ India 15847025 | Type 2 DM N=60 | Prevalent CAD | LDL 4 | 3.7 (CAD) vs 1.5 P<.05 | C
Mohan 2005^47^ India 15847025 | Type 2 DM N=60 | Prevalent CAD | LDL 5 | 0.79 (CAD) vs 0.06 P<.05 | C
Mohan 2005^47^ India 15847025 | Type 2 DM N=60 | Prevalent CAD | Small LDL (LDL ≥3) | 16.7 (CAD) vs 11.1 P<.05 | C

A “The relative percentage of the [area under the curve] of each LDL band was multiplied by its band number. The sum of all LDL bands present was calculated to produce a final LDL score.”

B Area under the curve of each LDL band multiplied by its band number for bands 1–6.

Table 8 Longitudinal study of time-averaged Berkeley HeartLab GE-measured LDL subfractions and progression of CVD

Author Year Country UI | Population | Mean Age, A years | >65, A % | Male, A % | DM, A % | Smoke, A % | Mean LDL-c, A mg/dL
Williams 2003^51^ US 12588777 | Men with CAD <age 75, under “usual care” (n=106) | 56 | 100 | 100 | nd | nd | 151
Williams 2003^51^ US 12588777 | Men with CAD <age 75, under “usual care” (n=106) | Outcome | Definitions | Results | | | Quality
Williams 2003^51^ US 12588777 | Men with CAD <age 75, under “usual care” (n=106) | Annualized rate of stenosis (%/year), 4 years | Small LDL mass (S_f_0–7), mg/dL | Regression slope=0.006, P=0.09 | | | B
Williams 2003^51^ US 12588777 | Men with CAD <age 75, under “usual care” (n=106) | Annualized rate of stenosis (%/year), 4 years | Large LDL mass (S_f_7–12), mg/dL | Regression slope=0.002, NS | | | B
Williams 2003^51^ US 12588777 | Men with CAD <age 75, under “usual care” (n=106) | Annualized rate of stenosis (%/year), 4 years | LDL peak diameter, nm | Regression slope=−0.391, NS | | | B
Williams 2003^51^ US 12588777 | Men with CAD <age 75, under “usual care” (n=106) | Annualized rate of stenosis (%/year), 4 years | LDL IIIb (242–247Å), % | Regression slope=0.149, P=0.06 (P=0.02 if baseline stenosis <30%; NS if ≥30%) | | | B
Williams 2003^51^ US 12588777 | Men with CAD <age 75, under “usual care” (n=106) | Annualized rate of stenosis (%/year), 4 years | LDL IVb (220–233Å), % | Regression slope=0.238, P=0.01 (P=0.002 if baseline stenosis <30%; NS if ≥30%) (Adjusted for other lipoproteins, P=0.06 overall; P<0.05 if stenosis <30%; NS if stenosis ≥30%; the best fitting multivariable model with lipoproteins includes only LDL IVb, among subfractions) | | | B
Williams 2003^51^ US 12588777 | Men with CAD <age 75, under “usual care” (n=106) | Annualized rate of stenosis (%/year), 4 years | LDL IVb, quartiles (2.5%, 3.7%, 5.2%) | Trend for more rapid stenosis with increasing quartile, P=0.04 4^th^ vs 1^st^ quartiles: Rate ~6× greater, P=0.03; stronger association if stenosis <30%; NS if stensosis≥30% | | | B
Williams 2003^51^ US 12588777 | Men with CAD <age 75, under “usual care” (n=106) | Annualized rate of stenosis (%/year), 4 years | LDL I, IIa, IIb, IIIa, or IVa, % | NS | | | B

A Data at baseline

#### Other methods to measure LDL subfractions

As described above, full data extraction and study analysis were performed only on those studies that used methods available for clinical use to measure LDL subfractions. We performed only limited extraction of other studies. We did not extract detailed results, nor did we assess study quality. We extracted only data presented in Tables 9–13. Measurements of LDL subfractions were classified as “size” (measured in angstroms), “pattern” (where the measurement was of a described pattern based on subfraction distribution or of a specific subfraction such as small dense LDL). In an overall summary table described below, NMR measurements of LDL subfraction number (or concentration) are classified as “number.” Within each classification, the magnitude and statistical association between the LDL subfraction and the CVD outcome are presented as symbols as described in Table 9 and following. Analyses that were unadjusted or adjusted for LDL or HDL cholesterol, triglycerides, or other commonly used lipid measurements are separated (and given different symbols). Note that analyses that are categorized here as unadjusted may have been adjusted for such factors as treatment, demographics, or past medical history, but not lipids. We ignored adjustments for other lipid subfractions.

##### Results

Forty-one studies evaluated the associations between LDL subfraction measurements and CVD outcomes using measurement methods not clinically available. Among these, 30 used GE, 8 used ultracentrifugation, 2 used HPLC, and 1 did not report its methodology; 32 measured the size of the LDL particles and 29 evaluated different patterns. Seven studies evaluated incident CVD events in 5 nested case control studies and 2 prospective longitudinal studies (Table 9); followup occurred at averages ranging from 3.5 to 13 years. Five studies evaluated progression of coronary artery disease (Table 10), measured by angiography, in prospective longitudinal studies; followup occurred between 2 and 5 years. Twenty studies evaluated prevalent coronary artery disease in 16 case control studies and 4 prospective cohort studies (Table 11). Eight studies evaluated prevalent carotid atherosclerotic disease, primarily measuring IMT, in 1 case control study and 7 prospective cohort studies (Table 12). Lastly, a singly study evaluated prevalent cerebrovascular disease (silent lacunar infarcts) in a prospective cohort study (Table 13).

These additional studies were generally consistent with the studies that evaluated LipoPrint^®^ GE or NMR. They evaluated a wide range of populations, including those with and without baseline CVD, with various comorbidities, on a wide range of medications (though this was generally not explicitly described). In most studies, participants tended to be relatively young. Eighteen studies included very few or no subjects above age 65 years; 3 studies had more than half the subjects over age 65 years, none of which included only older subjects.

Tables 14–16 summarize findings across all studies (including those that used the clinically available methods). Table 14 summarizes the studies that reported unadjusted analyses of LDL subfractions and cardiovascular outcomes, Table 15 summarizes the studies that reported analyses of LDL subfractions and cardiovascular outcomes adjusted for lipid and other cardiovascular risk factors, and Table 16 summarizes the studies that reported both unadjusted and adjusted analyses of LDL subfractions and cardiovascular outcomes. For the purpose of these analyses, the many specific measurements were categorized as being measurements of LDL subfraction size, number, or pattern. The numbers of studies that reported statistically significant “positive” or “negative” associations or no significant associations are summarized. Only those studies that reported associations not adjusted for other cardiovascular risk factors are included in Table 14; only those studies that reported associations that were adjusted for other cardiovascular risk factors are included in Table 15; and only studies that reported both unadjusted and adjusted associations are included in Table 16.

###### Unadjusted analyses

Looking at Table 14 alone, the majority of studies found that LDL subfraction size, number, and patterns were significantly associated with CVD outcomes. Overall, 64 percent of analyses found statistically significant associations with incident CVD or progression, and 78 percent with prevalent CVD. Interestingly, a minority of studies found that larger LDL subfractions were associated with prevalent disease (10 percent). There were no obvious factors among these seven studies to explain this heterodox finding, other than chance.

###### Lipid-adjusted analyses

Given the wide variety of participants across the studies, particularly that many studies included very narrow populations (eg, cases and controls selected among patients having coronary angiograms, patients with a history of myocardial infarction before age 45) and that many studies were case control (ie, matched retrospective), the unadjusted analyses may be misleading. Particularly, given that the major potential treatments for abnormal LDL subfractions also treat dyslipidemias, it is important to evaluate the lipid-adjusted associations to have a better understanding of the clinical value of LDL subfractions. Only half the number of lipid-adjusted analyses were performed as unadjusted analyses. The distribution of statistically significant and nonsignificant associations was more evenly split among these analyses; 50 percent of analyses found significant adjusted associations with incident CVD or progression, and 58 percent with prevalent CVD. Only 1 adjusted analysis found a significant association between larger subfractions and prevalent CVD. An important caveat to these analyses, though, is that studies used different statistical (or clinical) methods to determine which variables would be adjusted for, including the various lipoprotein cholesterol and triglyceride concentrations, lipid ratios, along with other CVD risk factors (such as blood pressure) and other variables (such as demographics). It is impossible to evaluate how the distribution of findings would have changed had all researchers used the same analytic technique.

Importantly, many of these adjusted analyses were reported without presenting the unadjusted analyses. To understand the impact of adjustment on the findings of significant associations, we evaluated how findings changed within those studies that reported both the unadjusted and lipid-adjusted analyses (Table 16). As displayed in the striped columns to the right of the table, possible findings within studies include similar conclusions regardless of adjustment (the grey columns) or changes between significant and nonsignificant associations after adjustment (the white columns). Among the 17 analyses that found a statistically significant unadjusted association between LDL subfractions and incident CVD or progression (▽ in the table), 8 (47 percent) became nonsignificant after adjusting for lipid and other factors; 5 analyses remained nonsignificant regardless of adjustment. Among the 27 analyses that found a statistically significant unadjusted association between smaller LDL subfractions and prevalent CVD, 10 (37 percent) became nonsignificant after adjusting for lipid and other factors; 1 analysis remained nonsignificant regardless of adjustment, 1 nonsignificant unadjusted analysis was statistically significant after adjustment, and 2 analyses that found an association between larger LDL subfractions and CVD both lost significance after adjustment.

###### Summary of specific measures

To further understand whether there are specific measures of LDL sub fractions that are associated with CVD outcomes, we focused on those studies that evaluated GE or NMR for incident CVD or progression of CVD in lipid-adjusted analyses (studies had to adjust for lipoprotein cholesterol or triglycerides, they may also have adjusted for other CVD risk factors). We chose these studies for clinical reasons, as these are the measures that could be available to clinicians and the outcomes of interest to clinicians and patients, if treatment options are being considered.

None of the studies of the clinically available GE evaluated incident CVD or progression. We evaluated the other GE studies under the assumption that the specific measurements would be available using all GE methods. Eight GE studies and six NMR studies reported lipid-adjusted associations with incidence or progression of cvD.27,35,37,40–42,51–58 GE and NMR results are analyzed separately.

Six GE studies evaluated LDL particle size,52–56,58 four of which found no significant adjusted association with CVD. Three GE studies analyzed the percent of LDL which was defined as small; though each used a different definition for small LDL: less than 228 Å, between 220 and 233 Å (LDL IVb), or less than 255 Å.51,56,57 The study that measured the smallest particles (less than 228 Å) found no significant association,56 in contrast with the other two studies. Despite the generally common use of describing peoples as having LDL Pattern A or B (or intermediate), only one GE study of incident CVD performed lipid-adjusted analyses. This study found no significant association with Pattern B (defined as less than 258 Å).58 Two GE studies evaluated both size and another measure, but both found no association with CVD with either measure evaluated.56,58 Overall, none of the specific measures of LDL subfractions determined by GE consistently was associated with incidence or progression of CVD after adjustment for lipid concentrations.

The most common measurement by NMR was concentration of LDL particles. The four studies that evaluated incident disease all found a significant lipid-adjusted association between LDL particle concentration and CVD,27,35,37,40 in contrast with the one evaluation of CVD progression, which found no association.41 Three studies each evaluated LDL particle size27,40,41 and small LDL particles (defined as either 183 to 197 Å in two studies or 180 to 212 Å in one).40–42 For both measures, only one study41 found a statistically significant association (with progression of CVD); the other studies found no significant associations with incident CVD with either measure. Three NMR studies evaluated both LDL particle size and concentration; two of which also evaluated small LDL (defined differently).27,40,41 The two studies of CVD incidence were consistent in finding that concentration was significantly associated with CVD, but not particle size (or small LDL in one study). The study of CVD progression had the opposite finding, that size and small LDL, but not concentration, were associated with CVD.

In summary, only LDL particle concentration, as measured by NMR, was consistently found to be associated with incident CVD after adjustment for lipids (and other risk factors). Other specific measures have been found to be associated with incidence or progression of CVD by only a minority of studies.

Table 9 Association between LDL Subfraction and incident CVD events (not full extraction)

▽/▼ Smaller particles associated with more CAD outcome: Statistically significant association in unadjusted (unadj)/adjusted (adj) analysis ⚪/⚪ No statistically significant association in unadjusted (unadj)/adjusted (adj) analysis △/▲ Larger particles associated with more CAD outcome: Statistically significant association in unadjusted (unadj)/adjusted (adj) analysis [image]/[image] An association was reported, but no statistical analysis was performed
Author Year Country UI | Test Category A Study Design | Mean Age B | %>65 C | %Male B | %DM B | %Smoke D | LDL-c B (mg/dL) | | Group (Arm) | N | Follow-up Time | Outcome (Definition) | | Predictor | Results
Author Year Country UI | Test Category A Study Design | Mean Age B | %>65 C | %Male B | %DM B | %Smoke D | Subfraction Data | | Group (Arm) | N | Follow-up Time | Outcome (Definition) | | Predictor | Unadj | Adj
Howard 2000^59^ US 10712410 | nd | 56 | ~15 | nd | 47 | 35c | LDL-c | 113 | American Indian | 3668? or 4378? E | mean 4.8 yr | Fatal and nonfatal CVD event | Women | Size | ▽
Howard 2000^59^ US 10712410 | Prospective longitudinal | 56 | ~15 | nd | 47 | 35c | mean 259.1 Å | | American Indian | 3668? or 4378? E | mean 4.8 yr | Fatal and nonfatal CVD event | Men | Size | ⚪
Howard 2000^59^ US 10712410 | Prospective longitudinal | 56 | ~15 | nd | 47 | 35c | mean 259.1 Å | | American Indian | 3668? or 4378? E | mean 4.8 yr | Fatal and nonfatal CVD event | DM | Size | | ⚪
St. Pierre 2005^57^ Canada 15618542 | GE | 57 | 0 | 100 | 5 | 23c | LDLc | 148 | Healthy | 2072 | 13 yr unadj 5 yr adj F | Ischemic CAD event | | Size | ⚪
St. Pierre 2005^57^ Canada 15618542 | Prospective longitudinal | 57 | 0 | 100 | 5 | 23c | mean 256.9 Å B (<255 Å): 40% | | Healthy | 2072 | 13 yr unadj 5 yr adj F | Ischemic CAD event | | Pattern | ▽ | ▼
Stampfer 1996^58^ US 8782637 | GE | 59 | ~25 | 100 | 6 | 56e | Total:HDL-c ratio | 5.2 | CAD event | 266 | 7 yr | Incident MI or CAD death | | Size | ▽ | ⚪
Stampfer 1996^58^ US 8782637 | Nested case control | 59 | ~25 | 100 | 6 | 56e | mean 256 Å B: 47% I: 20% | | Control | 308 | 7 yr | Incident MI or CAD death | | Pattern | ▽ | ⚪
Austin 2000^52^ US (HI G) 10946034 | GE | 68 | ~70 | 100 | 17 | 63e | LDL-c: | 142 | Incident CHD | 145 | 12 yr | Incident CAD: MI or coronary intervention | | Size | ▽ | ⚪
Austin 2000^52^ US (HI G) 10946034 | Nested case control | 68 | ~70 | 100 | 17 | 63e | mean 260.0 Å | | Control | 296 | 12 yr | Incident CAD: MI or coronary intervention | | Pattern | ▽
Gardner 1996^54^ US 8782636 | GE | 59 | 33 | 73 | nd | 42n | Non-HDL-c: | 176 | CAD event | 124 | mean 5 yr to CAD event | Incident MI or CAD death | | Size | ▽ | ▼
Gardner 1996^54^ US 8782636 | Nested case control | 59 | 33 | 73 | nd | 42n | mean 261.7 Å <260 Å: 40% >274.2 Å: 10% | | No event | 124 | mean 5 yr to CAD event | Incident MI or CAD death | | Pattern | [image]
Mykkanen 1999^55^ Finland 10559020 | GE | 69 | 100 | 50 | 33 | 20c | Total:HDL-c ratio | 6.09 | CAD event | 86 | mean 3.5 yr | Incident MI or CAD death | | Size | ⚪ | ⚪
Mykkanen 1999^55^ Finland 10559020 | Nested case control | 69 | 100 | 50 | 33 | 20c | mean 268.2 Å B or I: 21% | | Control | 172 | mean 3.5 yr | Incident MI or CAD death | | Pattern | ⚪
Campos 2001^53^ US 11572739 H | GE | 60 | ~30 | 87 | 16 | 17c | LDL-c | 139 | CAD event | 242 | median 5 yr | Confirmed MI or CAD death (on placebo) | | Size | ▽ | ▼
Campos 2001^53^ US 11572739 H | Nested case control | 60 | ~30 | 87 | 16 | 17c | mean 256 Å | | Control | 218 | median 5 yr | Confirmed MI or CAD death (on placebo) | | Size | ▽ | ▼

A, Pattern A (if no definition included, the article did not define); I, Indeterminate pattern (not A or B); B, Pattern B;

Pattern: analysis based on distribution across categories of LDL subfractions (eg, small, medium, large)

Size: analysis based on actual particle size (eg, regression or comparisons of mean sizes)

A CITP; GE; HPLC; NMR; UC; Other

B Of cases in case-control or cross-sectional studies (when reported separately); Data at baseline

C ~ = estimated from mean and standard deviation, otherwise reported value (rounded to nearest 5%)

D c = current smokers; e = ever smoked; n = not defined.

E Unclear how many of the subjects were analyzed.

F Lamarche 2001^60^ UI 11521128.

G Japanese Americans in the Honolulu Heart Program.

H Also in section 4.4.

Table 10 Association between LDL Subfraction and progression of coronary artery disease (not full extraction)

▽/▼ Smaller particles associated with more CAD outcome: Statistically significant association in unadjusted (unadj)/adjusted (adj) analysis ⚪/⚪ No statistically significant association in unadjusted (unadj)/adjusted (adj) analysis △/▲ Larger particles associated with more CAD outcome: Statistically significant association in unadjusted (unadj)/adjusted (adj) analysis [image]/[image] An association was reported, but no statistical analysis was performed
Author Year Country UI | Test Category A Study Design | Mean Age B | %>65 C | %Male B | %DM B | %Smoke D | LDL-c B (mg/dL) | | Group (Arm) | N | Follow- up Time | Outcome (Definition) | Predictor | Results
Author Year Country UI | Test Category A Study Design | Mean Age B | %>65 C | %Male B | %DM B | %Smoke D | Subfraction Data | | Group (Arm) | N | Follow- up Time | Outcome (Definition) | Predictor | Unadj | Adj
Zhao 2003^61^ US 12601286 | GE | 62 | 40 | 74 | 23 | 64e | LDL-c | 141 | CAD requiring PTCA or CABG | 278 | 3 yr | Native CAD progression (angiography) | Size | ▽
Zhao 2003^61^ US 12601286 | Prospective longitudinal (RCT) | 62 | 40 | 74 | 23 | 64e | mean 266.8 Å B: 26% A: 64% Small (<256 Å): 26% | | CAD requiring PTCA or CABG | 278 | 3 yr | Native CAD progression (angiography) | Pattern | ▽ | E
Watts 1993^62^ UK 8231842 | UC | nd | nd | 100 | nd | nd | TC | 280 | Angina pectoris not requiring revascularization | 74 | 38 mo | Change coronary atherosclerosis (angiography) | Pattern | ▽
Watts 1993^62^ UK 8231842 | Prospective longitudinal (RCT) | nd | nd | 100 | nd | nd | LDL_2_ (d=1.019–1.040 Kg/L): 36 mg/dL LDL_3_ (d=1.040–1.063 kg/L): 92 mg/dL | | Angina pectoris not requiring revascularization | 74 | 38 mo | Change coronary atherosclerosis (angiography) | Pattern | ▽
Ruotolo 1998^56^ Sweden 9822092 F | GE | 42 | 0 | 100 | nd | 24c | LDL-c | 180 | MI<45 yo | 92 | 5 yr | Change coronary atherosclerosis (angiography) | Size | ⚪ | ⚪
Ruotolo 1998^56^ Sweden 9822092 F | Prospective longitudinal (RCT) | 42 | 0 | 100 | nd | 24c | mean 230 Å Small (<228 Å): 39% | | MI<45 yo | 92 | 5 yr | Change coronary atherosclerosis (angiography) | Pattern | ⚪ | ⚪
Miller 1996^63^ US 8901665 F | UC | 57 | ~20 | 100 | nd | nd | LDL-c | 156 | Coronary stenosis (usual care arm) | 116 | 4 yr | Change coronary atherosclerosis (angiography) | Pattern | ⚪
Miller 1996^63^ US 8901665 F | Prospective longitudinal (RCT) | 57 | ~20 | 100 | nd | nd | sdLDL (S_f_° 0–5): 44% B: 41% I: 31% A: 28% | | Coronary stenosis (usual care arm) | 116 | 4 yr | Change coronary atherosclerosis (angiography) | Pattern | ⚪
Mack 1996^64^ US 8963728 F | UC | 58 | ~15 | 92 | nd | 79e | LDL-c | 156 | Coronary stenosis | 220 | 2 yr | Change coronary atherosclerosis (angiography) | Size | ⚪
Mack 1996^64^ US 8963728 F | Prospective longitudinal (RCT) | 58 | ~15 | 92 | nd | 79e | Peak flotation rate, S_f_: 5.4 IV (S_f_ 0–3): 14.7 mg/dL | | Coronary stenosis | 220 | 2 yr | Change coronary atherosclerosis (angiography) | Pattern | ▽

A, Pattern A (if no definition included, the article did not define); I, Indeterminate pattern (not A or B); B, Pattern B;

Pattern: analysis based on distribution across categories of LDL subfractions (eg, small, medium, large)

Size: analysis based on actual particle size (eg, regression or comparisons of mean sizes)

A CITP; GE; HPLC; NMR; UC; Other

B Of cases in case-control or cross-sectional studies (when reported separately); Data at baseline

C ~ = estimated from mean and standard deviation, otherwise reported value (rounded to nearest 5%)

D c = current smokers; e = ever smoked; n = not defined.

E Significant association adjusted for history of hypertension, ST depression 1 mm at baseline exercise tolerance test. Lipids not included in model.

F Also in section 4.4.

Table 11 Association between LDL Subfraction and prevalent coronary artery disease (not full extraction)

▽/▼ Smaller particles associated with more CAD outcome: Statistically significant association in unadjusted (unadj)/adjusted (adj) analysis ⚪/⚪ No statistically significant association in unadjusted (unadj)/adjusted (adj) analysis △/▲ Larger particles associated with more CAD outcome: Statistically significant association in unadjusted (unadj)/adjusted (adj) analysis [image]/[image] An association was reported, but no statistical analysis was performed
Author Year Country UI | Test Category^A^ Study Design | Mean Age^B^ | %>65^C^ | %Male^B^ | %DM^B^ | %Smoke^D^ | LDL-c^B^ (mg/dL) | | Group (Arm) | N | Follow- up Time | Outcome (Definition) | Predictor | Results
Author Year Country UI | Test Category^A^ Study Design | Mean Age^B^ | %>65^C^ | %Male^B^ | %DM^B^ | %Smoke^D^ | Subfraction Data | | Group (Arm) | N | Follow- up Time | Outcome (Definition) | Predictor | Unadj | Adj
Jang 2006^65^ S Korea 16787988 | UC | 55 | ~0 | 100 | 0 | 71c | LDL-c | 106 | CAD | 532 | XS | CAD (angiography) | Size | ▽
Jang 2006^65^ S Korea 16787988 | Case control | 55 | ~0 | 100 | 0 | 71c | mean 255 Å | | Control | 670 | XS | CAD (angiography) | Size | ▽
Campos 1992^66^ US 1543692 | GE | 50 | 0 | 100 | nd | nd | LDL-c | 143 | CAD | 275 | XS | CAD (angiography) | Size | ▽ | ⚪
Campos 1992^66^ US 1543692 | Case control | 50 | 0 | 100 | nd | nd | LDL particle score^E^: 4.32 | | Control | 822 | XS | CAD (angiography) | Pattern | ▽ | ⚪
Koba 2002^67^ Japan 12486427 F | GE | 63 | ~40 | 79 | 34 | 35c | LDL-c | 123 | CAD | 571 | XS | CAD (angiography) | Size | ▽
Koba 2002^67^ Japan 12486427 F | Case control | 63 | ~40 | 79 | 34 | 35c | mean 255 Å B (≤255 Å): 53% | | Control | 263 | XS | CAD (angiography) | Pattern | ▽ | ▼
Alabakovska 2002^68^ Macedonia 12035134 | GE | 49 | 0 | 73 | 0 | nd | LDL-c | 135 | CAD | 132 | XS | CAD (previous MI) | Size | ▽
Alabakovska 2002^68^ Macedonia 12035134 | Case control | 49 | 0 | 73 | 0 | nd | mean 244 Å B: 81% | | Control | 334 | XS | CAD (previous MI) | Pattern | ▽
Koba 2006^69^ Japan 16414053 | GE | 60 | ~30 | 77 | 24 | 66e | LDL-c | 127 | Coronary angiography performed | 367 | XS | CAD (angiography) | Size | ▽
Koba 2006^69^ Japan 16414053 | GE | 60 | ~30 | 77 | 24 | 66e | LDL-c | 127 | Coronary angiography performed | 367 | XS | CAD (angiography) | Pattern | ▽
Koba 2006^69^ Japan 16414053 | Prospective cohort | 60 | ~30 | 77 | 24 | 66e | mean 257.1 Å B (<255 Å): 37% | | Coronary angiography performed | 367 | XS | CAD severity (affected vessels, n=225) | Size | ⚪
Koba 2002^70^ Japan 11755944 F | GE | 63 | ~40 | 100 | 100 | 51c | LDL-c | 108 | CAD+DM+ | 45 | XS | CAD (clinical diagnosis) | Size | ▽
Koba 2002^70^ Japan 11755944 F | GE | 63 | ~40 | 100 | 100 | 51c | mean 250 Å B (≤255 Å): 76% | | CAD−DM+ | 76 | XS | CAD (clinical diagnosis) | Pattern | ▽ | ▼
Koba 2002^70^ Japan 11755944 F | Case control | 60 | ~30 | 100 | 0 | 49c | LDL-c | 116 | CAD+DM− | 85 | XS | CAD (clinical diagnosis) | Size | ▽
Koba 2002^70^ Japan 11755944 F | Case control | 60 | ~30 | 100 | 0 | 49c | mean 252 Å B (≤255 Å): 71% | | CAD−DM− | 142 | XS | CAD (clinical diagnosis) | Pattern | ▽ | ▼
Erbey 1999^71^ US 10206450 | GE | 42 | 0 | 52 | 100 | 32c | LDL-c | 125 | CAD | 44 | XS | CAD (clinical diagnosis) | Size | ▽ | ⚪
Erbey 1999^71^ US 10206450 | Prospective cohort | 42 | 0 | 52 | 100 | 32c | mean 261.3 nmol/L B (<235.5 nmol/L): 3% A (>257 nmol/L): 9% | | Control | 297 | XS | CAD (clinical diagnosis) | Size | ▽ | ⚪
Kamigaki 2001^72^ US 11384949 | GE | 40 | 0 | 0 | 14 | 86e | LDL-c | 139 | Premature CAD | 72 | XS | CAD (previous MI) | Size | ▽ | ▼
Kamigaki 2001^72^ US 11384949 | Case control | 40 | 0 | 0 | 14 | 86e | mean 264 Å B (<255 Å): 36% | | Control | 159 | XS | CAD (previous MI) | Pattern | ▽
Austin 1988^73^ US 3418853 | GE | 52 | 0 | 84 | nd | nd | LDL-c | 144 | CAD | 109 | XS | CAD (previous MI) | Pattern | ▽ | ⚪
Austin 1988^73^ US 3418853 | Case control | 52 | 0 | 84 | nd | nd | B (<255 Å): 50% | | Control | 121 | XS | CAD (previous MI) | Pattern | ▽ | ⚪
Sherrard 1996^74^ Australia 8902153 | UC | nd | nd | 64 | nd | nd | LDL-c | ~138 | CAD | 53 | XS | CAD (angiography) | Size | ⚪
Sherrard 1996^74^ Australia 8902153 | Case control | nd | nd | 64 | nd | nd | mean 250 Å | | Control | 167 | XS | CAD (angiography) | Pattern | [image]
Coresh 1993^75^ US 8245719 | GE | 48 | 0 | 54 | 22 | 85e | LDL-c | 127 | CAD | 107 | XS | CAD (angiography) | Size | ▽ | ⚪
Coresh 1993^75^ US 8245719 | Prospective cohort | 48 | 0 | 54 | 22 | 85e | mean 251.6 Å | | Control | 91 | XS | CAD (angiography) | Size | ▽ | ⚪
Campos 1995^76^ US 7627694 | GE | 58 | ~22 | 100 | 0 | nd | LDL-c | 126 | CAD | 92 | XS | CAD (angiography) | Size | △ | ▲
Campos 1995^76^ US 7627694 | Case control | 58 | ~22 | 100 | 0 | nd | mean 268 Å III (<260 Å): 43% I (>268 Å): 14% | | Control | 92 | XS | CAD (angiography) | Pattern | △
Griffin 1994^77^ UK 8060384 | UC | 53 | 0 | 100 | ?0 | 70e | LDL-c | 154 | CAD+/MI− | 46 | XS | CAD (angiography or recent MI) | Pattern | ⚪ | ▼
Griffin 1994^77^ UK 8060384 | UC | 53 | 0 | 100 | ?0 | 70e | LDL-c | 154 | CAD− | 24 | XS | CAD (angiography or recent MI) | Pattern | ⚪ | ▼
Griffin 1994^77^ UK 8060384 | Case control | 53 | 0 | 100 | ?0 | 70e | %LDL: I (≤1.034 mg/dL): 15% III (≥1.044 mg/dL): 38% | | MI+ | 40 | XS | CAD (angiography or recent MI) | Pattern | ▽ | ▼
Griffin 1994^77^ UK 8060384 | Case control | 53 | 0 | 100 | ?0 | 70e | %LDL: I (≤1.034 mg/dL): 15% III (≥1.044 mg/dL): 38% | | Healthy | 58 | XS | CAD (angiography or recent MI) | Pattern | ▽ | ▼
Miwa 2003^78^ Japan 12559540 | GE (Lipophor) | 61 | ~35 | 80 | 31 | 74n | LDL-c | 124 | Spastic angina | 49 | XS | CAD (angiography) | Size | ▽
Miwa 2003^78^ Japan 12559540 | Case control | 61 | ~35 | 80 | 31 | 74n | Relative migratory distance^G^:0.370 Small (>0.36): 48% | | Stable angina | 56 | XS | CAD (angiography) | Pattern | ▽
Miwa 2003^78^ Japan 12559540 | Case control | 61 | ~35 | 80 | 31 | 74n | Relative migratory distance^G^:0.370 Small (>0.36): 48% | | Control | 40 | XS | CAD (angiography) | Pattern | ▽
Crouse 1985^79^ US 4020295 | Ultracentrifugation | 57 | nd | 100 | 13 | 76e | LDL-c | 140 | CAD | 46 | XS | CAD (angiography) | Size | ▽
Crouse 1985^79^ US 4020295 | Case control | 57 | nd | 100 | 13 | 76e | mean 279 Å | | Control | 47 | XS | CAD (angiography) | Size | ▽
Okazaki 2006^80^ Japan 16990425 | HPLC | 64 | ~45 | 100 | 0 | 51c | LDL-c | 122 | CAD | 45 | XS | CAD (angiography) | Pattern | ▽
Okazaki 2006^80^ Japan 16990425 | Prospective cohort | 64 | ~45 | 100 | 0 | 51c | Large (Peak 286 Å): ~35 mg/dL Medium (255 Å): ~50 mg/dL Small (230 Å): ~30 mg/dL Very small (207, 186, & 167 Å): ~10 mg/dL | | Control | 17 | XS | CAD (angiography) | Pattern | ▽
Hitsumoto 2002^81^ Japan 12226547 | GE | 61 | ~35 | 100 | 3 | 68n | LDL-c | 124 | Recent MI | 44 | XS | Recent MI | Pattern | ▽ | ⚪
Hitsumoto 2002^81^ Japan 12226547 | Case control | 61 | ~35 | 100 | 3 | 68n | Small (Relative migratory distance>0.35): 68% | | Control | 16 | XS | Recent MI | Pattern | ▽ | ⚪
Barbagallo 2006^82^ Italy 16631444 | GE | 43 | 0 | 100 | 0 | 0c | LDL-c | 111 | CAD | 29 | XS | CAD (angiography) | Size | ▽
Barbagallo 2006^82^ Italy 16631444 | Case control | 43 | 0 | 100 | 0 | 0c | mean 262.7 Å | | Control | 29 | XS | CAD (angiography) | Size | ▽
Karpe 1993^83^ Sweden 8457249 | UC | 49 | 0 | 100 | 25 | 91e | LDL-c | 154 | CAD, elevated Tg | 15 | XS | History of early MI (<age 45 yr) | Pattern | ▽
Karpe 1993^83^ Sweden 8457249 | UC | 49 | 0 | 100 | 25 | 91e | Dense (1.040<d<1.063 kg/L): 56% | | CAD, elevated Tg | 15 | XS | History of early MI (<age 45 yr) | Pattern | ▽
Karpe 1993^83^ Sweden 8457249 | Case control | 49 | 0 | 100 | 25 | 91e | LDL-c | 171 | CAD, normal Tg | 17 | XS | History of early MI (<age 45 yr) | Pattern | ⚪
Karpe 1993^83^ Sweden 8457249 | Case control | 49 | 0 | 100 | 25 | 91e | Dense (1.040<d<1.063 kg/L): 43% | | Control | 10 | XS | History of early MI (<age 45 yr) | Pattern | ⚪
Tilly-Kiesi 1992^84^ Finland 1569383 | GE | 57 | ~0 | 100 | 100 | nd | LDL-c | 117 | CAD+DM+ | 10 | XS | CAD (angiography) | Size | ⚪/△^H^
Tilly-Kiesi 1992^84^ Finland 1569383 | GE | 57 | ~0 | 100 | 100 | nd | mean 259 Å 2^nd^ peak (>255Å): 80% | | CAD−DM+ | 10 | XS | CAD (angiography) | Pattern | [image]
Tilly-Kiesi 1992^84^ Finland 1569383 | Case control | 57 | ~0 | 100 | 0 | nd | LDL-c | 133 | CAD+DM− | 10 | XS | CAD (angiography) | Size | ⚪/△^H^
Tilly-Kiesi 1992^84^ Finland 1569383 | Case control | 57 | ~0 | 100 | 0 | nd | mean 259 Å 2^nd^ peak (>255Å): 60% | | CAD−DM− | 10 | XS | CAD (angiography) | Pattern | ⚪

A, Pattern A (if no definition included, the article did not define); I, Indeterminate pattern (not A or B); B, Pattern B;

A CITP; GE; HPLC; NMR; UC; Other

B Of cases in case-control or cross-sectional studies (when reported separately); Data at baseline

C ~ = estimated from mean and standard deviation, otherwise reported value (rounded to nearest 5%)

D c = current smokers; e = ever smoked; n = not defined.

E Area under curve for each LDL band (1–5, 5 densest) multiplied by the band number, summed across bands.

F Probably some overlap in subjects.

G Measure of LDL particle size: “relative migratory distance of LDL [compared] to that of HDL from VLDL”. Relative migratory distance LDL >0.36 corresponded to the particle diameter <255 Å.

H NS when subjects with and without diabetes analyzed separately, but statistically significant when combined.

Table 12 Summary: Association between LDL Subfraction and CVD outcomes (not full extraction)

▽/▼ Smaller particles associated with more CAD outcome: Statistically significant association in unadjusted (unadj)/adjusted (adj) analysis ⚪/⚪ No statistically significant association in unadjusted (unadj)/adjusted (adj) analysis △/▲ Larger particles associated with more CAD outcome: Statistically significant association in unadjusted (unadj)/adjusted (adj) analysis [image]/[image] An association was reported, but no statistical analysis was performed
Author Year Country UI | Test Category^A^ Study Design | Mean Age^B^ | %>65^C^ | %Male^B^ | %DM B | %Smoke^D^ | LDL-c^B^ (mg/dL) | | Group (Arm) | N | Follow-up Time | Outcome (Definition) | Predictor | Results
Author Year Country UI | Test Category^A^ Study Design | Mean Age^B^ | %>65^C^ | %Male^B^ | %DM B | %Smoke^D^ | Subfraction Data | | Group (Arm) | N | Follow-up Time | Outcome (Definition) | Predictor | Unadj | Adj
Hallman 2004^85^ US 15370875 | GE | 57 | 0 | 68 | nd | 84e | LDL-c | 146 | Carotid disease, White | 151 | XS | Carotid atherosclerosis (ultrasonography) | Pattern | ▽ | ▼^E^
Hallman 2004^85^ US 15370875 | GE | 57 | 0 | 68 | nd | 84e | B: 29% A: 40% | | Control | 237 | XS | Carotid atherosclerosis (ultrasonography) | Pattern | ▽ | ▼^E^
Hallman 2004^85^ US 15370875 | Case control | 54 | 0 | 40 | nd | 51e | LDL-c | 135 | Carotid disease, Black | 47 | XS | Carotid atherosclerosis (ultrasonography) | Pattern | ⚪
Hallman 2004^85^ US 15370875 | Case control | 54 | 0 | 40 | nd | 51e | B: 19 A: 49 | | Control | 81 | XS | Carotid atherosclerosis (ultrasonography) | Pattern | ⚪
Hulthe 2000^86^ Sweden 10978261 | GE | 58 | 0 | 100 | 0 | 63e | LDL-c | 157 | Healthy^F^ | 380 | XS | Carotid & Femoral IMT^G^ (mm) | Size | ▽
Hulthe 2000^86^ Sweden 10978261 | Prospective cohort | 58 | 0 | 100 | 0 | 63e | Peak size: 263 Å B (<255 Å): 16% | | Healthy^F^ | 380 | XS | Carotid & Femoral IMT^G^ (mm) | Pattern | ⚪
Hulthe 2000^87^ Sweden 10947880 | GE | 60 | ~30 | 51 | nd | 57e | LDL-c | 267 | Hypercholesterolemia, Carotid IMT ≥1 mm | 102 | XS | Carotid & Femoral IMT^G^ (mm) | Size | ⚪^H^
Hulthe 2000^87^ Sweden 10947880 | GE | 60 | ~30 | 51 | nd | 57e | Peak size: 266.9 Å B (<255 Å): 9% | | Hypercholesterolemia, Carotid IMT ≥1 mm | 102 | XS | Carotid & Femoral IMT^G^ (mm) | Size | ⚪^H^
Hulthe 2000^87^ Sweden 10947880 | Prospective cohort | 60 | ~30 | 51 | nd | 57e | LDL-c | 142 | Healthy | 102 | XS | Carotid & Femoral IMT^G^ (mm) | Size | ⚪^J^
Hulthe 2000^87^ Sweden 10947880 | Prospective cohort | 60 | ~30 | 51 | nd | 57e | Peak size: 271.4 Å B (<255 Å): 7% | | Healthy | 102 | XS | Carotid & Femoral IMT^G^ (mm) | Size | ⚪^J^
Hayashi 2007^88^ Japan 17445534 | GE | 67 | ~55 | 65 | 100 | nd | LDL-c | 109 | Diabetes | 172 | XS | Carotid IMT (mm, maximum value) | Size | ▽ | ▼
Hayashi 2007^88^ Japan 17445534 | Prospective cohort | 67 | ~55 | 65 | 100 | nd | mean 251 Å | | Diabetes | 172 | XS | Carotid IMT (mm, maximum value) | Size | ▽ | ▼
Liu 2002^89^ Finland 11988600 | GE | 40 | 0 | 36 | 0 | 57e | LDL-c | 136 | Dyslipidemia or family history | 148 | XS | Carotid IMT (mm, mean) | Size | ▽ | ▼
Liu 2002^89^ Finland 11988600 | Prospective cohort | 40 | 0 | 36 | 0 | 57e | mean 267 Å | | Dyslipidemia or family history | 148 | XS | Carotid IMT (mm, mean) | Size | ▽ | ▼
Watanabe 2004^90^ Japan 15045695 | GE | 74 | ~85 | 100 | 0 | 22c | LDL-c | 99 | Dementia | 134 | XS | Carotid IMT (mm, mean) | Size | ▽
Watanabe 2004^90^ Japan 15045695 | Prospective cohort | 74 | ~85 | 100 | 0 | 22c | B (<255 Å): 26% | | Dementia | 134 | XS | Carotid IMT (mm, mean) | Size | ▽
Skoglund 1999^91^ Sweden 10521372 | GE | 50 | 0 | 100 | 0 | nd | LDL-c | 139 | Healthy | 94 | XS | Carotid IMT (mm, common carotid) | Size | ▽
Skoglund 1999^91^ Sweden 10521372 | Prospective cohort | 50 | 0 | 100 | 0 | nd | Peak size 236 Å IV (<225 Å): 5%I (>250 Å): 20% | | Healthy | 94 | XS | Carotid IMT (mm, common carotid) | Pattern | ▽ | ▼
Raal 1999^92^ S Africa 10235090 | GE | 29 | 0 | 52 | 0 | 0c | LDL-c | | With or without FH | 62 | XS | Carotid IMT (mm, common carotid) | Size | △ | ⚪
Raal 1999^92^ S Africa 10235090 | GE | 29 | 0 | 52 | 0 | 0c | homozygous | 526 | With or without FH | 62 | XS | Carotid IMT (mm, common carotid) | Size | △ | ⚪
Raal 1999^92^ S Africa 10235090 | GE | 29 | 0 | 52 | 0 | 0c | heterozygous | 243 | With or without FH | 62 | XS | Carotid IMT (mm, common carotid) | Size | △ | ⚪
Raal 1999^92^ S Africa 10235090 | GE | 29 | 0 | 52 | 0 | 0c | control | 124 | With or without FH | 62 | XS | Carotid IMT (mm, common carotid) | Size | △ | ⚪
Raal 1999^92^ S Africa 10235090 | Prospective cohort | 29 | 0 | 52 | 0 | 0c | mean 261 Å | | With or without FH | 62 | XS | Carotid IMT (mm, common carotid) | Size | △ | ⚪

A, Pattern A (if no definition included, the article did not define); I, Indeterminate pattern (not A or B); B, Pattern B;

Pattern: analysis based on distribution across categories of LDL subfractions (eg, small, medium, large)

Size: analysis based on actual particle size (eg, regression or comparisons of mean sizes

A CITP; GE; HPLC; NMR; UC; Other

B Of cases in case-control or cross-sectional studies (when reported separately); Data at baseline

C ~ = estimated from mean and standard deviation, otherwise reported value (rounded to nearest 5%)

D c = current smokers; e = ever smoked; n = not defined.

E Not statistically significant if all variables included (age, smoking, body mass index, triglycerides, and HDL cholesterol), but statistically significant if one or more of the variables are omitted).

F Uneven selection of participants based on insulin sensitivity, overrepresenting highest and lowest sensitivity quintiles.

G Separate analyses for common carotid, carotid bulb, and common femoral. Same results for all.

H Adjusted for age, common carotid IMT was positively associated (△) with LDL peak particle size in women, but not men. No association in other arteries.

J Adjusted for age, carotid bulb IMT was positively associated (△) with LDL peak particle size in men, but not women. No association in other arteries.

Table 13 Association between LDL Subfraction and cerebrovascular outcomes (not full extraction)

▽/▼ Smaller particles associated with more CAD outcome: Statistically significant association in unadjusted (unadj)/adjusted (adj) analysis ⚪/⚪ No statistically significant association in unadjusted (unadj)/adjusted (adj) analysis △/▲ Larger particles associated with more CAD outcome: Statistically significant association in unadjusted (unadj)/adjusted (adj) analysis [image]/[image] An association was reported, but no statistical analysis was performed
Author Year Country UI | Test Category A Study Design | Mean Age B | %>65 C | %Male B | %DM B | %Smoke D | LDL-c B (mg/dL) | | Group (Arm) | N | Follow-up Time | Outcome (Definition) | Predictor | Results
Author Year Country UI | Test Category A Study Design | Mean Age B | %>65 C | %Male B | %DM B | %Smoke D | Subfraction Data | | Group (Arm) | N | Follow-up Time | Outcome (Definition) | Predictor | Unadj | Adj
Kato 2006^93^ Japan 16832149 | HPLC | 61 | ~35 | 66 | 0 | 0c | LDL-c | 123 | Essential hypertension | 100 | XS | Silent lacunar infarct (brain MRI) | Pattern | ▽ | ▼
Kato 2006^93^ Japan 16832149 | Prospective cohort | 61 | ~35 | 66 | 0 | 0c | LDL-3 (fastest): 8.3 mg/dL | | Essential hypertension | 100 | XS | Silent lacunar infarct (brain MRI) | Pattern | ▽ | ▼

Pattern: analysis based on distribution across categories of LDL subfractions (eg, small, medium, large)

Size: analysis based on actual particle size (eg, regression or comparisons of mean sizes)

A CITP; GE; HPLC; NMR; UC; Other

B Of cases in case-control or cross-sectional studies (when reported separately); Data at baseline

C ~ = estimated from mean and standard deviation, otherwise reported value (rounded to nearest 5%)

D c = current smokers; e = ever smoked; n = not defined.

Table 14 Overall summary of unadjusted analyses of LDL subfractions and cardiovascular outcomes

Outcome | Predictor | Study Design | No. Studies | N | Unadjusted A Analyses
Outcome | Predictor | Study Design | No. Studies | N | ▽ B | ⚪ | △ B
CAD, Incident | Size | P Long | 2 | 5740 C | 10 | 5
CAD, Incident | Size | nCC | 11 | 7382 | 10 | 5
CAD, Incident | Number | nCC | 7 | 5401 | 5 | 2
CAD, Incident | Pattern | P Long | 1 | 2072 | 6 | 4
CAD, Incident | Pattern | nCC | 8 | 5996 | 6 | 4
CAD, Progression | Size | P Long | 7 | 6430 | 4 | 3
CAD, Progression | Number | P Long | 1 | 111 | | 1
CAD, Progression | Pattern | P Long | 7 | 6472 | 5 | 2
CAD, Prevalent | Size | P Cohort | 6 | 2488 | 19 | 3 | 3
CAD, Prevalent | Size | CC | 14 | 5414 | 19 | 3 | 3
CAD, Prevalent | Number | P Cohort | 1 | 286 | 1
CAD, Prevalent | Pattern | P Cohort | 5 | 1377 | 24 | | 3
CAD, Prevalent | Pattern | CC | 17 | 4688 | 24 | | 3
CerebroVD, Prevalent | Pattern | P Cohort | 2 | 179 | 2
IMT | Size | P Cohort | 8 | 1330 | 5 | 3 | 1
IMT | Pattern | P Cohort | 3 | 513 | 3 | 2
IMT | Pattern | CC | 1 | 516 | 3 | 2
Summary by disease type
Incident Disease or Progression | Size | | 20 | 19,522 D | 14 | 8
Incident Disease or Progression | Number | | 8 | 5512 | 5 | 3
Incident Disease or Progression | Pattern | | 16 | 14,540 | 11 | 6
Prevalent Disease | Size | | | 9232 | 24 | 6 | 4
Prevalent Disease | Number | | 1 | 286 | 1
Prevalent Disease | Pattern | | 36 | 7273 | 29 | 2 | 3

CC, case control; nCC, nested case control; P Cohort, prospective cohort (cross-sectional); P Long, prospective longitudinal.

A ▽/▼ Smaller particles associated with more CAD outcome: Significant association in unadjusted (unadj)/adjusted (adj) analysis.

⚪/⚪ No statistically significant association in unadjusted (unadj)/adjusted (adj) analysis.

△/▲ Larger particles associated with more CAD outcome: Significant association in unadjusted (unadj)/adjusted (adj) analysis.

B or an association was reported, but no statistical analysis was performed.

C or 6450 (number of analyzed subjects unclear in one study).

D or 8366 (number of analyzed subjects unclear in one study).

Table 15 Overall summary of lipid-adjusted analyses of LDL subfractions and cardiovascular outcomes

Outcome | Predictor | Study Design | No. Studies | N | Adjusted A,B Analyses
Outcome | Predictor | Study Design | No. Studies | N | ▼ | ⚪ | ▲
CAD, Incident | Size | P Long | 1 | 2072 | 3 | 6
CAD, Incident | Size | nCC | 8 | 2507 | 3 | 6
CAD, Incident | Number | nCC | 2 | 3148 | 2
CAD, Incident | Pattern | P Long | 1 | 2072 | 1 | 3
CAD, Incident | Pattern | nCC | 3 | 840 | 1 | 3
CAD, Progression | Size | P Long | 3 | 5741 | 1 | 2
CAD, Progression | Number | P Long | 1 | 111 | | 1
CAD, Progression | Pattern | P Long | 4 | 5858 | 3 | 1
CAD, Prevalent | Size | P Cohort | 4 | 1617 | 2 | 5 | 1
CAD, Prevalent | Size | CC | 3 | 1512 | 2 | 5 | 1
CAD, Prevalent | Number | P Cohort | 1 | 286 | 1
CAD, Prevalent | Pattern | P Cohort | 3 | 948 | 9 | 5
CAD, Prevalent | Pattern | CC | 8 | 3071 | 9 | 5
CerebroVD, Prevalent | Pattern | P Cohort | 2 | 179 | 1 | 1
IMT | Size | P Cohort | 3 | 382 | 2 | 1
IMT | Pattern | P Cohort | | 133 | 3
IMT | Pattern | CC | 1 | 516 | 3
Summary by disease type
Incident Disease C | Size | | 12 | 9879 | 4 | 8
Incident Disease C | Number | | 3 | 3259 | 2 | 1
Incident Disease C | Pattern | | 9 | 9211 | 4 | 5
Prevalent Disease | Size | | 10 | 3511 | 4 | 6 | 1
Prevalent Disease | Number | | 1 | 286 | 1
Prevalent Disease | Pattern | | 16 | 4847 | 13 | 6

A ▽/▼ Smaller particles associated with more CAD outcome: Significant association in unadjusted (unadj)/adjusted (adj) analysis.

⚪/⚪ No statistically significant association in unadjusted (unadj)/adjusted (adj) analysis.

△/▲ Larger particles associated with more CAD outcome: Significant association in unadjusted (unadj)/adjusted (adj) analysis.

B Adjusted for cardiovascular risk factors, including LDL and/or HDL cholesterol and/or total:HDL cholesterol ratio, and possibly other items such as age, weight, and diagnosis of diabetes.

C Including progression of coronary atherosclerosis, by angiography.

Table 16 Overall summary of studies that reported both unadjusted and lipid-adjusted analyses of LDL subfractions and cardiovascular outcomes

Outcome | Predictor | Study Design | No. Studies | N | Unadjusted A → Adjusted A, B Analyses
Outcome | Predictor | Study Design | No. Studies | N | ▽→▼ | ▽→⚪ | ⚪→⚪ | ⚪→▼ | △→▲ | △→⚪
CAD, Incident | Size | nCC | 8 | 2507 | 2 | 5 | 1
CAD, Incident | Number | nCC | 2 | 3148 | 2
CAD, Incident | Pattern | P Long | 1 | 2072 | 1 | 2 | 1
CAD, Incident | Pattern | nCC | 3 | 840 | 1 | 2 | 1
CAD, Progression | Size | P Long | 3 | 5741 | 1 | 1 | 1
CAD, Progression | Number | P Long | 1 | 111 | | | 1
CAD, Progression | Pattern | P Long | 4 | 5858 | 3 | | 1
CAD, Prevalent | Size | P Cohort | 4 | 1617 | 2 | 4 | 1 | | | 1
CAD, Prevalent | Size | CC | 2 | 1512 | 2 | 4 | 1 | | | 1
CAD, Prevalent | Number | P Cohort | 1 | 286 | 1
CAD, Prevalent | Pattern | P Cohort | 3 | 948 | 8 | 5 | | 1
CAD, Prevalent | Pattern | CC | 8 | 3071 | 8 | 5 | | 1
CerebroVD, Prevalent | Pattern | P Cohort | 2 | 179 | 1 | 1
IMT | Size | P Cohort | 3 | 382 | 2 | | | | | 1
IMT | Pattern | P Cohort | 2 | 133 | 3
IMT | Pattern | CC | 1 | 516 | 3
Summary by disease type
Incident Disease or Progression | Size | | 11 | 8248 | 3 | 6 | 2
Incident Disease or Progression | Number | | 3 | 3259 | 2 | | 1
Incident Disease or Progression | Pattern | | 8 | 8770 | 4 | 2 | 2
Prevalent Disease | Size | | 9 | 3511 | 4 | 4 | 1 | | | 2
Prevalent Disease | Number | | 1 | 286 | 1
Prevalent Disease | Pattern | | 16 | 4847 | 12 | 6 | | 1

A ▽/▼ Smaller particles associated with more CAD outcome: Significant association in unadjusted (unadj)/adjusted (adj) analysis.

⚪/⚪ No statistically significant association in unadjusted (unadj)/adjusted (adj) analysis.

△/▲ Larger particles associated with more CAD outcome: Significant association in unadjusted (unadj)/adjusted (adj) analysis.

B Adjusted for cardiovascular risk factors, including LDL and/or HDL cholesterol and/or total:HDL cholesterol ratio, and possibly other items such as age, weight, diabetes.

### Question 4.2

#### If these tests are used in combination with other cardiovascular risk assessment technologies, what is the incremental increase of diagnostic performance?

Among the studies that used the clinically available GE test (LipoPrint^®^) or NMR, none revised a cardiovascular risk assessment technology (such as the Framingham Risk Score) by adding data on LDL subfractions or compared predictive models with and without LDL subfractions. Thus, there are no data on how cardiovascular risk assessment technologies are affected by the addition of information from clinically available LDL subfraction tests.

### Question 4.3

#### If there is a relationship between LDL subfractions and CVD how strong is it relative to other risk factors?

Seven studies that used the LipoPrint^®^ GE and all 12 studies that used NMR directly or indirectly compared the relative strengths of various risk factors, including LDL subfraction, for cardiovascular outcomes (Tables 17–23).27,34–47,49,50,94 The studies have been described in the first section of the results for Question 4.1. In Tables 17–23, we did not include the increments implied by the associations reported (eg, whether OR was per 1 SD increment of the predictor or per 1 mg/dL). The goal of these tables is to evaluate the relative strengths of the risk factors (as per Question 4.3) within studies. We thus decided that the details would add complexity to the tables without adding value to answer the question at hand. Readers are referred to the primary studies for more details.

To address this question across studies, it would be ideal if all studies performed multivariable analyses using a standard set of risk factors for CVD. As can be seen in Tables 17–23, different studies evaluated different risk factors. None evaluated all the risk factors used by the ATP III or JNC 7 guidelines to determine treatment goals for dyslipidemia or hypertension.2,13 Notably, history of atherosclerotic CVD, family history of CVD, and chronic kidney disease were rarely evaluated; though, this may be a study applicability issue, since eligibility criteria were based on these factors.

As discussed above (Question 4.1), the LipoPrint^®^ studies predominantly evaluated prevalent disease while the NMR studies mostly evaluated incident disease or progression of CVD. The clinical utility of using LDL subfraction (or other risk factors) as a predictor for prevalent disease is unclear.

##### Results

Only three studies, two using NMR (Table 23) and one using GE (Table 21), reported on the association between cardiovascular risk factors and incident disease in a multivariable model together with LDL subfraction data.35,42,45 All reported that other CVD risk factors had stronger associations with incident coronary disease than LDL subfraction.

Eight NMR studies and one GE study reported univariable associations of LDL subfraction together with other CVD risk factors (Tables 21 & 22). 27,35,37,38,40–42,45,94 The studies evaluated different incident CVD outcomes, including coronary disease, acute myocardial infarction (or death), acute coronary syndrome (including angina), stroke, and progression of coronary calcification or coronary minimum lumen diameter. Seven of the nine studies found that one or more measures of smaller LDL subfractions were among the most strongly associated risk factors for incident CVD. Three of these studies found that LDL subfractions were more strongly associated with CVD than other risk factors, while the other four found that other risk factors, including lipoprotein cholesterol, smoking, diabetes, weight, blood pressure or hypertension, and high sensitivity C reactive protein, were similarly associated with incident CVD. One study (Campbell 2007) found that LDL particles were larger among patients who developed an intracranial hemorrhage. The remaining study (Kuller 2002) did not clearly report which risk factors were most strongly associated with acute myocardial infarction.

Six studies evaluated LDL subfraction by GE and two evaluated NMR in multivariable models for prevalent CVD - coronary calcification, existing coronary or carotid atherosclerosis (Tables 19 & 20). The studies did not have consistent findings regarding the relative strength of LDL subfraction and other risk factors and their association with prevalent CVD. Three studies found no association between LDL subfraction and prevalent disease (coronary calcification or atherosclerosis, or carotid disease) (Kullo 2004, Landry 1998, Freeman 1998). Two studies found that LDL subfraction (pattern B) had broadly similar strengths of association with prevalent disease (coronary atherosclerosis) as other risk factors (age and diabetes, or HDL and smoking) (Kwon 2006, Yoon 2005). Three studies found that LDL subfraction (LDL score or small dense LDL) was most strongly associated with prevalent CVD (coronary or carotid atherosclerosis) (Rajman 1996, Inukai 2005, Mora 2007).

Seven GE studies and three NMR studies reported univariable associations of LDL subfraction and other risk factors versus prevalent CVD (coronary atherosclerotic disease, carotid atherosclerosis, and coronary calcification).34,36,39,43–47,49,50 The studies were again inconsistent. Four often studies found that other risk factors were stronger predictors of prevalent disease; including a subgroup analysis of patients without diabetes (Yoon 2005). Three found that LDL subfractions were similarly predictive of CVD as other risk factors (lipoprotein cholesterol, hypertension, diabetes, and overall Framingham risk score); including the other subgroup analysis of patients with diabetes (Yoon 2005). The remaining four found that various measures of smaller LDL subfractions were most strongly associated with prevalent disease.

##### Summary

Among the four groups of analyses (univariable and multivariable, incident and prevalent CVD), the multivariable analyses of incident disease are the most clinically and methodologically relevant. The clinical utility of LDL subfraction as a predictor of prevalent disease is limited. The methodological value of univariable analyses, particularly among nonrandomized studies, is questionable. Also, since both ATP III and JNC 7 use multivariable approaches to determine thresholds for lipoproteins or blood pressure, multivariable analyses are clinically pertinent. All such analyses found that other risk factors were more strongly associated with CVD than LDL subfractions; though only three of 18 studies evaluated this association. The univariable analyses were inconsistent regarding how strongly (relatively) LDL subfractions were associated with incident disease. Similar to both univariable and multivariable analyses of prevalent disease, about equal numbers of studies found that LDL subfraction was most strongly associated with CVD, was similarly associated as more traditional risk factors, or were less strongly (or not) associated with CVD, regardless of the specific CVD outcome. Overall, the data do not adequately answer the question of how strongly LDL subfraction information is associated with CVD, in relation to other known and putative risk factors.

Table 17 LipoPrint: Prevalent Disease: Univariable

Predictor | Kullo 2004^44^ | | | | Kwon 2006^45^ | | Yoon 2005^50^ | | | | Landry 1998^46^ | | Rajman 1996^49^ | | Mohan 2005^47^ | | Inukai 2005^43^
Predictor | OR 95% CI | P | OR 95% CI | P | Diff | P | Diff | P | Diff | P | Diff | P | Diff | P | Diff | P | Diff | P
Outcome: | CAC Women | | CAC Men | | CAD | | CAD & DM | | CAD, No DM | | Carotid Dz | | CAD | | CAD | | IMT
N: | 470 | | 322 | | 504 | | 79 | | 188 | | 79 | | 68 | | 60 | | 27
Pattern B | | | | | +23.3% | <.001 | ~−25% | <.05 | ~−40% | <.05
LDL size | 0.94 0.90–0.99 | .008 | 1.02 0.97–1.08 | NS | −3.2 | <.001 | −8 | <.05 | −10 | <.05
sdLDL | | | | | +6.0% | <.001 | | | | | | | | | +5.6 mg/dL | <.05 | +39 mg/dL | <.01
LDL score | | | | | | | | | | | +0.30 | .04 | +0.52 | <.001
LDL-c | 1.001 1.00–1.01 | .05 | 0.998 0.99–1.01 | NS | +7.1 | .02 | +10 | NS | +9 | NS | | | +24 | <.05 | +16 | NS | +34 | <.05
HDL-c A | 0.98 0.97–0.99 | .003 | 0.99 0.98–1.01 | NS | −3.8 | <.001 | −10 | <.05 | −20 | <.0001 | | | −3 | .08 | 0 | NS | +7 | NS
Tg | 1.8 1.2–2.6 | .004 | 0.9 0.6–1.4 | NS | +12.5 | NS | −2 | NS | +28 | <.05 | +24 | NS | +4 | NS | +18 | NS | −12 | NS
TC | 1.005 0.99–1.01 | .10 | 0.997 0.99–1.01 | NS | +5.6 | NS | −7 | NS | −5 | <.05 | +23 | NS | +21 | .07 | +15 | NS | +21 | NS
Age A | 1.15 1.12–1.18 | <.001 | 1.15 1.12–1.18 | <.001 | +5.7 | <.001 | +1.7 | NS | +1.4 | NS | +9.9 | <.001 | +2 | NS | 0 | NS
HTN A | 2.1 1.3–3.5 | .003 | 1.3 0.8–2.4 | NS | +16.4% | <.001 | +29.8% | <.05 | +49% | <.05 | +16% | NS
Smoker A | 2.4 1.6–3.6 | <.001 | 1.7 1.0–2.7 | .03 | +12.1% | .005 | +8.3% | NS | +13.8% | <.05 | +24% | <.005
CVD A
FHx CVD A
DM A, B | 3.4 1.9–6.0 | <.001 | 2.1 0.8–2.4 | .02 | +20.8% | <.001 | | | | | +12% | NS
FPG C | | | | | | | | | | | | | | | +4 | NS | −51 | NS
Hb A1c C | | | | | | | | | | | | | | | +0.9 | NS | −0.8 | NS
CKD B
Fram Sc | | | | | +2.9 | <.001
BMI | | | | | −0.7 | .04 | +0.8 | NS | +1.3 | <.05 | −0.2 | NS | +0.9 | NS | −0.9 | NS | +2.7 | <.05
SBP | | | | | | | | | | | +16 | <.005 | | | +2 | NS | −7 | NS
DBP | | | | | | | | | | | −2 | NS | | | +3 | NS | −4 | NS
Male | | | | | | | +11.1% | NS | +16.6% | <.05 | +39% | <.001 | | | 0% | NS
hsCRP | | | | | +2.9 | NS
Strongest Assns: | Age, Smoking, Diabetes | | Age | | Subfraction & Others | | Subfraction & Others | | HDL-c | | Age, Sex | | Subfraction | | Subfraction | | Subfraction

A Cardiovascular risk factors used in consideration of LDL-c treatment. www.nhlbi.nih.gov/guidelines/cholesterol/atglance.htm

B Cardiovascular risk factors used in consideration of hypertension treatment. www.nhlbi.nih.gov/guidelines/hypertension/express.pdf

C Cardiovascular risk factors associated with risk factors in footnotes A and B.

Table 18 NMR: Prevalent Disease: Univariable

Predictor | Mora 2007^39^ | | Barzilai 2003^34^ | | Freedman 1998^36^
Predictor | Change | P | Diff | P | Correlation | P
Outcome: | IMT | | CVD | | CAD score
N: | 5538 | | 229 | | 158
Particle No. | 40.2 | <.001
LDL size | −20.9 D | <.001 D | −6 | .001
sdLDL | 31.7 D | <.001 D | +23.2% | .001
LDL score | | | | | −0.17 | <.05
LDL-c | 37.4 D | <.001 D | −16.2 | .03 | 0.26 | <.001
HDL-c A | −22.4 D | <.001 D | | | 0.27 | <.001
Tg | 13.1 D | .002 D | | | 0.20 | <.05
TC | | | | | 0.25 | <.05
Age A | | | | | 0.33 | <.001
HTN A
Smoker A
CVD A
FHx CVD A
DM A, B
FPG C
Hb A1c C
CKD B
Fram Sc
BMI | | | | | 0.08 | NS
SBP
DBP
Male
hsCRP
Strongest Assns: | Subfraction Lipoproteins | | Subfraction | | Lipoproteins, Age

A Cardiovascular risk factors used in consideration of LDLc treatment. www.nhlbi.nih.gov/guidelines/cholesterol/atglance.htm

B Cardiovascular risk factors used in consideration of hypertension treatment. www.nhlbi.nih.gov/guidelines/hypertension/express.pdf

C Cardiovascular risk factors associated with risk factors in footnotes A and B.

D Adjusted for age, sex, race, hypertension, and smoking, but not other risk factors in table.

Table 19 LipoPrint: Prevalent Disease: Multivariable

Predictor | Kullo 2004^44^ | | | | Kwon 2006^45^ | | Yoon 2005^50^ | | Landry 1998^46^ | | Rajman 1996^49^ | | Inukai 2005^43^
Predictor | OR 95% CI | P | OR 95% CI | P | OR 95% CI | Diff | OR 95% CI | P | OR 95% CI | P | F statistic | P | OR | P
Outcome: | CAC Women | | CAC Men | | CAD | | CAD | | Carotid Dz | | CAD | | IMT
N: | 470 | | 322 | | 504 | | 267 | | 79 | | 68 | | 27
Pattern B | | | | | 2.3 1.5–3.5 | <.001 | 4.4 1.2–16 | .03
LDL size | 0.98 0.92–1.04 | NS | 1.02 0.96–1.08 | NS
sdLDL | | | | | | | | | | | | | 1.6 | .01
LDL score | | | | | | | | | 2.2 0.9–5.3 | NS | 22.3 | <.001
LDL-c | | | | | 2.2 0.8–2.0 | NS | | | | | 4.21 | NS | 1.5 | .04
HDL-c A | 0.98 0.96–1.00 | .04 | 0.99 0.97–1.01 | NS | 1.2 0.7–2.0 | NS | 0.9 0.8–0.97 | .01 | | | 1.72 | NS | 0.8 | NS
Tg | 0.9 0.5–1.5 | NS | 0.8 0.4–1.6 | NS | | | adjusted | nd | | NS | 0.33 | NS | 1.1 | NS
TC | 1.01 1.01–1.01 | .04 | 1.00 1.00–1.00 | NS | | | adjusted | nd | | NS | 0.98 | NS | 1.3 | .07
Age A | 1.14 1.12–1.16 | <.001 | 1.14 1.12–1.16 | <.001 | 3.7 2.1–6.8 | <.001 | adjusted | nd | 1.09 1.03–1.15 | <.05 | nd | NS
HTN A | 1.8 1.1–2.9 | .02 | 1.2 0.7–2.2 | NS | 1.5 1.0–2.3 | .05 | adjusted | nd | | NS
Smoker A | 2.5 1.7–3.8 | <.001 | 1.6 1.0–2.7 | .05 | 1.8 1.2–2.8 | .006 | 4.8 1.1–22 | .04 | 2.1 1.1–4.0 | <.05
CVD A
FHx CVD A
DM A, B | 2.9 1.7–4.9 | <.001 | 1.9 1.0–3.6 | .04 | 3.3 2.0–5.5 | <.001 | | | | NS
FPG C | | | | | | | | | | | | | 1.1 | NS
Hb A1c C | | | | | | | | | | | | | 1.3 | NS
CKD B
Fram Sc
BMI | | | | | 0.8 0.5–1.2 | NS | adjusted | nd | | | nd | NS | 1.4 | .04
SBP | | | | | | | | | | NS | | | 1.2 | NS
DBP | | | | | | | | | | NS | | | 1.3 | NS
Male | | | | | | | adjusted | nd | | NS
hsCRP | | | | | | | adjusted | nd
Strongest Assns: | Age, Smoking, Diabetes | | Age | | Subfraction, Age, Diabetes | | Subfraction, HDL-c, Smoking | | Age, Smoking | | Subfraction | | Subfraction

A Cardiovascular risk factors used in consideration of LDL-c treatment. www.nhlbi.nih.gov/guidelines/cholesterol/atglance.htm

B Cardiovascular risk factors used in consideration of hypertension treatment. www.nhlbi.nih.gov/guidelines/hypertension/express.pdf

C Cardiovascular risk factors associated with risk factors in footnotes A and B.

Table 20 NMR: Prevalent Disease: Multivariable

Predictor | Mora 2007^39^ | | Freedman 1998^36^
Predictor | Change | P | Predicted Change | P
Outcome: | IMT | | CAD score
N: | 5538 | | 158
Particle No./Conc.
LDL size
sdLDL | 34.8 | .001 | -- | NS
LDL score
LDL-c | 11.8 | NS | 28 | <.05
HDL-c A | −17.3 | .003 | −25 | <.05
Tg | −1. 6 | NS | 11 | NS
TC
Age A | Adjusted | nd | 43 | <.05
HTN A | Adjusted | nd
Smoker A | Adjusted | nd
CVD A
FHx CVD A
DM A, B
FPG C
Hb A1c C
CKD B
Fram Sc
BMI
SBP
DBP
Male | Adjusted | nd
hsCRP
Strongest Assns: | Subfraction | | Lipoproteins, Age

A Cardiovascular risk factors used in consideration of LDLc treatment. www.nhlbi.nih.gov/guidelines/cholesterol/atglance.htm

B Cardiovascular risk factors used in consideration of hypertension treatment. www.nhlbi.nih.gov/guidelines/hypertension/express.pdf

C Cardiovascular risk factors associated with risk factors in footnotes A and B.

Table 21 LipoPrint: Incident Disease: Univariable and Multivariable

Predictor | Kwon 2006^45^
Predictor | Diff | P | OR (95% CI) | P
Outcome: | ACS, Univariable | | ACS, Multivariable
N: | 262
Pattern B | +7.3% | NS | 1.4 (0.8–2.5) | NS
LDL size | −4.5 | .01
sdLDL | +6.5% | .03
LDL score
LDL-c | +0.2 | NS | 1.0 (0.3–3.5) | NS
HDL-c A | −0.1 | NS | 1.0 (0.5–1.9) | NS
Tg | −2.2 | NS
TC | −1.5 | NS
Age A | −1.8 | NS | 1.0 (0.3–2.7) | NS
HTN A | −17.6% | .01 | 0.6 (0.3–1.1) | NS
Smoker A | +13.7% | .05 | 2.1 (1.2–3.9) | .01
CVD A
FHx CVD A
DM A, B | −1.9% | NS | 0.9 (0.5–1.7) | NS
FPG C
Hb A1c C
CKD B
Fram Sc | −0.4 | NS
BMI | −0.7 | NS | 0.5 (0.2–0.8) | .02
SBP
DBP
Male
hsCRP | +11.2 | .02 | 1.01 (1.00–1.02) | NS
Strongest Assns: | Subfraction, HTN | | Smoking

A Cardiovascular risk factors used in consideration of LDL-c treatment. www.nhlbi.nih.gov/guidelines/cholesterol/atglance.htm

B Cardiovascular risk factors used in consideration of hypertension treatment. www.nhlbi.nih.gov/guidelines/hypertension/express.pdf

C Cardiovascular risk factors associated with risk factors in footnotes A and B.

Table 22 NMR: Incident Disease: Univariable (part 1)

Predictor | El Harchaoui 2007^35^ | | Kuller 2002^37^ | | | | Otvos 2006^40^ | | Mackey 2002^38^ | | Blake 2002^27^ | | Campbell 2007^94^
Predictor | Diff | P | Diff | P | Diff | P | OR | P | Diff | P | Diff | P | Diff | P
Outcome: | CAD | | MI Women | | MI Men | | MI or Death | | Coronary Calcification | | CVD event | | ICH
N: | 2888 | | 373 | | 310 | | 1061 | | 268 | | 260 | | 148
Particle No./Conc. | +115 | <.0001 | +11 | nd | +101 | nd | 1.2 D | .006 D | +339 | .001 | +193 | <.001 | −95 | NS
LDL size | −1 | .002 | −3 | nd | 0 | NS | 1.0 D | NS D | −3.3 | .004 | −3 | .05 | +3 | .04
sdLDL | +114 | <.0001 | +7.1 | <.05 | +3.0 | nd | 1.1 D | NS D | +26.2 | .001 | 0 | NS
LDL score
LDL-c | +8 | <.0001 | +8 | nd | +2 | nd | 1.1 D | NS D | +16 | .006 | +11 | .01 | +1 | NS
HDL-c A | −4 | <.0001 | | | | | 0.9 D | NS D | −7.1 | .02 | −5.9 | .004 | +5 | .05
Tg | +18 | <.0001 | +19 | nd | +15 | NS | 1.1 D | NS D | +37.4 | .005 | +23 | .006
TC | +8 | <.0001 | +8 | nd | 0 | NS | | | +16.7 | .007 | | | +4 | NS
Age A | | | | | | | | | | | | | 0 | NS
HTN A | | | | | | | | | | | +22% | .001 | +15% | NS
Smoker A | +7.4% | <.0001 | | | | | | | | | | | −3% | NS
CVD A | | | | | | | | | | | | | −4% | NS
FHx CVD A | | | | | | | | | | | +12% | .01
DM A, B | +4.5% | <.0001 | | | | | | | | | +7.7% | .02 | −3% | NS
FPG C | | | | | | | | | +10.1 | .002
Hb A1c C
CKD B
Fram Sc
BMI | +1.1 | <.0001 | | | | | | | +2.1 | NS | +1.9 | .003 | −1.0 | NS
SBP | +5 | <.0001 | | | | | | | +4.6 | NS | | | 7 | .06
DBP | +2 | <.0001 | | | | | | | | | | | +2 | NS
Male | | | | | | | | | | | | | −3% | NS
hsCRP | | | | | | | | | | | +.23 | <.001 | −.07 | NS
Strongest Assns: | Subfraction & Others | | Unclear | | | | Subfraction | | Subfraction | | Subfraction, hsCRP | | Subfraction (−) HDL-c

A Cardiovascular risk factors used in consideration of LDL-c treatment. www.nhlbi.nih.gov/guidelines/cholesterol/atglance.htm

B Cardiovascular risk factors used in consideration of hypertension treatment. www.nhlbi.nih.gov/guidelines/hypertension/express.pdf

C Cardiovascular risk factors associated with risk factors in footnotes A and B.

D Adjusted for treatment (gemfibrozil vs placebo), age, hypertension, smoking, BMI, and diabetes, but not other risk factors in table.

Table 22 NMR: Incident Disease: Univariable (part 2)

Predictor | Soedamah-Muthu 2003^42^ | | Rosenson 2002^41^
Predictor | Diff | P | OR | P
Outcome: | CAD | | MLD Progression
N: | 118 | | 111
Particle No./Conc. | +274 | <.001 | 2.1 | NS
LDL size | −4 | <.01 | 0.2 | <.05
sdLDL | +0.47 | <.001 | 7.5 | <.05
LDL score
LDL-c | +12 | .07 | 1.4 | NS
HDL-c A | −10 | <.001 | 1.3 | NS
Tg | +38 | <.001 | 1.9 | NS
TC | +12 | .09
Age A | | | Adjusted
HTN A | +5% | NS
Smoker A | +16% | <.001
CVD A
FHx CVD A
DM A, B
FPG C
Hb A1c C | +0.2 | NS
CKD B | +14% | .01
Fram Sc
BMI | −0.5 | NS
SBP | +1.5 | NS
DBP | +2.3 | NS
Male | | | Adjusted
hsCRP
Strongest Assns: | Subfraction Lipoproteins, Smoking | | Subfraction

A Cardiovascular risk factors used in consideration of LDL-c treatment. www.nhlbi.nih.gov/guidelines/cholesterol/atglance.htm

B Cardiovascular risk factors used in consideration of hypertension treatment. www.nhlbi.nih.gov/guidelines/hypertension/express.pdf

C Cardiovascular risk factors associated with risk factors in footnotes A and B.

D Adjusted for treatment (gemfibrozil vs placebo), age, hypertension, smoking, BMI, and diabetes, but not other risk factors in table.

Table 23 NMR: Incident Disease: Multivariable

Predictor | El Harchaoui 2007^35^ | | Soedamah-Muthu 2003^42^
Predictor | OR | P | OR | P
Outcome: | CAD | | CAD
N: | 2888 | | 118
Particle No./Conc. | 1.4 1.0–1.9 | .02 | -- | NS
LDL size | | | -- | NS
sdLDL | | | -- | NS
LDL score
LDL-c | 1.6 1.2–2.0 | .001
HDL-c A | 0.7 0.5–0.9 | .001 | -- | NS
Tg | 1.5 1.2–2.0 | .001 | 3.1 D | .0004
TC
Age A | Adjusted | nd
HTN A
Smoker A | Adjusted | nd | -- | NS
CVD A
FHx CVD A
DM A, B
FPG C
Hb A1c C
CKD B | | | 11 | .02
Fram Sc
BMI
SBP | Adjusted | nd
DBP
Male | Adjusted | nd
hsCRP
Strongest Assns: | Lipoproteins | | Overt nephropathy

A Cardiovascular risk factors used in consideration of LDL-c treatment. www.nhlbi.nih.gov/guidelines/cholesterol/atglance.htm

B Cardiovascular risk factors used in consideration of hypertension treatment. www.nhlbi.nih.gov/guidelines/hypertension/express.pdf

C Cardiovascular risk factors associated with risk factors in footnotes A and B.

D In one of several models.

### Question 4.4

#### What do studies report regarding the link between therapies to alter LDL subfractions and CVD outcomes?

The aim of this question was to evaluate the link within trials between treatment effects on LDL subfractions and subsequent CVD outcomes. Upon reviewing the studies it became clear that this is a complex question that can be addressed a number of different ways. To structure our analysis (and to help determine which studies provide analyses relevant to this question) we developed an analytic framework of interventions, LDL subfractions, and CVD outcomes (Figure 1). The different possible analyses to address the question (arrows C, D, E) are described in the legend.

Figure 1 Analytic framework for association between interventions, LDL subfractions, and CVD events

Triangle “Treatment” and circle “Control” represent the interventions in a trial.

Solid lines represent associations related to treatment; dashed lines represent associations related to control.

The interventions (treatment and control) have putative effects on LDL subfractions, displayed as the grey horizontal arrows representing the change from baseline (square) to on-trial (octagon).

The horizontal double-headed arrow A represents the comparison between the effect of treatment and control on change in LDL subfractions.

The interventions also have a putative effect on the clinical outcome incident CVD events (star), as displayed by the longer vertical arrows.

The net treatment effect on incident disease is represented by the horizontal double-headed arrow B.

The diagonal arrows from Baseline LDL Subfractions to CVD Event represent the association addressed in Question 4.1, LDL subfractions as a predictor of CVD outcomes. The difference between the associations of baseline LDL subfractions and CVD events found in the intervention arm and the control arm (arrow C) would provide evidence that treatment alters the strength of the association between the risk factor and outcome.

The other pair of diagonal arrows emanating from On-Trial LDL Subfractions (at arrow D) represent how the associations between LDL subfractions and CVD may be altered after patients have begun treatment.

The other type of analysis found is an association between the change in LDL subfractions and later CVD outcomes (E).

figure

Briefly, associations between baseline LDL subfractions and CVD events could be analyzed separately for treatment and control arms, and then compared. In theory, if patients on treatment have a lessened association between their baseline LDL subfractions and incident CVD than patients in the control arm, then the treatment may be beneficial for those patients at increased risk of CVD based on their LDL subfractions. Associations between LDL subfractions while study subjects are being treated and CVD events can be evaluated. Interpretation of the possible meaning of differences in associations on and off treatment is complex, and may not convincingly demonstrate the connections among treatment for LDL particle size, particle size, and outcomes. Or associations between the change in LDL subfractions while on treatment (or control) and CVD events can be analyzed. In theory, the association could be analyzed separately for treated and control patients. As will be discussed below, however, studies analyzed all patients together; it is implied that changed LDL subfractions were related to treatment. These analyses address whether altering LDL subfractions may be effective at altering CVD risk; however, by lumping treatment and control, it would be unclear whether the changes related to treatment, as opposed to changes correlated to other factors, were what altered CVD event rates.

The necessary analyses (or subanalyses) in clinical trials to determine whether treatment of LDL subfractions may be effective at reducing CVD events are depicted in Figure 2. These approaches follow the reasoning that would be used by clinicians and patients to decide whether active treatment of abnormal LDL subfractions is worthwhile for reducing the risk of CVD events (this simple model does not account for other factors such as adverse events, effects on other diseases, or cost). Patients with abnormal LDL subfractions fall into two broad categories, those with normal lipoprotein (LDL and HDL) cholesterol and triglyceride concentrations and those with abnormal LDL and/or HDL cholesterol and/or triglyceride concentrations. We focus on these cholesterol risk factors, as opposed to others such as blood pressure and diabetes control, because the treatments that have been evaluated in studies addressing this question all are primarily treatments for lipoprotein cholesterol or triglyceride concentrations.

The primary question addressed by these two study designs is whether treating patients specifically for their abnormal LDL subfractions, in the setting of either normal or abnormal lipoprotein cholesterol or triglyceride concentrations, would reduce their risk of CVD.

Figure 2 Analyses to demonstrate clinical effect of treatment of abnormal LDL subfractions

See text for description of figure.

text boxes

#### Results

Seven studies performed analyses regarding the associations among putative treatments, LDL subfractions, and CVD outcomes. 40,41,53,56,63,64,95 Two studies used NMR and are also reviewed in detail in Question 4.1.^40,41^ Two studies used GE methods that are not clinically available,53,56; three used ultracentrifugation.63,64,95

All studies were secondary analyses of randomized trials of lipid reduction interventions or (in one trial) a multifactorial cardiovascular risk reduction regimen in patients who had already had a cardiovascular event (secondary prevention). Each trial evaluated a specific group of patients at risk for another cardiovascular event, including groups such as men with normal LDL cholesterol but low HDL cholesterol concentrations (VA-HIT),40 men with a myocardial infarction before age 45 years, and other groups of patients whose lipoproteins were within constrained ranges. All trials had at least three-quarters men. No trial focused on people over age 65 years. Only one trial had almost half the subjects over age 65 years; 40 two excluded patients over 65 years.56,95 The percentage of patients with diabetes was not reported in most trials; the percentage of people who smoked (ever or current) ranged widely. Except for VA-HIT (which excluded patients with elevated LDL cholesterol), the mean LDL cholesterol concentrations was generally elevated (for patients with a history of cardiovascular events), ranging from 139 to 194 mg/dL.

##### Baseline LDL subfractions

Three fair quality trials reported on the potential association between baseline LDL subfractions and CVD outcomes, stratified by treatment (analysis C in Figure 1, Table 24). Rosenson 2002 and Miller 1996 performed secondary analyses of RCTs, one of pravastatin and one of a “risk reduction” protocol. Both evaluated changes in coronary minimum lumen diameter (MLD). Campos 2001 performed a nested case control study of a pravastatin RCT, where the cases were patients with confirmed myocardial infarction or cardiac death. All were secondary prevention trials, where patients had coronary artery disease. All three studies used different definitions of LDL subfractions.

Only Miller 1996 directly compared the associations between LDL subfraction and outcome across treatments. They measured change in MLD in subgroups of patients in multiple categories of LDL subfractions. Comparing patients receiving active risk reduction and those receiving usual care, patients in the risk reduction arm with small dense LDL had significantly smaller changes in their MLD than their counterparts in the usual care arm. Other LDL subfraction subgroups of patients did not have significantly different changes in their MLD based on treatment; though P values were less than 0.10 (favoring risk reduction) for patients in the middle or high tertiles of LDL density.

Both Rosenson 2002 and Campos 2001 found that statistically significant associations between LDL subfractions and CVD outcomes in the placebo arm were smaller and not statistically significant in the pravastatin arms. This may imply that pravastatin mitigated the effect that small LDL subfractions had on the risk of CVD, perhaps by reducing the absolute number of particles.

##### On-treatment LDL subfractions

Two fair quality secondary prevention trials reported on the potential association between on-treatment LDL subfractions and CVD outcomes, stratified by treatment (analysis D in Figure 1, Table 25). Both Rosenson 2002 and Mack 1996 performed secondary analyses of RCTs, one of pravastatin and one of lovastatin. Both evaluated progression of coronary artery disease. The studies used different methods for measuring LDL subfractions and definitions of the subfractions.

Both studies found that on-treatment (whether with a statin or placebo) LDL size (in angstroms or concentration of small particles) were not associated with progression of CVD. For Rosenson 2002, where baseline small LDL particles were associated with MLD progression in the placebo arm but not the statin arm, in contrast, this analysis of on-treatment associations may call into question the interpretation that pravastatin mitigated the effect that small LDL particles had on the risk of CVD. Mack 1996 does not provide evidence that the effect of lovastatin on progression of coronary stenosis is related to LDL subfractions. Rosenson 2002 did, however, find that 6 month particle concentration in the placebo arm, but not the statin arm, was associated with progression. However, in the absence of data on the baseline association between particle concentration and progression for each intervention, this information is difficult to interpret.

##### Change in LDL subfractions

Three studies reported on the potential association between the change in LDL subfractions during the trials and incident CVD (analysis E in Figure 1, Table 26). All were of poor quality regarding this analysis. Ruotolo 1998 and Zambon 1999 were subanalyses of RCTs of either bezafibrate or different treatments including lovastatin, colestipol, and niacin. Otvos 2006 was a nested case control study of an RCT of gemfibrozil. Outcomes included nonfatal myocardial infarction or cardiac death, MLD, and percent coronary stenosis. All were secondary prevention trials. Each used a different method for measuring and defining LDL subfractions.

Otvos 2006 and Ruotolo 1998 reported only that changes in LDL subfractions during the trials were not significantly associated with CVD outcomes; however, data were not provided. Zambon 1999 reported a statistically significant negative correlation between change in LDL particle buoyancy and change in percent coronary stenosis for all patients analyzed together. None of the studies reported on associations adjusted for other CVD risk factors. None stratified their analyses based on intervention.

#### Summary

Only one trial addressed the question of whether treatment (with lipid lowering agents or other cardiovascular risk factor modification) based on LDL subfractions may be associated with improved cardiovascular outcomes. In the SCRIP trial of diet, exercise, counseling, and drugs, the intervention was of greatest value in slowing progression of MLD in those people with small dense LDL However, no study evaluated whether treatment based on LDL subfractions is associated with improvement in true CVD outcomes (ie, either events or clinical severity). The three studies that evaluated treatment-stratified associations between baseline LDL subfractions and CVD weakly suggest that the risk of CVD that is associated with abnormal LDL subfractions may be mitigated by pravastatin or more general risk reduction, but this conclusion is partly offset by the lack of difference (between treatment and control) in associations in analyses of on-trial LDL subfractions. Three studies were inconsistent regarding whether changes in LDL subfractions are associated with improved CVD outcomes and are hampered by their failure to stratify their analyses. The applicability of these trials to the Medicare population is somewhat limited as these are all secondary prevention trials in predominantly young men.

Table 24 Association between baseline LDL subfraction and CVD outcome, stratified by treatment vs control

Author Year Country UI Quality | Test Category A | Population [Design] | Intervention (Duration) | N | Mean Age (>65^C^) {% Male} <% DM> [%Smoke D] | LDL-c (mg/dL) | Subfraction Data | | Outcome | | | Association | P value
Author Year Country UI Quality | Test Category A | Population [Design] | Intervention (Duration) | N | Mean Age (>65^C^) {% Male} <% DM> [%Smoke D] | LDL-c (mg/dL) | Definition | Base | Definition | Base | Rate/ Change | Association | P value
Rosenson 2002^41^ US 12106834 B | NMR | CAD LDL-c 130–189 Tg≤350 (PLAC-I) [RCT] | Pravastatin 40 mg/d (3 yr) | 130 | 58 (~20%) {76%} <nd> [nd] | 165 [117 A] | | | MLD | 1.99 | −0.018 | Unadjusted Correlation B
Rosenson 2002^41^ US 12106834 B | NMR | CAD LDL-c 130–189 Tg≤350 (PLAC-I) [RCT] | Pravastatin 40 mg/d (3 yr) | 130 | 58 (~20%) {76%} <nd> [nd] | 165 [117 A] | Size, Å | 207 | MLD | 1.99 | −0.018 | 0.11 | NS
Rosenson 2002^41^ US 12106834 B | NMR | CAD LDL-c 130–189 Tg≤350 (PLAC-I) [RCT] | Pravastatin 40 mg/d (3 yr) | 130 | 58 (~20%) {76%} <nd> [nd] | 165 [117 A] | Large, mg/dL | 84 | MLD | 1.99 | −0.018 | 0.04 | NS
Rosenson 2002^41^ US 12106834 B | NMR | CAD LDL-c 130–189 Tg≤350 (PLAC-I) [RCT] | Pravastatin 40 mg/d (3 yr) | 130 | 58 (~20%) {76%} <nd> [nd] | 165 [117 A] | Small, mg/dL | 43 | MLD | 1.99 | −0.018 | −0.12 | NS
Rosenson 2002^41^ US 12106834 B | NMR | CAD LDL-c 130–189 Tg≤350 (PLAC-I) [RCT] | Placebo | 111 | 58 (~20%) {76%} <nd> [nd] | 161 [164 A] | Size, Å | 207 | MLD | 2.00 | −0.053 | 0.14 | NS
Rosenson 2002^41^ US 12106834 B | NMR | CAD LDL-c 130–189 Tg≤350 (PLAC-I) [RCT] | Placebo | 111 | 58 (~20%) {76%} <nd> [nd] | 161 [164 A] | Large, mg/dL | 79 | MLD | 2.00 | −0.053 | 0.05 | NS
Rosenson 2002^41^ US 12106834 B | NMR | CAD LDL-c 130–189 Tg≤350 (PLAC-I) [RCT] | Placebo | 111 | 58 (~20%) {76%} <nd> [nd] | 161 [164 A] | Small, mg/dL | 40 | MLD | 2.00 | −0.053 | −0.21 | <.01
Miller 1996^63^ US 8901665 B | UC | CAD Lumen narrowing 5–69% (SCRIP) [RCT] | Diet, Exercise, Counseling, Drugs C (4 yr) | 97 | 57 (~20%) {100%} <nd> [nd] | 156 | | | MLD | 2.36 | nd | ΔMLD/yr | btw
Miller 1996^63^ US 8901665 B | UC | CAD Lumen narrowing 5–69% (SCRIP) [RCT] | Diet, Exercise, Counseling, Drugs C (4 yr) | 97 | 57 (~20%) {100%} <nd> [nd] | 156 | σ<1.03007 g/mL | 38% | MLD | 2.36 | nd | −0.049 | NS
Miller 1996^63^ US 8901665 B | UC | CAD Lumen narrowing 5–69% (SCRIP) [RCT] | Diet, Exercise, Counseling, Drugs C (4 yr) | 97 | 57 (~20%) {100%} <nd> [nd] | 156 | 1.03007–1.0355 | 28% | MLD | 2.36 | nd | −0.019 | .09
Miller 1996^63^ US 8901665 B | UC | CAD Lumen narrowing 5–69% (SCRIP) [RCT] | Diet, Exercise, Counseling, Drugs C (4 yr) | 97 | 57 (~20%) {100%} <nd> [nd] | 156 | >1.0355 | 34% | MLD | 2.36 | nd | −0.006 | .06
Miller 1996^63^ US 8901665 B | UC | CAD Lumen narrowing 5–69% (SCRIP) [RCT] | Diet, Exercise, Counseling, Drugs C (4 yr) | 97 | 57 (~20%) {100%} <nd> [nd] | 156 | sdLDL (S_f_° 0–5) | 42% | MLD | 2.36 | nd | −0.008 | .007 D
Miller 1996^63^ US 8901665 B | UC | CAD Lumen narrowing 5–69% (SCRIP) [RCT] | Diet, Exercise, Counseling, Drugs C (4 yr) | 97 | 57 (~20%) {100%} <nd> [nd] | 156 | Buoyant (S_f_° 5–12) | 58% | MLD | 2.36 | nd | −0.039 | NS E
Miller 1996^63^ US 8901665 B | UC | CAD Lumen narrowing 5–69% (SCRIP) [RCT] | Diet, Exercise, Counseling, Drugs C (4 yr) | 97 | 57 (~20%) {100%} <nd> [nd] | 156 | Pattern B | 39% | MLD | 2.36 | nd | −0.017 | NS
Miller 1996^63^ US 8901665 B | UC | CAD Lumen narrowing 5–69% (SCRIP) [RCT] | Diet, Exercise, Counseling, Drugs C (4 yr) | 97 | 57 (~20%) {100%} <nd> [nd] | 156 | Pattern I | 22% | MLD | 2.36 | nd | −0.017 | NS
Miller 1996^63^ US 8901665 B | UC | CAD Lumen narrowing 5–69% (SCRIP) [RCT] | Usual Care | 116 | 57 (~20%) {100%} <nd> [nd] | 156 | σ<1.03007 g/mL | 29% | MLD | 2.36 | nd | −0.045
Miller 1996^63^ US 8901665 B | UC | CAD Lumen narrowing 5–69% (SCRIP) [RCT] | Usual Care | 116 | 57 (~20%) {100%} <nd> [nd] | 156 | 1.03007–1.0355 | 38% | MLD | 2.36 | nd | −0.049
Miller 1996^63^ US 8901665 B | UC | CAD Lumen narrowing 5–69% (SCRIP) [RCT] | Usual Care | 116 | 57 (~20%) {100%} <nd> [nd] | 156 | >1.0355 | 33% | MLD | 2.36 | nd | −0.040
Miller 1996^63^ US 8901665 B | UC | CAD Lumen narrowing 5–69% (SCRIP) [RCT] | Usual Care | 116 | 57 (~20%) {100%} <nd> [nd] | 156 | sdLDL (S_f_° 0–5) | 44% | MLD | 2.36 | nd | −0.054
Miller 1996^63^ US 8901665 B | UC | CAD Lumen narrowing 5–69% (SCRIP) [RCT] | Usual Care | 116 | 57 (~20%) {100%} <nd> [nd] | 156 | Buoyant (S_f_° 5–12) | 58% | MLD | 2.36 | nd | −0.038
Miller 1996^63^ US 8901665 B | UC | CAD Lumen narrowing 5–69% (SCRIP) [RCT] | Usual Care | 116 | 57 (~20%) {100%} <nd> [nd] | 156 | Pattern B | 41% | MLD | 2.36 | nd | −0.046
Miller 1996^63^ US 8901665 B | UC | CAD Lumen narrowing 5–69% (SCRIP) [RCT] | Usual Care | 116 | 57 (~20%) {100%} <nd> [nd] | 156 | Pattern I | 31% | MLD | 2.36 | nd | −0.046
Campos 2001^53^ US 11572739 B | GE | Recent MI TC<240 LDL-c 115–174 Tg<350 (CARE) [Nested case control] | Pravastatin 40 mg (5 yr) | 377 | 60 (~30) {87%} <16%> [17%c] | 139 | | | Confirmed MI or CHD death | -- | 46% (10.2% in RCT) | Adjusted RR F
Campos 2001^53^ US 11572739 B | GE | Recent MI TC<240 LDL-c 115–174 Tg<350 (CARE) [Nested case control] | Pravastatin 40 mg (5 yr) | 377 | 60 (~30) {87%} <16%> [17%c] | 139 | Size, Å | 256 | Confirmed MI or CHD death | -- | 46% (10.2% in RCT) | II: ~1 | NS
Campos 2001^53^ US 11572739 B | GE | Recent MI TC<240 LDL-c 115–174 Tg<350 (CARE) [Nested case control] | Pravastatin 40 mg (5 yr) | 377 | 60 (~30) {87%} <16%> [17%c] | 139 | I (237–247 Å) | 20% | Confirmed MI or CHD death | -- | 46% (10.2% in RCT) | III: ~0.9 | NS
Campos 2001^53^ US 11572739 B | GE | Recent MI TC<240 LDL-c 115–174 Tg<350 (CARE) [Nested case control] | Pravastatin 40 mg (5 yr) | 377 | 60 (~30) {87%} <16%> [17%c] | 139 | I (237–247 Å) | 20% | Confirmed MI or CHD death | -- | 46% (10.2% in RCT) | IV: ~1.2 | NS
Campos 2001^53^ US 11572739 B | GE | Recent MI TC<240 LDL-c 115–174 Tg<350 (CARE) [Nested case control] | Pravastatin 40 mg (5 yr) | 377 | 60 (~30) {87%} <16%> [17%c] | 139 | II (248–254 Å) | 20% | Confirmed MI or CHD death | -- | 46% (10.2% in RCT) | V: 1.33 | NS
Campos 2001^53^ US 11572739 B | GE | Recent MI TC<240 LDL-c 115–174 Tg<350 (CARE) [Nested case control] | Placebo | 460 | 60 (~30) {87%} <16%> [17%c] | 139 | III (255–259 Å) | 20% | Confirmed MI or CHD death | -- | 53% (13.2% in RCT) | II: 2.08 | .03
Campos 2001^53^ US 11572739 B | GE | Recent MI TC<240 LDL-c 115–174 Tg<350 (CARE) [Nested case control] | Placebo | 460 | 60 (~30) {87%} <16%> [17%c] | 139 | IV (260–262 Å) | 20% | Confirmed MI or CHD death | -- | 53% (13.2% in RCT) | III: 2.42 | .01
Campos 2001^53^ US 11572739 B | GE | Recent MI TC<240 LDL-c 115–174 Tg<350 (CARE) [Nested case control] | Placebo | 460 | 60 (~30) {87%} <16%> [17%c] | 139 | V (263–277 Å) | 20% | Confirmed MI or CHD death | -- | 53% (13.2% in RCT) | IV: 2.72 | .008
Campos 2001^53^ US 11572739 B | GE | Recent MI TC<240 LDL-c 115–174 Tg<350 (CARE) [Nested case control] | Placebo | 460 | 60 (~30) {87%} <16%> [17%c] | 139 | V (263–277 Å) | 20% | Confirmed MI or CHD death | -- | 53% (13.2% in RCT) | V: 4.00 | .001

A 6 months.

B Spearman (rank) correlation, adjusted for baseline MLD, race, sex, and age. An inverse association indicates that high baseline levels are associated with a reduction in lumen diameter (adverse outcome).

C Goal: LDL<110 mg/dL, triglycerides<100 mg/dL, HDL>55 mg/dL.

D For change in mean diameter and % stenosis, there was no significant difference between interventions for patients with small dense LDL (P=.09 and .08, respectively).

E For change in mean diameter and % stenosis, there was no significant difference between interventions for patients with buoyant LDL (P=.93 and .67, respectively).

F Relative risk of outcome compared to Quintile I.

Table 25 Association between on-treatment LDL subfraction and CVD outcome, stratified by treatment vs control

Author Year Country UI Quality | Test Category A | Population [Design] | Intervention (Duration) | N | Mean Age (>65^C^) {% Male} <% DM> [%Smoke ^D^] | LDL-c (mg/dL) | Subfraction Data | | Outcome | | | Association | P value
Author Year Country UI Quality | Test Category A | Population [Design] | Intervention (Duration) | N | Mean Age (>65^C^) {% Male} <% DM> [%Smoke ^D^] | LDL-c (mg/dL) | Definition | On Trial | Definition | Base | Rate/ Change | Association | P value
Rosenson 2002^41^ US 12106834 B | NMR | CAD LDL-c 130–189 Tg≤350 (PLAC-I) [RCT] | Pravastatin 40 mg/d (3 yr) | 130 | 58 (~20%) {76%} <nd> [nd] | 165 [117 A] | 6 mo data | | MLD | 1.99 | −0.018 | Adjusted Correlation B
Rosenson 2002^41^ US 12106834 B | NMR | CAD LDL-c 130–189 Tg≤350 (PLAC-I) [RCT] | Pravastatin 40 mg/d (3 yr) | 130 | 58 (~20%) {76%} <nd> [nd] | 165 [117 A] | Particle concentration, nmol/L | 1858 | MLD | 1.99 | −0.018 | −0.10 | NS
Rosenson 2002^41^ US 12106834 B | NMR | CAD LDL-c 130–189 Tg≤350 (PLAC-I) [RCT] | Pravastatin 40 mg/d (3 yr) | 130 | 58 (~20%) {76%} <nd> [nd] | 165 [117 A] | Size, Å | 208 | MLD | 1.99 | −0.018 | 0.14 | NS
Rosenson 2002^41^ US 12106834 B | NMR | CAD LDL-c 130–189 Tg≤350 (PLAC-I) [RCT] | Pravastatin 40 mg/d (3 yr) | 130 | 58 (~20%) {76%} <nd> [nd] | 165 [117 A] | Large, mg/dL | 69 | MLD | 1.99 | −0.018 | 0.03 | NS
Rosenson 2002^41^ US 12106834 B | NMR | CAD LDL-c 130–189 Tg≤350 (PLAC-I) [RCT] | Pravastatin 40 mg/d (3 yr) | 130 | 58 (~20%) {76%} <nd> [nd] | 165 [117 A] | Small, mg/dL | 30 | MLD | 1.99 | −0.018 | −0.14 | NS
Rosenson 2002^41^ US 12106834 B | NMR | CAD LDL-c 130–189 Tg≤350 (PLAC-I) [RCT] | Placebo | 111 | 58 (~20%) {76%} <nd> [nd] | 161 [164 A] | Particle concentration, nmol/L | 1918 | MLD | 2.00 | −0.053 | −0.24 | <.05
Rosenson 2002^41^ US 12106834 B | NMR | CAD LDL-c 130–189 Tg≤350 (PLAC-I) [RCT] | Placebo | 111 | 58 (~20%) {76%} <nd> [nd] | 161 [164 A] | Size, Å | 207 | MLD | 2.00 | −0.053 | 0.10 | NS
Rosenson 2002^41^ US 12106834 B | NMR | CAD LDL-c 130–189 Tg≤350 (PLAC-I) [RCT] | Placebo | 111 | 58 (~20%) {76%} <nd> [nd] | 161 [164 A] | Large, mg/dL | 79 | MLD | 2.00 | −0.053 | 0.01 | NS
Rosenson 2002^41^ US 12106834 B | NMR | CAD LDL-c 130–189 Tg≤350 (PLAC-I) [RCT] | Placebo | 111 | 58 (~20%) {76%} <nd> [nd] | 161 [164 A] | Small, mg/dL | 43 | MLD | 2.00 | −0.053 | −0.18 | NS
Mack 1996^64^ US 8963728 B | UC | CAD TC 190–295 37–67 yo (MARS) [RCT] | Lovastatin 80 mg (2 yr) | 114 | 58 (~15%) {92%} <nd> [79%e] | 156 | IV (S_f_ 0–3), mg/dL | 14.7 | Coronary stenosis (progression) | 37% | Progression in 51% of lesions | Unadjusted OR (per 10 mg/dL)
Mack 1996^64^ US 8963728 B | UC | CAD TC 190–295 37–67 yo (MARS) [RCT] | Lovastatin 80 mg (2 yr) | 114 | 58 (~15%) {92%} <nd> [79%e] | 156 | IV (S_f_ 0–3), mg/dL | 14.7 | Coronary stenosis (progression) | 37% | Progression in 51% of lesions | 1.6 | NS
Mack 1996^64^ US 8963728 B | UC | CAD TC 190–295 37–67 yo (MARS) [RCT] | Placebo | 106 | 58 (~15%) {92%} <nd> [79%e] | 156 | IV (S_f_ 0–3), mg/dL | 14.7 | Coronary stenosis (progression) | 37% | Progression in 51% of lesions | 1.6 | NS

A 6 months.

B Spearman (rank) correlation, adjusted for baseline MLD, race, sex, and age; and triglycerides, LDL and HDL cholesterol. An inverse association indicates that high baseline levels are associated with a reduction in lumen diameter (adverse outcome).

Table 26 Association between change in LDL subfraction, on intervention (control), and CVD outcome

Author Year Country UI Quality | Test Category^A^ | Population [Design] | Intervention (Duration) | N | Mean Age (>65^C^) {% Male} <% DM> [%Smoke^D^] | LDL-c (mg/dL), Base [on trial] | Subfraction Data | | | Outcome | | | Association | | P value
Author Year Country UI Quality | Test Category^A^ | Population [Design] | Intervention (Duration) | N | Mean Age (>65^C^) {% Male} <% DM> [%Smoke^D^] | LDL-c (mg/dL), Base [on trial] | Definition | Base | Change | Definition | Base | Rate/ Change | Association | | P value
Otvos 2006^40^ US 16534013 C | NMR | CAD; LDL-c≤140 Tg;≤300 HDL-c≤40 (VA-HIT) [Nested case control] | Gemfibrozil 1200 mg/d (5.1 yr, median) | 515 | 64 yr (~45%) {100%} <30%> [20%c] | 112 [115^B^] | Size, Å | 204 | +5 | Nonfatal MI or CHD death | -- | 17%^C^ | Unadj: | NR^D^ | NS
Otvos 2006^40^ US 16534013 C | NMR | CAD; LDL-c≤140 Tg;≤300 HDL-c≤40 (VA-HIT) [Nested case control] | Gemfibrozil 1200 mg/d (5.1 yr, median) | 515 | 64 yr (~45%) {100%} <30%> [20%c] | 112 [115^B^] | Large, nmol/L | 354 | +126 | Nonfatal MI or CHD death | -- | 17%^C^ | Unadj: | NR^D^ | NS
Otvos 2006^40^ US 16534013 C | NMR | CAD; LDL-c≤140 Tg;≤300 HDL-c≤40 (VA-HIT) [Nested case control] | Gemfibrozil 1200 mg/d (5.1 yr, median) | 515 | 64 yr (~45%) {100%} <30%> [20%c] | 112 [115^B^] | Small, nmol/L | 967 | −190 | Nonfatal MI or CHD death | -- | 17%^C^ | Unadj: | NR^D^ | NS
Otvos 2006^40^ US 16534013 C | NMR | CAD; LDL-c≤140 Tg;≤300 HDL-c≤40 (VA-HIT) [Nested case control] | Placebo | 546 | 64 yr (~45%) {100%} <30%> [20%c] | 112 [112^B^] | Size, nm | 204 | −1 | Nonfatal MI or CHD death | -- | 22%^C^ | Adj: | not analyzed
Otvos 2006^40^ US 16534013 C | NMR | CAD; LDL-c≤140 Tg;≤300 HDL-c≤40 (VA-HIT) [Nested case control] | Placebo | 546 | 64 yr (~45%) {100%} <30%> [20%c] | 112 [112^B^] | Large, nmol/L | 346 | −1 | Nonfatal MI or CHD death | -- | 22%^C^ | Adj: | not analyzed
Otvos 2006^40^ US 16534013 C | NMR | CAD; LDL-c≤140 Tg;≤300 HDL-c≤40 (VA-HIT) [Nested case control] | Placebo | 546 | 64 yr (~45%) {100%} <30%> [20%c] | 112 [112^B^] | Small, nmol/L | 984 | +99 | Nonfatal MI or CHD death | -- | 22%^C^ | Adj: | not analyzed
Ruotolo 1998^56^ Sweden 9822092 C | GE | MI <45 yo; TC≥200 Tg≥140 Coronary stenosis (BECAIT) [RCT] | Bezafibrate 600 mg/d (5 yr) | 47 | 42 yr (0%) {100%} <nd> [24%c] | 180 [159] | Size, Å | 230 | +3.2 | MLD | 1.82 | −0.06 | Unadj: | NR^D^ | NS
Ruotolo 1998^56^ Sweden 9822092 C | GE | MI <45 yo; TC≥200 Tg≥140 Coronary stenosis (BECAIT) [RCT] | Bezafibrate 600 mg/d (5 yr) | 47 | 42 yr (0%) {100%} <nd> [24%c] | 180 [159] | % Small | 41.4 | −9.7 | MLD | 1.91 | −0.17 | Adj: | not analyzed
Ruotolo 1998^56^ Sweden 9822092 C | GE | MI <45 yo; TC≥200 Tg≥140 Coronary stenosis (BECAIT) [RCT] | Placebo | 45 | 42 yr (0%) {100%} <nd> [24%c] | 179 [171] | Size, Å | 231 | +0.2 | % Stenosis | 36.5 | +1.70 | Unadj: | NR^E^ | NS
Ruotolo 1998^56^ Sweden 9822092 C | GE | MI <45 yo; TC≥200 Tg≥140 Coronary stenosis (BECAIT) [RCT] | Placebo | 45 | 42 yr (0%) {100%} <nd> [24%c] | 179 [171] | % Small | 35.9 | −0.3 | % Stenosis | 35.2 | +4.25 | Adj: | not analyzed
Zambon 1999^95^ US 10208998 C | UC | CAD Family Hx ≤62 yo Apo B≥125 (FATS) [RCT] | Lovastatin 40 mg/d & Colestipol 30 g/d (2.5 yr) | 31 | 47 yr (0%) {100%} <nd> [24%c] | 194 [102] | Buoyancy (Rf) | 0.261 | +0.020 | % Stenosis | 36% | −1.25% | Unadj: | r=−0.61 | <.001
Zambon 1999^95^ US 10208998 C | UC | CAD Family Hx ≤62 yo Apo B≥125 (FATS) [RCT] | Niacin 4 g/d & Colestipol 30 g/d | 26 | 47 yr (0%) {100%} <nd> [24%c] | 191 [131] | Buoyancy (Rf) | 0.252 | +0.026 | % Stenosis | 36% | −0.7% | Unadj: | r=−0.61 | <.001
Zambon 1999^95^ US 10208998 C | UC | CAD Family Hx ≤62 yo Apo B≥125 (FATS) [RCT] | Colestipol if LDL-c≥90^th^ percentile | 13 | 47 yr (0%) {100%} <nd> [24%c] | 177 [160] | Buoyancy (Rf) | 0.267 | −0.018 | % Stenosis | 30% | +1.87% | Adj: | not analyzed
Zambon 1999^95^ US 10208998 C | UC | CAD Family Hx ≤62 yo Apo B≥125 (FATS) [RCT] | Placebo if LDL-c<90^th^ percentile | 18 | 47 yr (0%) {100%} <nd> [24%c] | 177 [160] | Buoyancy (Rf) | 0.250 | −0.008 | % Stenosis | 30% | +1.87% | Adj: | not analyzed

A CITP; GE; HPLC; NMR; UC; Other

B 7 months

C Within complete trial (219/1264 on gemfibrozil; 275/1267 on placebo). Data within nested case control study not reported.

D Not reported. “Additional analyses (results not shown) indicated that no change (by concentration or percentage) in any of the … lipoprotein particle variables was a significant predictor of CHD risk.”

E Not reported. “Percentage change in … lipoprotein … concentrations from baseline to mean on-trial levels did not correlate significantly with any of the angiographic outcome variables (… with control for treatment assignment, baseline angiographic score, age, [body mass index], smoking and alcohol consumption).”