# Methods

This report on the low density lipoprotein (LDL) subfractions and associations with CVD is based on a systematic review of the literature, selected review articles, and Food and Drug Administration (FDA) documents.

## Search Strategy

A comprehensive search of the scientific literature was conducted to identify relevant studies addressing the key questions. Our final search was conducted on August 22 2007. We searched MEDLINE (from 1950 to present), CAB Abstracts (1973 to present), the Cochrane Clinical Trial Registry (3^rd^ quarter 2007), and the Cochrane Database of Systematic Reviews (3^rd^ quarter 2007) to identify articles relevant to each key question. In electronic searches, we used various terms for LDL, particle size/subfractions, and test methodologies, limited to humans and English language (see Appendix A for complete search strategy). The same literature data set was used for all key questions. We did not systematically search for unpublished data with the exception of FDA documents, as described below.

## Classification of LDL Subfraction Methods (Tests)

For the purposes of our analyses, we divided the researched methods into different categories:

- Nuclear Magnetic Resonance (NMR). This method uses NMR techniques to measure amplitudes of spectral signals emitted by lipoprotein subfractions of different sizes. This method is available for clinical use via a small number of medical laboratories.
- LipoPrint™. This is a measurement technique clinically available that uses a standardized method for using linear polyacrylamide gel electrophoresis to separate LDL particles on the basis of size and to a lesser extent charge. The kit and instrument for this method are marketed by Quantimetrix.
- Berkeley HeartLab^®^ gradient gel electrophoresis. This is a standardized system using a specific gradient GE to provide LDL subfraction patterns. The standardized version of this system is performed only at the Berkeley HeartLab^®^, but is clinically available.
- Gel electrophoresis (GE) (Bench). This covers a wide range of methods using GE. These methods are either not standardized or, if standardized, are not routinely used by clinical laboratories. In general, researchers prepare their own gels and use their own methods for running the analyses. Different compounds are used to create the gels, though polyacrylamide is most common, and different distributions of gel densities are used. These methods are time- and resource-intensive.
- Ultracentrifugation. This covers a wide range of methods that separate lipoprotein particles on the basis of density, either sequentially and continuously, prior to lipid or apoprotein analysis. These methods are time- and resource-intensive.
- Other methods that were considered include high pressure liquid chromatography (HPLC), capillary isotachophoresis (CITP), Lipophor™ (another GE method developed by Quantimetrix), and other techniques. In addition, other clinically available methods for measuring LDL subfractions include an ultracentrifugation technique performed at the University of Washington’s Northwest Lipid Research Laboratory and the Vertical Auto Profile^®^. However, as described in the results section for Question 4, no studies eligible for the clinical associations portions of this review used these latter two methods.

## Study Selection

We assessed titles and/or abstracts of citations identified from literature searches for inclusion, using the criteria described below. For studies that potentially met the criteria, the full text articles were retrieved and a second review was conducted to determine inclusion by reapplying the eligibility criteria. A low threshold was used to retrieve articles for full rescreening.

### Eligibility criteria for key question 1 (routinely used measurement methods and reference standards)

General approach: Discussion regarding methods (tests) that are available for routine use or that may be used as a reference standard. The term “routine” was operationalized to mean that the method could be suitable for use by a commercial or institutional clinical laboratory for measuring LDL subfractions, as ordered by clinicians.

Study design: Narrative or systematic review, editorial or letter with references. English language. Published since 2001.

Intervention: Methods (tests) for the measurement of LDL subfraction distribution.

In addition, to identify methods submitted to the Food and Drug Administration (FDA) for clearance to proceed to market, the FDA Clinical Laboratory Improvement Act (CLIA) database was searched for all listed analyte names with “lipoprotein fractions” and for “nuclear magnetic resonance/NMR” test systems or specific manufacturers. All documents and internet links associated with the FDA CLIA records were examined for the relevance to the methods of measuring or separating LDL subfractions.

### Eligibility criteria for key questions 2 and 3 (test performance)

Population: Human serum samples. If information is provided on the individuals, then they must be at least 18 years old.

Intervention: Any method to measure LDL subfraction distribution.

Comparators: For question 2, studies must have compared methods from two or more different categories of methods (as described above). Exclude studies that evaluated only incremental or technical changes to the methods. For question 3.1, studies must have drawn serum samples from the same volunteers on multiple days within a short period of time (we did not set a strict upper limit on the time frame). For question 3.2, studies must have measured the same serum samples using the same methods at least twice.

Outcomes: We allowed any method of comparing test accuracy, validity, or consistency, including sensitivity/specificity, Bland-Altman plots, correlation (r), or measures of variability.

Design: Articles must report original data; review articles were excluded. Articles must have been peer reviewed; letters and abstracts were excluded. The dataset must include serum samples from at least 10 individuals for each method.

### Eligibility criteria for key questions 4.1–4.3 (association with CVD)

Population: Adult humans (≥18 years old). Excluded highly atypical populations on a case by case basis (eg, a study of people with hypopituitary growth hormone deficiency was excluded).

Predictors: LDL subfraction information, including size, concentration, or subclass pattern, using any method (test). Serum (or plasma) samples must be drawn prior to outcomes (for incidence studies) or at least 1 month after a cardiovascular event (for prevalence studies) to allow time for stabilization of lipoproteins after the event. Studies were excluded if they used a measurement method that was determined to be outdated to the extent that there is little comparability to modern methods. For question 4.2, studies must report the incremental change in diagnostic performance over other cardiovascular risk assessment tools. For question 4.3, studies must report complete results of multivariable analyses that included both LDL subfractions and other cardiovascular risk factors (though not exclusively other lipoprotein subfractions). For all questions we did not evaluate differences in constituents of LDL, such as percent total protein, apo B, cholesteryl esters, or triglycerides.

Outcomes: Clinical or selected surrogate cardiovascular outcomes, including cardiovascular events, clinical CVD status (eg, diagnosis or prevalence of CVD, stage or severity of CVD), intima-media thickness (IMT, Doppler ultrasonography measurement of degree of arterial atherosclerosis), or electron beam computerized tomography (EBCT, a measurement of calcium deposits in the coronary vessels).

Design: Prospective or retrospective, cross-sectional (for prevalence) or longitudinal (for incidence). Single or parallel cohort studies, case control or nested case control studies. Data set must include at least 10 subjects per study group. Studies must report sufficient data or analyses to assess the association between LDL subfractions and cardiovascular outcomes. No minimum duration for longitudinal studies.

### Eligibility criteria for key question 4.4 (therapy, LDL subfraction, & CVD)

Population: Adult humans (≥18 years old). Excluded highly atypical populations on a case by case basis.

Interventions: Pharmaceutical or other intervention hypothesized to beneficially affect LDL subfractions.

Comparators: Other interventions that may affect LDL subfractions, or placebo, usual care, or no treatment.

Outcomes: Clinical or selected surrogate cardiovascular outcomes, including cardiovascular events, clinical CVD status (eg, diagnosis or prevalence of CVD, stage or severity of CVD), IMT (Doppler ultrasonography measurement of degree of arterial atherosclerosis), or electron beam computerized tomography (EBCT, a measurement of calcium deposits in the coronary vessels).

Analyses: At a minimum, the studies must have reported how the baseline or on-trial LDL subfractions were associated with CVD outcomes, stratified by intervention (i.e., the associations in both the intervention and the control arms), or they must have reported how the change in LDL subfractions from baseline to on-trial was associated with CVD outcomes. Studies were excluded (for this question) if they reported associations between baseline or on-trial LDL subfractions and CVD outcomes if they pooled interventions, even if they adjusted for intervention in a multivariable model.

Design: Randomized controlled trials (RCTs) or nested case control studies within an RCT. Dataset must include at least 10 subjects per arm (or original arm of the RCT). No minimum duration.

## Data Extraction

Separate data extraction forms were designed for questions 2 & 3 and for question 4. For studies that met criteria for questions 4.1–4.4, full data extraction was completed only for studies that used specific methods or kits that are currently available for clinical use or had the samples analyzed by laboratories that also perform LDL subfraction analyses for clinical use (using the same methods that are currently used for clinical samples). We used the best information available to us from CMS, FDA, domain experts, the reviewed studies, internet searches, invited reviewers, and conversations with several laboratories to determine which methods are available for clinical use. We also used the best available information to determine whether the specific methods used by investigators are similar to the methods used by clinical laboratories; however, we did not contact investigators. Because the methods used in other studies are not clinically available in the US, data from studies that used these other methods were summarized only briefly (see below for more details). For eligible studies we extracted data on study year, country, setting, funding source, study design, timing of endpoints (if applicable), eligibility criteria, measurement method, comparator (if applicable), definitions of outcomes, subject characteristics (if applicable), and baseline, final, or correlation results for outcomes of interest (as applicable).

For question 4.1–4 we focused on two types of analyses: adjusted analyses (multivariable analyses where the association between LDL subfraction and CVD outcomes were adjusted for LDL cholesterol, HDL cholesterol, non-HDL cholesterol, and/or triglycerides); and unadjusted analyses (whether completely unadjusted or, if these data are not reported, adjusted only for variables not included in the adjusted list, such as other lipoprotein subfractions, clinical history, demographics, or blood pressure).

For questions 4.1–4.4 studies of “other” methods, data were extracted directly into summary tables.

## Quality Assessment

We assessed the methodological quality of each fully extracted study (and all question 4.4 studies) based on predefined criteria. We used a 3-category grading system (A, B, C) to denote the methodological quality of each study. This grading system has been used in most of the previous evidence reports from the Tufts EPC as well as in evidence-based clinical practice guidelines. This system defines a generic grading system that is applicable to varying study designs including randomized and nonrandomized comparative trials, cohort, and case-control studies. Studies were not rejected due to poor quality.

- A (good)
  Good quality studies are likely to have the least bias and results are considered valid. They include studies that adhere most closely to the commonly held concepts of high quality including the following: a formal randomized controlled study; clear description of the population, setting, interventions, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; no reporting errors; clear reporting of dropouts; and no obvious bias. For studies evaluating associations between LDL subfractions and CVD outcomes, only those that evaluated incidence or progression of disease in longitudinal studies were eligible to be a grade A study. The association between LDL subfractions and prevalent CVD was not deemed to be a clinically high quality analysis.
- B (fair)
  Fair quality studies are susceptible to some bias, but not sufficient to invalidate the results. They do not meet all the criteria in category A because they have some deficiencies, but none likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems.
- C (poor)
  Poor quality studies have substantial bias that may invalidate the results. These studies have serious problems in design, analysis, or reporting; have large amounts of missing information, large dropout rates, discrepancies in reporting, lack of proper adjustments for relevant variables, or other major sources of bias.

## Applicability Assessment

Applicability addresses the relevance of a given study to a population of interest. Every study applies certain eligibility criteria when selecting study subjects. Most of these criteria are explicitly stated (eg, disease status, age, comorbidities). Some may be implicit or due to unintentional biases, such as those related to location (eg, multicenter vs. single center, intensive care vs. all inpatients), year of procedure, and other issues. The applicability of a study is dictated by the key questions, the populations, and the interventions that are of interest to this review, as opposed to those of interest to the original investigators.

We categorized studies within a target population into 1 of 3 levels of applicability that are defined as follows:

High | Sample is representative of Medicare population in relevant settings. Patients’ age (older adult), gender, spectrum of disease severity and type, etc. are representative of population of interest. No substantial exclusion criteria that would make the sample atypical of Medicare patients for whom LDL subfraction testing might be considered.
Moderate | Sample is an important subgroup of population of interest. Possibly limited by a narrow or young age range, type of disease, gender, restrictive eligibility criteria, etc.
Low | Sample represents only a narrow, atypical subgroup of population of interest.

## Summary Tables

For each question we summarized data in summary tables which include data on study design characteristics, subject characteristics, test method, number of subjects (or samples) analyzed, results data, and for most questions, quality, and applicability.

Most tables include details of the outcome data as reported by the study authors. However, because of the large number of studies that used methods that are not available for clinical use and because of the limited applicability of these studies to clinical practice (given the lack of standardization of LDL subfraction measurement or reporting), we report only qualitative results for each of these studies that addressed questions 4.1–4.3. Symbols were used to denote statistically significant positive or negative associations between LDL subfractions and CVD outcomes, lack of association, or in a few cases what the authors reported as substantial associations but where statistical analysis was not reported. See Tables 9 and following for the symbols and their definitions. Analyses that were adjusted or unadjusted for lipoproteins are presented in separate columns, with differently shaded symbols. For these tables, we distinguished between measurements of “size” (diameter in angstroms) and measurements of “pattern.” Pattern covered all the different measurements of specific subfraction concentrations (or other levels), proportions (compared to overall or other subfractions), and other measurements describing the distribution of subfractions.

For question 4.1, grand summary tables (Tables 14–16) were also created, presenting clinically available methods and other methods together. These describe the number and type of studies that found positive, negative or no associations with CVD outcomes in both unadjusted and adjusted analyses. The final table (Table 16) also summarizes those studies that reported both unadjusted and adjusted analyses, to evaluate the effect of adjusting for lipoproteins.

For questions 4.2 and 4.3, separate summary tables were created for incident and prevalent CVD, each clinically available method, and univariable and multivariable analyses. Univariable and multivariable sets of data that do not include LDL subfraction are not included. Each table includes the same list of potential cardiovascular risk factors. This list was derived from the evaluated studies. It includes, in order, the LDL subfraction measures, the lipoprotein cholesterol and triglyceride concentrations, the risk factors used by ATP III2 and JNC 7,^13^ and other potential risk factors. The other lipoprotein subfractions are omitted from analysis. The primary purpose of the evaluation of the multivariable analyses for this report is to determine whether any measures of LDL subfractions are predictors of outcomes independent of other known or commonly measured predictors of or risk factors for CVD used in clinical practice. The approach used, and this report in general, is not meant to evaluate etiology of any associations. The tables are designed to describe the relative strengths of the associations between the risk factors and the CVD outcomes, not to describe each model created by individual studies or the value, per se, of each risk factor. Therefore, to maintain simplicity and readability, the measurement units for each risk factor are not included in the tables (except for percent of subjects. Other tables provide the more detailed data for the LDL subfractions. The original papers should be read for other detailed data. Unadjusted risk factors were ranked based on the statistical significance of their association with the outcome. From adjusted, multivariable models, the risk factors with the strongest associations with the CVD outcomes (eg, largest OR) are tabulated.

For question 4.4, tables were created based on the different potential analyses described under Eligibility criteria key question 4.4, above. Separate tables were created for data on the association between changes in LDL subfraction and CVD outcomes, between baseline LDL subfraction and outcomes stratified by intervention, and between on-trial LDL subfraction and outcomes stratified by intervention. Results are given for analyses both unadjusted and adjusted for lipoprotein concentrations.