# Introduction

Cardiovascular disease (CVD) is the leading cause of disability and death in the US.1 Identifying individuals at high risk for CVD and aggressively treating them is a critical component to lower the population-wide disease burden. The Adult Treatment Panel III (ATP III) of the Expert Panel of the National Cholesterol Education Program has identified a group of risk factors associated with CVD. Risk factor assessment is used to estimate individual risk and inform decisions on course of treatment and target goals for the efficacy of treatment once it has been initiated. Cardiovascular risk factors addressed by ATP III (in addition to elevated LDL cholesterol) include cigarette smoking, hypertension (blood pressure > 140/90 mm Hg or on antihypertensive medication), low concentration of high density lipoprotein (HDL) cholesterol (< 40 gm/dL), family history of premature coronary heart disease (CHD), and older age (women > 55 years; men > 45 years).2 For individuals with two or more risk factors, ATP III recommends estimating a 10-year CHD risk score (Framingham Score) and making treatment recommendations and setting LDL cholesterol goals on the basis of this score.3

Recently, questions have been raised as to how well the standard ATP III criteria for estimating CVD risk identifies high-risk individuals and whether additional diagnostic criteria are needed to adequately estimate CVD risk.4–7 For the most part, this controversy has centered on the incremental value of additional risk factors to those currently used. Some additional candidate risk factors include high sensitivity C-reactive protein, lipoprotein-associated phospholipase A2, N-terminal pro-atrial natriuretic peptide, aldosterone, renin, fibrinogen, D-dimer, plasminogen-activator inhibitor type 1, homocysteine, urinary albumin-to-creatinine ratio, hemoglobin A1c, lipoprotein (a) [Lp(a)], apoprotein (apo) A-I, apo B and LDL particle size.

It has been suggested that determining LDL particle size distribution provides additional predictive power to LDL cholesterol measurement alone to estimate an individual’s CVD risk.2 On the basis of particle density, small dense LDL particles are thought to confer a higher level of risk than larger less dense LDL particles.8,9 In vitro, small dense LDL particles are taken up more avidly by macrophages than larger less dense LDL particles.10 This may be related to small dense LDL being more susceptible to oxidative modification or having a greater binding potential to arterial wall proteoglycans than the larger less dense LDL particles. Higher plasma concentrations of small dense LDL tend to be associated with higher concentrations of triglyceride and apo B-100, and lower concentrations of HDL cholesterol and apo A-I, each of which has independently been associated with increased CVD risk.11

The American Diabetes Association, together with the American College of Cardiology Foundation, convened a panel of experts to develop a consensus position for patients with “cardiometabolic risk.” 12 In their opinion, LDL particle number, as measured by nuclear magnetic resonance (NMR) may be a better discriminator of risk than LDL cholesterol and that both LDL particle concentration and LDL size are “important predictors of CVD;” though several limitations, including availability and accuracy of the method, were noted. Despite this consensus piece, it has yet to be determined whether CVD risk assessment and treatment decisions would be improved if LDL subfraction measurements were available to clinicians and were factored into the decision making process. Furthermore, there are numerous disparate systems currently available to estimate LDL subfractions, though most are labor-intensive and/or require long assay turnaround times, making them impractical for routine use by clinical laboratories. Were LDL subfractions associated with altered CVD risk, it is unclear whether the different characteristics of the LDL subfractions assessed by the different methods would result in similar predictive qualities for estimating CVD risk. It is also unclear whether measuring LDL subfractions would be of incremental benefit over measurement and treatment of traditional cardiovascular risk factors.

Multiple terms are used in the literature to describe LDL subfractions and related features of LDL, including LDL subclasses, particles, particle concentration, particle numbers, and patterns. These terms describe separate, but sometimes overlapping features of LDL. For simplicity, this report uses what we believe is the most generic term, subfractions, except where specific measurements are being described. We acknowledge that this term does not completely describe all measured features of LDL, be we determined it was a reasonable compromise to reduce the burden of repeatedly listing terms. LDL subfraction clearly has deficiencies as a generic term, and our use of the term is not meant as a recommendation that this term be adopted by the research community. We also do not mean to suggest that that the disparate methods for analyzing LDL can be fully subsumed in a single concept.

In December 2006 the Food and Drug Administration (FDA) held a public hearing on lipoprotein subfractions (www.fda.gov/OHRMS/DOCKETS/ac/06/transcripts/2006-4263t1-01t.pdf, accessed Feb 19, 2008). Several questions were formulated from this meeting regarding the use of LDL (and HDL) subfractions for clinical decision making. Based on this hearing, the Centers for Medicare & Medicaid Services (CMS) requested a review of the literature on LDL subfractions and the risk of CVD. After an early overview of the potentially relevant literature by the Tufts Evidence-based Practice Center (Tufts EPC), the questions of interest for this report were restricted to a description of the measurement methods that potentially could be routinely used by clinical laboratories, comparisons of the different measurement methods, a review of the evidence regarding the association between LDL subfractions and CVD, and a review of studies that evaluated an intervention that may “improve” LDL subfraction profiles and also evaluated cardiovascular outcomes. The primary population of interest for this review is the over age 65 Medicare population; however, data from all adults are also of interest to CMS.

## Key questions to be addressed

1. What are the methods that have been proposed to be used routinely to measure LDL subfractions? Is there a method that is considered the reference standard?
2. How do different methods of measuring LDL subfractions compare in terms of test performance?
3.1 How much variability is there in measures of LDL subfractions from day to day?
3.2 How much variability is there in measures of LDL subfractions within the same individual (measure to measure)?
4.1 What is the relationship between LDL subfractions and outcome measures related to CVD?
4.2 If these tests are used in combination with other cardiovascular risk assessment technologies, what is the incremental increase of diagnostic performance?
4.3 If there is a relationship between LDL subfractions and CVD, how strong is it relative to other risk factors?
4.4 What do studies report regarding the link between therapies to alter LDL subfractions and CVD outcomes?