# Potential Treatment Studies

Abbasi F, Chu JW, McLaughlin T, et al. Effect of metformin treatment on multiple cardiovascular disease risk factors in patients with type 2 diabetes mellitus. Metabolism: Clinical & Experimental. 2004. UI 14767866. Metformin
Abbey M, Owen A, Suzakawa M, et al. Effects of menopause and hormone replacement therapy on plasma lipids, lipoproteins and LDL-receptor activity. Maturitas. 1999. UI 10656504. Hormone treatment
Aguilar-Salinas CA, Arita MO, Sauque RL, et al. Effects of estrogen/medrogestone therapy on the apoprotein B-containing lipoproteins in postmenopausal women with type 2 diabetes mellitus under satisfactory and non-satisfactory glycemic control. Israel Medical Association Journal: Imaj. 2001. UI 11344825. Hormone treatment
Alexandersen P, Haarbo J, Christiansen C. Impact of combined hormone replacement therapy on serum lipid metabolism: new aspects. Gynecological Endocrinology. 1997. UI 9272426. Hormone treatment
Almario RU, Vonghavaravat V, Wong R, Kasim-Karakas SE. Effects of walnut consumption on plasma fatty acids and lipoproteins in combined hyperlipidemia. American Journal of Clinical Nutrition. 2001. UI 11451720. Walnuts
Altena TS, Michaelson JL, Ball SD, et al. Lipoprotein subfraction changes after continuous or intermittent exercise training. Medicine & Science in Sports & Exercise. 2006. UI 16531908. Exercise
Ambring A, Friberg P, Axelsen M, et al. Effects of a Mediterranean-inspired diet on blood lipids, vascular function and oxidative stress in healthy subjects. Clinical Science. 2004. UI 14683522. Mediterranean diet
Anber V, Millar JS, McConnell M, et al. Interaction of very-low-density, intermediate-density, and low-density lipoproteins with human arterial wall proteoglycans. Arteriosclerosis, Thrombosis & Vascular Biology. 1997. UI 9409221. Fibrate
Andrade RJ, Garcia-Escano MD, Valdivielso P, et al. Effects of interferon-beta on plasma lipid and lipoprotein composition and post-heparin lipase activities in patients with chronic hepatitis C. Alimentary Pharmacology & Therapeutics. 2000. UI 10886050. Interferonbeta
Arosio M, Sartore G, Rossi CM, et al. LDL physical properties, lipoprotein and Lp(a) levels in acromegalic patients. Effects of octreotide therapy. Italian Multicenter Octreotide Study Group. Atherosclerosis. 2000. UI 10924734. Octreotide (acromegaly)
Ashton EL, Best JD, Ball MJ. Effects of monounsaturated enriched sunflower oil on CHD risk factors including LDL size and copper-induced LDL oxidation. Journal of the American College of Nutrition. 2001. UI 11506059. Sunflower oil
Avogaro P, Cazzolato G. Changes in the composition and physico-chemical characteristics of serum lipoproteins during ethanol-induced lipaemia in alcoholic subjects. Metabolism: Clinical & Experimental. 1975. UI 171538. Alcohol withdrawal
Ayaori M, Ishikawa T, Yoshida H, et al. Beneficial effects of alcohol withdrawal on LDL particle size distribution and oxidative susceptibility in subjects with alcohol-induced hypertriglyceridemia. Arteriosclerosis, Thrombosis & Vascular Biology. 1997. UI 9409225. Alcohol withdrawal
Bachen EA, Muldoon MF, Matthews KA, Manuck SB. Effects of hemoconcentration and sympathetic activation on serum lipid responses to brief mental stress. Psychosomatic Medicine. 2002. UI 12140348. Labetolol
Backes JM, Gibson CA. Effect of lipid-lowering drug therapy on small-dense low-density lipoprotein. Annals of Pharmacotherapy. 2005. UI 15671087. Lipid lowering
Baldassarre S, Scruel O, Deckelbaum RJ, et al. Beneficial effects of atorvastatin on sd LDL and LDL phenotype B in statinnaive patients and patients previously treated with simvastatin or pravastatin. International Journal of Cardiology. 2005. UI 16186066. Statin
Barnes JF, Farish E, Rankin M. Hart diabetes. A comparison of the effects of two continuous Hormone treatment regimens on cardiovascular risk factors. Atherosclerosis. 2002. UI 11755937. Hormone treatment
Baumstark MW, Frey I, Berg A. Acute and delayed effects of prolonged exercise on serum lipoproteins. II. Concentration and composition of low-density lipoprotein subfractions and very low-density lipoproteins. European Journal of Applied Physiology & Occupational Physiology. 1993. UI 8354253. Exercise
Bavirti S, Ghanaat F, Tayek JA. Peroxisome proliferator-activated receptor-gamma agonist increases both low-density lipoprotein cholesterol particle size and small high-density lipoprotein cholesterol in patients with type 2 diabetes independent of diabetic control. Endocrine Practice. 2003. UI 14715475. Troglitazone
Berg A, Baumstark MW, Frey I, et al. Clinical and therapeutic use of probucol. European Journal of Clinical Pharmacology. 1991. UI 2044650. Probucol
Blaha V, Zadak Z, Solichova D, et al. Hypocholesterolemic effect of pravastatin is associated with increased content of antioxidant vitamin-E in cholesterol fractions. Acta Medica (Hradec Kralove). 1998. UI 9729642. Pravastatin
Blake GJ, Albert MA, Rifai N, Ridker PM. Effect of pravastatin on LDL particle concentration as determined by NMR spectroscopy: a substudy of a randomized placebo controlled trial. European Heart Journal. 2003. UI 14563343. Pravastatin
Bos G, Poortvliet MC, Scheffer PG, et al. Dietary polyunsaturated fat intake is associated with low-density lipoprotein size, but not with susceptibility to oxidation in subjects with impaired glucose metabolism and type II diabetes: the Hoorn study. European Journal of Clinical Nutrition. 2007. UI 16943850. Dietary fat
Bradley K, Flack JM, Belcher J, et al. Chlorthalidone attenuates the reduction in total cholesterol and small, dense LDL cholesterol subclass associated with weight loss. American Journal of Hypertension. 1993. UI 8398006. Chlorthalidone
Bredie SJ, Bosch FH, Demacker PN, et al. Effects of peritoneal dialysis with an overnight icodextrin dwell on parameters of glucose and lipid metabolism. Peritoneal Dialysis International. 2001. UI 11475343. Icodextrin
Bredie SJ, de Bruin TW, Demacker PN, et al. Comparison of gemfibrozil versus simvastatin in familial combined hyperlipidemia and effects on apolipoprotein-B-containing lipoproteins, low-density lipoprotein subfraction profile, and low-density lipoprotein oxidizability. American Journal of Cardiology. 1995. UI 7856526. Gemfibrazole, Simvastatin
Brousseau ME, Goldkamp AL, Collins D, et al. Polymorphisms in the gene encoding lipoprotein lipase in men with low HDL-C and coronary heart disease: the Veterans Affairs HDL Intervention Trial. Journal of Lipid Research. 2004. UI 15292370. Gemfibrazole
Brousseau ME, Schaefer EJ, Wolfe ML, et al. Effects of an inhibitor of cholesteryl ester transfer protein on HDL cholesterol. New England Journal of Medicine. 2004. UI 15071125. Torcetrapib
Brussaard HE, Gevers Leuven JA, Kluft C, et al. Effect of 17 beta-estradiol on plasma lipids and LDL oxidation in postmenopausal women with type II diabetes mellitus. Arteriosclerosis, Thrombosis & Vascular Biology. 1997. UI 9081688. Estrogen
Byrne DJ, Neil HA, Vallance DT, Winder AF. A pilot study of garlic consumption shows no significant effect on markers of oxidation or sub-fraction composition of low-density lipoprotein including lipoprotein(a) after allowance for non-compliance and the placebo effect. Clinica Chimica Acta. 1999. UI 10481920. Garlic
Caixas A, Ordonez-Llanos J, de LA, et al. Optimization of glycemic control by insulin therapy decreases the proportion of small dense LDL particles in diabetic patients. Diabetes. 1997. UI 9200657. Insulin
Caixas A, Perez A, Payes A, et al. Effects of a short-acting insulin analog (Insulin Lispro) versus regular insulin on lipid metabolism in insulin-dependent diabetes mellitus. Metabolism: Clinical & Experimental. 1998. UI 9580247. Insulin
Calabresi L, Donati D, Pazzucconi F, et al. Omacor in familial combined hyperlipidemia: effects on lipids and low density lipoprotein subclasses. Atherosclerosis. 2000. UI 10657575. Omega 3
Campos H, Blijlevens E, McNamara JR, et al. LDL particle size distribution. Results from the Framingham Offspring Study. Arteriosclerosis & Thrombosis. 1992. UI 1450174. Dietary fat, cholesterol
Campos H, Dreon diabetes, Krauss RM. Associations of hepatic and lipoprotein lipase activities with changes in dietary composition and low density lipoprotein subclasses. Journal of Lipid Research. 1995. UI 7775858. Dietary fat
Campos H, Sacks FM, Walsh BW, et al. Differential effects of estrogen on low-density lipoprotein subclasses in healthy postmenopausal women. Metabolism: Clinical & Experimental. 1993. UI 8412768. Estrogen
Campos H, Wilson PW, Jimenez D, et al. Differences in apolipoproteins and low-density lipoprotein subfractions in postmenopausal women on and off estrogen therapy: results from the Framingham Offspring Study. Metabolism: Clinical & Experimental. 1990. UI 2120547. Estrogen
Charest A, Desroches S, Vanstone CA, et al. Unesterified plant sterols and stanols do not affect LDL electrophoretic characteristics in hypercholesterolemic subjects. Journal of Nutrition. 2004. UI 14988452. Sterols, Stanols
Charest A, Vanstone C, St-Onge MP, et al. Phytosterols in nonfat and low-fat beverages have no impact on the LDL size phenotype. European Journal of Clinical Nutrition. 2005. UI 15856068. Phytosterol
Cheung MC, Austin MA, Moulin P, et al. Effects of pravastatin on apolipoprotein-specific high density lipoprotein subpopulations and low density lipoprotein subclass phenotypes in patients with primary hypercholesterolemia. Atherosclerosis. 1993. UI 8257447. Pravastatin
Clifton PM, Noakes M, Nestel PJ. LDL particle size and LDL and HDL cholesterol changes with dietary fat and cholesterol in healthy subjects. Journal of Lipid Research. 1998. UI 9741692. Dietary fat, cholesterol
da Costa Vieira JL, Gomes ME, Almeida AB, Moriguchi EH. Changes in the profile of lipoprotein subfractions associated with hormone replacement therapy. Arquivos Brasileiros de Cardiologia. 2001. UI 11262568. Hormone treatment
Davidson MH, Bays HE, Stein E, et al. Effects of fenofibrate on atherogenic dyslipidemia in hypertriglyceridemic subjects. Clinical Cardiology. 2006. UI 16796078. Fenofibrate
Davy BM, Davy KP, Ho RC, et al. High-fiber oat cereal compared with wheat cereal consumption favorably alters LDL-cholesterol subclass and particle numbers in middle-aged and older men. American Journal of Clinical Nutrition. 2002. UI 12145006. Oat
de GJ, Demacker PN, Stalenhoef AF. The effect of simvastatin treatment on the low-density lipoprotein subfraction profile and composition in familial hypercholesterolaemia. Netherlands Journal of Medicine. 1993. UI 8107933. Simvastatin
de Graaf J, Hendriks JC, Demacker PN, Stalenhoef AF. Identification of multiple dense LDL subfractions with enhanced susceptibility to in vitro oxidation among hypertriglyceridemic subjects. Normalization after clofibrate treatment. Arteriosclerosis & Thrombosis. 1993. UI 8485123. Clofibrate
de Graaf J, Swinkels DW, Demacker PN, et al. Differences in the low density lipoprotein subfraction profile between oral contraceptive users and controls. Journal of Clinical Endocrinology & Metabolism. 1993. UI 8421088. Oral contraceptive
Desroches S, Mauger JF, Ausman LM, et al. Soy protein favorably affects LDL size independently of isoflavones in hypercholesterolemic men and women. Journal of Nutrition. 2004. UI 14988449. Soy protein
Dornbrook-Lavender KA, Joy MS, nu-Ciocca CJ, et al. Effects of atorvastatin on low-density lipoprotein cholesterol phenotype and C-reactive protein levels in patients undergoing long-term dialysis. Pharmacotherapy. 2005. UI 15843280. Atorvastatin
Dreon diabetes. Fernstrom HA, Campos H, et al. Change in dietary saturated fat intake is correlated with change in mass of large low-density-lipoprotein particles in men. American Journal of Clinical Nutrition. 1998. UI 9583838. Diets
Dreon diabetes. Fernstrom HA, Miller B, Krauss RM. Apolipoprotein E isoform phenotype and LDL subclass response to a reduced-fat diet. Arteriosclerosis, Thrombosis & Vascular Biology. 1995. UI 7749804. Diets
Dreon diabetes. Fernstrom HA, Miller B, Krauss RM. Low-density lipoprotein subclass patterns and lipoprotein response to a reduced-fat diet in men. FASEB Journal. 1994. UI 8299884. Diets
Dreon diabetes. Fernstrom HA, Williams PT, Krauss RM. A very low-fat diet is not associated with improved lipoprotein profiles in men with a predominance of large, low-density lipoproteins. American Journal of Clinical Nutrition. 1999. UI 10075324. Diets
Dreon diabetes. Fernstrom HA, Williams PT, Krauss RM. LDL subclass patterns and lipoprotein response to a low-fat, high-carbohydrate diet in women. Arteriosclerosis, Thrombosis & Vascular Biology. 1997. UI 9108784. Diets
Dumesnil JG, Turgeon J, Tremblay A, et al. Effect of a low-glycaemic index--low-fat--high protein diet on the atherogenic metabolic risk profile of abdominally obese men. British Journal of Nutrition. 2001. UI 11737954. Diets
Ebenbichler CF, Laimer M, Kaser S, et al. Relationship between cholesteryl ester transfer protein and atherogenic lipoprotein profile in morbidly obese women. Arteriosclerosis, Thrombosis & Vascular Biology. 2002. UI 12231567. Bariatric surgery
Elisaf MS, Petris C, Bairaktari E, et al. The effect of moxonidine on plasma lipid profile and on LDL subclass distribution. Journal of Human Hypertension. 1999. UI 10578224. Moxonidine
Empen K, Geiss HC, Lehrke M, et al. Effect of atorvastatin on lipid parameters, LDL subtype distribution, hemorrheological parameters and adhesion molecule concentrations in patients with hypertriglyceridemia. Nutrition Metabolism & Cardiovascular Diseases. 2003. UI 12929621. Atorvastatin
Farish E, Spowart K, Barnes JF, et al. Effects of postmenopausal hormone replacement therapy on lipoproteins including lipoprotein(a) and LDL subfractions. Atherosclerosis. 1996. UI 8879436. Estrogen
Feher MD, Caslake M, Foxton J, et al. Atherogenic lipoprotein phenotype in type 2 diabetes: reversal with micronised fenofibrate. Diabetes/Metabolism Research Reviews. 1999. UI 10634964. Fenofibrate
Forster LF, Stewart G, Bedford D, et al. Influence of atorvastatin and simvastatin on apolipoprotein B metabolism in moderate combined hyperlipidemic subjects with low VLDL and LDL fractional clearance rates. Atherosclerosis. 2002. UI 12119202. Atorvastatin, Simvastatin
Foulon T, Payen N, Laporte F, et al. Effects of two low-dose oral contraceptives containing ethinylestradiol and either desogestrel or levonorgestrel on serum lipids and lipoproteins with particular regard to LDL size. Contraception. 2001. UI 11535207. Oral contraceptive
Franceschini G, Cassinotti M, Vecchio G, et al. Pravastatin effectively lowers LDL cholesterol in familial combined hyperlipidemia without changing LDL subclass pattern. Arteriosclerosis & Thrombosis. 1994. UI 7918306. Pravastatin
Franceschini G, Lovati MR, Manzoni C, et al. Effect of gemfibrozil treatment in hypercholesterolemia on low density lipoprotein (LDL) subclass distribution and LDL-cell interaction. Atherosclerosis. 1995. UI 7605377. Gemfibrozil
Freed MI, Ratner R, Marcovina SM, et al. Effects of rosiglitazone alone and in combination with atorvastatin on the metabolic abnormalities in type 2 diabetes mellitus. American Journal of Cardiology. 2002. UI 12398960. Rosiglitazone
Frost RJ, Otto C, Geiss HC, et al. Effects of atorvastatin versus fenofibrate on lipoprotein profiles, low-density lipoprotein subfraction distribution, and hemorheologic parameters in type 2 diabetes mellitus with mixed hyperlipoproteinemia. American Journal of Cardiology. 2001. UI 11137832. Atorvastatin, Fenofibrate
Geiss HC, Otto C, Parhofer KG. Effect of ezetimibe on low-density lipoprotein subtype distribution: results of a placebo-controlled, doubleblind trial in patients treated by regular low-density lipoprotein apheresis and statins. Metabolism: Clinical & Experimental. 2006. UI 16631435. Ezetimibe
Geiss HC, Otto C, Schwandt P, Parhofer KG. Effect of atorvastatin on low-density lipoprotein subtypes in patients with different forms of hyperlipoproteinemia and control subjects. Metabolism: Clinical & Experimental. 2001. UI 11474489. Atorvastatin
Geiss HC, Schwandt P, Parhofer KG. Influence of simvastatin on LDL-subtypes in patients with heterozygous familial hypercholesterolemia and in patients with diabetes mellitus and mixed hyperlipoproteinemia. Experimental & Clinical Endocrinology & Diabetes. 2002. UI 12058342. Simvastatin
Giri S, Thompson PD, Taxel P, et al. Oral estrogen improves serum lipids, homocysteine and fibrinolysis in elderly men. Atherosclerosis. 1998. UI 9622279. 17beta-estradiol
Goldberg RB, Kendall diabetes, Deeg MA, et al. A comparison of lipid and glycemic effects of pioglitazone and rosiglitazone in patients with type 2 diabetes and dyslipidemia. Diabetes Care. 2005. UI 15983299. Pioglitazone, Rosiglitazone
Goulet J, Lamarche B, Charest A, et al. Effect of a nutritional intervention promoting the Mediterranean food pattern on electrophoretic characteristics of low-density lipoprotein particles in healthy women from the Quebec City metropolitan area. British Journal of Nutrition. 2004. UI 15333160. Mediterranean diet
Granfone A, Campos H, McNamara JR, et al. Effects of estrogen replacement on plasma lipoproteins and apolipoproteins in postmenopausal, dyslipidemic women. Metabolism: Clinical & Experimental. 1992. UI 1435290. Estrogen
Greene CM, Waters D, Clark RM, et al. Plasma LDL and HDL characteristics and carotenoid content are positively influenced by egg consumption in an elderly population. Nutrition & Metabolism. 2006. UI 20073026003. Eggs
Griffin B, Farish E, Walsh D, et al. Response of plasma low density lipoprotein subfractions to oestrogen replacement therapy following surgical menopause. Clinical Endocrinology. 1993. UI 8287573. Estrogen
Griffin BA, Caslake MJ, Gaw A, et al. Effects of cholestyramine and acipimox on subfractions of plasma low density lipoprotein. Studies in normolipidaemic and hypercholesterolaemic subjects. European Journal of Clinical Investigation. 1992. UI 1633833. Cholestyramine, Acipimox
Griffin MD, Sanders TA, Davies IG, et al. Effects of altering the ratio of dietary n-6 to n-3 fatty acids on insulin sensitivity, lipoprotein size, and postprandial lipemia in men and postmenopausal women aged 45-70 y: the OPTILIP Study. American Journal of Clinical Nutrition. 2006. UI 17158408. Omega 3:Omega 6
Guerin M, Dolphin PJ, Talussot C, et al. Pravastatin modulates cholesteryl ester transfer from HDL to apoB-containing lipoproteins and lipoprotein subspecies profile in familial hypercholesterolemia. Arteriosclerosis, Thrombosis & Vascular Biology. 1995. UI 7670950. Pravastatin
Guerin M, Egger P, Soudant C, et al. Dose-dependent action of atorvastatin in type IIB hyperlipidemia: preferential and progressive reduction of atherogenic apoB-containing lipoprotein subclasses (VLDL-2, IDL, small dense LDL) and stimulation of cellular cholesterol efflux. Atherosclerosis. 2002. UI 12052475. Atorvastatin
Guerin M, Le GW, Frisdal E, et al. Action of ciprofibrate in type IIb hyperlipoproteinemia: modulation of the atherogenic lipoprotein phenotype and stimulation of high-density lipoprotein-mediated cellular cholesterol efflux. Journal of Clinical Endocrinology & Metabolism. 2003. UI 12915663. Ciprofibrate
Gylling H, Miettinen TA. Serum cholesterol and cholesterol and lipoprotein metabolism in hypercholesterolaemic NIDdiabetes patients before and during sitostanol ester-margarine treatment. Diabetologia. 1994. UI 7988779. Sitostanol ester
Halle M, Berg A, Garwers U, et al. Influence of 4 weeks' intervention by exercise and diet on low-density lipoprotein subfractions in obese men with type 2 diabetes. Metabolism: Clinical & Experimental. 1999. UI 10337867. Exercise, diet
Halverstadt A, Phares DA, Wilund KR, et al. Endurance exercise training raises high-density lipoprotein cholesterol and lowers small low-density lipoprotein and very low-density lipoprotein independent of body fat phenotypes in older men and women. Metabolism: Clinical & Experimental. 2007. UI 17378998. Exercise
Harder H, Dinesen B, Astrup A. The effect of a rapid weight loss on lipid profile and glycemic control in obese type 2 diabetic patients. International Journal of Obesity & Related Metabolic Disorders: Journal of the International Association for the Study of Obesity. 2004. UI 14610532. Diet, low calorie
Harper CR, Edwards MC, Jacobson TA. Flaxseed oil supplementation does not affect plasma lipoprotein concentration or particle size in human subjects. Journal of Nutrition. 2006. UI 17056811. Flaxseed
Hayashi K, Kurushima H, Kuga Y, et al. Comparison of the effect of bezafibrate on improvement of atherogenic lipoproteins in Japanese familial combined hyperlipidemic patients with or without impaired glucose tolerance. Cardiovascular Drugs & Therapy. 1998. UI 9607127. Bezafibrate
Hayashi T, Hirano T, Yamamoto T, et al. Intensive insulin therapy reduces small dense low-density lipoprotein particles in patients with type 2 diabetes mellitus: relationship to triglyceride-rich lipoprotein subspecies. Metabolism: Clinical & Experimental. 2006. UI 16784958. Intensive diabetes treatment
Hays JH, DiSabatino A, Gorman RT, et al. Effect of a high saturated fat and no-starch diet on serum lipid subfractions in patients with documented atherosclerotic cardiovascular disease. Mayo Clinic Proceedings. 2003. UI 14601690. Diet, Saturated fatty acids, Low starch
Herbst KL, Amory JK, Brunzell JD, et al. Testosterone administration to men increases hepatic lipase activity and decreases HDL and LDL size in 3 wk. American Journal of Physiology - Endocrinology & Metabolism. 2003. UI 12736156. Testosterone
Hermenegildo C, Garcia-Martinez MC, Tarin JJ, et al. The effect of oral hormone replacement therapy on lipoprotein profile, resistance of LDL to oxidation and LDL particle size. Maturitas. 2001. UI 11358646. Hormone treatment
Hermenegildo C, Garcia-Martinez MC, Valldecabres C, et al. Transdermal estradiol reduces plasma myeloperoxidase levels without affecting the LDL resistance to oxidation or the LDL particle size. Menopause. 2002. UI 11875328. Estradiol
Herron KL, Lofgren IE, Sharman M, et al. High intake of cholesterol results in less atherogenic low-density lipoprotein particles in men and women independent of response classification. Metabolism: Clinical & Experimental. 2004. UI 15164336. Eggs
Hirano T, Yoshino G, Kashiwazaki K, Adachi M. Doxazosin reduces prevalence of small dense low density lipoprotein and remnant-like particle cholesterol levels in nondiabetic and diabetic hypertensive patients. American Journal of Hypertension. 2001. UI 11587157. Doxazosin
Homma Y, Kobayashi T, Yamaguchi H, et al. Specific reduction of plasma large, light low-density lipoprotein by a bile acid sequestering resin, cholebine (MCI-196) in type II hyperlipoproteinemia. Atherosclerosis. 1997. UI 9105567. Cholebine
Homma Y, Kobayashi T, Yamaguchi H, et al. Decrease of plasma large, light LDL (LDL1), HDL2 and HDL3 levels with concomitant increase of cholesteryl ester transfer protein (CETP) activity by probucol in type II hyperlipoproteinemia. Artery. 1993. UI 8447724. Probucol
Homma Y, Moriguchi EH, Sakane H, et al. Effects of probucol on plasma lipoprotein subfractions and activities of lipoprotein lipase and hepatic triglyceride lipase. Atherosclerosis. 1991. UI 1892484. Probucol
Homma Y, Ohshima K, Yamaguchi H, et al. Effects of eicosapentaenoic acid on plasma lipoprotein subfractions and activities of lecithin:cholesterol acyltransferase and lipid transfer protein. Atherosclerosis. 1991. UI 1811549. Fish oil
Homma Y, Ozawa H, Kobayashi T, et al. Effects of bezafibrate therapy on subfractions of plasma low-density lipoprotein and high-density lipoprotein, and on activities of lecithin:cholesterol acyltransferase and cholesteryl ester transfer protein in patients with hyperlipoproteinemia. Atherosclerosis. 1994. UI 8060379. Bezafibrate
Homma Y, Ozawa H, Kobayashi T, et al. Effects of simvastatin on plasma lipoprotein subfractions, cholesterol esterification rate, and cholesteryl ester transfer protein in type II hyperlipoproteinemia. Atherosclerosis. 1995. UI 7605391. Simvastatin
Ikejiri A, Hirano T, Murayama S, et al. Effects of atorvastatin on triglyceriderich lipoproteins, low-density lipoprotein subclass, and C-reactive protein in hemodialysis patients. Metabolism: Clinical & Experimental. 2004. UI 15334369. Atorvastatin
Ikewaki K, Noma K, Tohyama J, et al. Effects of bezafibrate on lipoprotein subclasses and inflammatory markers in patients with hypertriglyceridemia--a nuclear magnetic resonance study. International Journal of Cardiology. 2005. UI 15907413. Bezafibrate
Ikewaki K, Tohyama J, Nakata Y, et al. Fenofibrate effectively reduces remnants, and small dense LDL, and increases HDL particle number in hypertriglyceridemic men - a nuclear magnetic resonance study. Journal of Atherosclerosis & Thrombosis. 2004. UI 15557710. Fenofibrate
Jenkins DJ, Kendall CW, Vuksan V, et al. Effect of wheat bran on serum lipids: influence of particle size and wheat protein. Journal of the American College of Nutrition. 1999. UI 10204832. Wheat Bran
Kalogirou M, Tsimihodimos V, Gazi I, et al. Effect of ezetimibe monotherapy on the concentration of lipoprotein subfractions in patients with primary dyslipidaemia. Current Medical Research & Opinion. 2007. UI 17519084. Ezetimibe
Kasim-Karakas SE, Lane E, Almario R, et al. Effects of dietary fat restriction on particle size of plasma lipoproteins in postmenopausal women. Metabolism: Clinical & Experimental. 1997. UI 9109849. Dietary fat
Katzel LI, Coon PJ, Rogus E, et al. Persistence of low HDL-C levels after weight reduction in older men with small LDL particles. Arteriosclerosis, Thrombosis & Vascular Biology. 1995. UI 7749838. Weight loss
Kazama H, Usui S, Okazaki M, et al. Effects of bezafibrate and pravastatin on remnant-like lipoprotein particles and lipoprotein subclasses in type 2 diabetes. Diabetes Research & Clinical Practice. 2003. UI 12590014. Pravastatin, Bezafibrate
Kearney T, de Gallegos CN, Proudler A, et al. Effects of short- and long-term growth hormone replacement on lipoprotein composition and on very-low-density lipoprotein and low-density lipoprotein apolipoprotein B100 kinetics in growth hormone-deficient hypopituitary subjects. Metabolism: Clinical & Experimental. 2003. UI 12524662. Growth hormone
Keidar S, Goldberg AC, Cook K, et al. High carbohydrate fat-free diet modulates epitope expression of LDL-apoB-100 and interaction of LDL with human fibroblasts. Journal of Lipid Research. 1989. UI 2480987. Diet
Keidar S, Goldberg AC, Cook K, et al. High carbohydrate fat-free diet modulates epitope expression of LDL-apoB-100 and interaction of LDL with human fibroblasts. Journal of Lipid Research. 1989. UI 19911438981. Diet
Kelley DS, Rasooly R, Jacob RA, et al. Consumption of Bing sweet cherries lowers circulating concentrations of inflammation markers in healthy men and women. Journal of Nutrition. 2006. UI 16549461. Bing cherries
Kim MK, Campos H. Intake of trans fatty acids and low-density lipoprotein size in a Costa Rican population. Metabolism: Clinical & Experimental. 2003. UI 12800093. Trans fatty acids
Kondo A, Morita H, Nakamura H, et al. Influence of fibrate treatment on malondialdehyde-modified LDL concentration. Clinica Chimica Acta. 2004. UI 14687899. Fibrate
Kontopoulos AG, Athyros VG, Papageorgiou AA, et al. Effects of simvastatin and ciprofibrate alone and in combination on lipid profile, plasma fibrinogen and low density lipoprotein particle structure and distribution in patients with familial combined hyperlipidaemia and coronary artery disease. Coronary Artery Disease. 1996. UI 8993943. Simvastatin, Ciprofibrate
Kratz M, Gulbahce E, von EA, et al. Dietary mono- and polyunsaturated fatty acids similarly affect LDL size in healthy men and women. Journal of Nutrition. 2002. UI 11925466. Dietary fats
Krauss RM. Dreon diabetes. Low-density-lipoprotein subclasses and response to a low-fat diet in healthy men. American Journal of Clinical Nutrition. 1995. UI 7625363. Diet, low fat
Kuvin JT, Dave diabetes, Sliney KA, et al. Effects of extended-release niacin on lipoprotein particle size, distribution, and inflammatory markers in patients with coronary artery disease. American Journal of Cardiology. 2006. UI 16950175. Niacin
Lagrost L, Athias A, Lemort N, et al. Plasma lipoprotein distribution and lipid transfer activities in patients with type IIb hyperlipidemia treated with simvastatin. Atherosclerosis. 1999. UI 10217372. Simvastatin
Lahdenpera S, Puolakka J, Pyorala T, et al. Effects of postmenopausal estrogen/progestin replacement therapy on LDL particles; comparison of transdermal and oral treatment regimens. Atherosclerosis. 1996. UI 8769679. Hormone treatment
Lai CQ, Arnett DK, Corella D, et al. Fenofibrate effect on triglyceride and postprandial response of apolipoprotein A5 variants: the GOLDN study. Arteriosclerosis, Thrombosis & Vascular Biology. 2007. UI 17431185. Fenofibrate
Lai CQ, Corella D, Demissie S, et al. Dietary intake of n-6 fatty acids modulates effect of apolipoprotein A5 gene on plasma fasting triglycerides, remnant lipoprotein concentrations, and lipoprotein particle size: the Framingham Heart Study. Circulation. 2006. UI 16636175. Diet, n-6 FA
Lamarche B, Desroches S, Jenkins DJ, et al. Combined effects of a dietary portfolio of plant sterols, vegetable protein, viscous fibre and almonds on LDL particle size. British Journal of Nutrition. 2004. UI 15522135. "Healthy" foods
Lamon-Fava S, Fisher EC, Nelson ME, et al. Effect of exercise and menstrual cycle status on plasma lipids, low density lipoprotein particle size, and apolipoproteins. Journal of Clinical Endocrinology & Metabolism. 1989. UI 2491859. Exercise
Lamon-Fava S, McNamara JR, Farber HW, et al. Acute changes in lipid, lipoprotein, apolipoprotein, and low-density lipoprotein particle size after an endurance triathlon. Metabolism: Clinical & Experimental. 1989. UI 2505019. Endurance training
Landray MJ, Hartland A, Hubscher D, et al. Effect of atorvastatin on low-density lipoprotein subfraction profile. Annals of Clinical Biochemistry. 1999. UI 10370746. Atorvastatin
Lariviere M, Lamarche B, Pirro M, et al. Effects of atorvastatin on electrophoretic characteristics of LDL particles among subjects with heterozygous familial hypercholesterolemia. Atherosclerosis. 2003. UI 12618273. Atorvastatin
Lawrence JM, Reid J, Taylor GJ, et al. The effect of high dose atorvastatin therapy on lipids and lipoprotein subfractions in overweight patients with type 2 diabetes. Atherosclerosis. 2004. UI 15135263. Atorvastatin
Le ML, Valensi P, Charniot JC, et al. Serum 1H-nuclear magnetic spectroscopy followed by principal component analysis and hierarchical cluster analysis to demonstrate effects of statins on hyperlipidemic patients. NMR in Biomedicine. 2005. UI 16075416. Simvastatin, Atorvastatin
Le NA, Innis-Whitehouse W, Li X, et al. Lipid and apolipoprotein levels and distribution in patients with hypertriglyceridemia: effect of triglyceride reductions with atorvastatin. Metabolism: Clinical & Experimental. 2000. UI 10690940. Atorvastatin
Lemieux I, Laperriere L, Dzavik V, et al. A 16-week fenofibrate treatment increases LDL particle size in type IIA dyslipidemic patients. Atherosclerosis. 2002. UI 11996956. Fenofibrate
Lepage S, Nigon F, Bonnefont-Rousselot D, et al. Oxidizability of atherogenic low-density lipoprotein subspecies in severe familial hypercholesterolemia: impact of long-term low-density lipoprotein apheresis. Journal of Cardiovascular Pharmacology & Therapeutics. 2000. UI 11150388. LDL apheresis
Li Z, Lamon-Fava S, Otvos J, et al. Fish consumption shifts lipoprotein subfractions to a less atherogenic pattern in humans. Journal of Nutrition. 2004. UI 15226460. Fish
Li Z, Otvos JD, Lamon-Fava S, et al. Men and women differ in lipoprotein response to dietary saturated fat and cholesterol restriction. Journal of Nutrition. 2003. UI 14608054. Diet, low fat
Lindbohm N, Gylling H, Miettinen TE, Miettinen TA. Statin treatment increases the sialic acid content of LDL in hypercholesterolemic patients. Atherosclerosis. 2000. UI 10924733. Statin
Liu ML, Bergholm R, Makimattila S, et al. A marathon run increases the susceptibility of LDL to oxidation in vitro and modifies plasma antioxidants. American Journal of Physiology. 1999. UI 10362621. Endurance training
Lofgren I, Zern T, Herron K, et al. Weight loss associated with reduced intake of carbohydrate reduces the atherogenicity of LDL in premenopausal women. Metabolism: Clinical & Experimental. 2005. UI 16125523. Diets
Lumb PJ, McMahon Z, Chik G, Wierzbicki AS. Effect of moxonidine on lipid subfractions in patients with hypertension. International Journal of Clinical Practice. 2004. UI 15206502. Moxonidine
Lupattelli G, Pasqualini L, Siepi D, et al. Increased postprandial lipemia in patients with normolipemic peripheral arterial disease. American Heart Journal. 2002. UI 11923813. Fat load
Luscombe ND, Noakes M, Clifton PM. Diets high and low in glycemic index versus high monounsaturated fat diets: effects on glucose and lipid metabolism in NIDdiabetes. European Journal of Clinical Nutrition. 1999. UI 10403584. Diet, glycemic index
Maki KC, Van Elswyk ME, McCarthy D, et al. Lipid responses in mildly hypertriglyceridemic men and women to consumption of docosahexaenoic acid-enriched eggs. International Journal for Vitamin & Nutrition Research. 2003. UI 14639800. Omega 3 eggs
Manuel YK, Vinckx M, Vertommen J, et al. Impact of Vitamin E supplementation on lipoprotein peroxidation and composition in Type 1 diabetic patients treated with Atorvastatin. Atherosclerosis. 2004. UI 15262194. Vitamin E, Atorvastatin
Manzato E, Zambon S, Zambon A, et al. Lipoprotein sub-fraction levels and composition in obese subjects before and after gastroplasty. International Journal of Obesity & Related Metabolic Disorders: Journal of the International Association for the Study of Obesity. 1992. UI 1326487. Gastroplasty
Marais AD, Firth JC, Bateman ME, et al. Atorvastatin: an effective lipid-modifying agent in familial hypercholesterolemia. Arteriosclerosis, Thrombosis & Vascular Biology. 1997. UI 9301631. Atorvastatin
Markovic TP, Campbell LV, Balasubramanian S, et al. Beneficial effect on average lipid levels from energy restriction and fat loss in obese individuals with or without type 2 diabetes. Diabetes Care. 1998. UI 9589226. Diet, low calorie
Marz W, Scharnagl H, Abletshauser C, et al. Fluvastatin lowers atherogenic dense low-density lipoproteins in postmenopausal women with the atherogenic lipoprotein phenotype. Circulation. 2001. UI 11306521. Fluvastatin
Matvienko OA, Lewis DS, Swanson M, et al. A single daily dose of soybean phytosterols in ground beef decreases serum total cholesterol and LDL cholesterol in young, mildly hypercholesterolemic men. American Journal of Clinical Nutrition. 2002. UI 12081816. Soy phytosterols
Mauger JF, Lichtenstein AH, Ausman LM, et al. Effect of different forms of dietary hydrogenated fats on LDL particle size. American Journal of Clinical Nutrition. 2003. UI 12936917. Dietary fat
McKenney JM, Davidson MH, Shear CL, Revkin JH. Efficacy and safety of torcetrapib, a novel cholesteryl ester transfer protein inhibitor, in individuals with below-average high-density lipoprotein cholesterol levels on a background of atorvastatin. Journal of the American College of Cardiology. 2006. UI 17084250. Torcetrapib
McKenney JM, McCormick LS, Schaefer EJ, et al. Effect of niacin and atorvastatin on lipoprotein subclasses in patients with atherogenic dyslipidemia. American Journal of Cardiology. 2001. UI 11472706. Atorvastatin, Niacin
Melenovsky V, Malik J, Wichterle D, et al. Comparison of the effects of atorvastatin or fenofibrate on nonlipid biochemical risk factors and the LDL particle size in subjects with combined hyperlipidemia. American Heart Journal. 2002. UI 12360175. Atorvastatin, Fenofibrate
Mooren MJ, Graaf Jd, Demacker PNM, et al. Changes in the low-density lipoprotein profile during 17 beta -estradiol-dydrogesterone therapy in postmenopausal women. Metabolism, Clinical and Experimental. 1994. UI 19951409616. Hormone treatment
Moreno JA, Perez-Jimenez F, Marin C, et al. The effect of dietary fat on LDL size is influenced by apolipoprotein E genotype in healthy subjects. Journal of Nutrition. 2004. UI 15465740. Diets
Morgan JM, Capuzzi diabetes, Baksh RI, et al. Effects of extended-release niacin on lipoprotein subclass distribution. American Journal of Cardiology. 2003. UI 12804729. Niacin
Mori TA, Burke V, Puddey IB, et al. Purified eicosapentaenoic and docosahexaenoic acids have differential effects on serum lipids and lipoproteins, LDL particle size, glucose, and insulin in mildly hyperlipidemic men. American Journal of Clinical Nutrition. 2000. UI 10799369. Omega 3
Nakandakare E, Garcia RC, Rocha JC, et al. Effects of simvastatin, bezafibrate and gemfibrozil on the quantity and composition of plasma lipoproteins. Atherosclerosis. 1990. UI 2102085. Simvastatin, Bezafibrate, Gemfibrozil
Niemeijer-Kanters SD, linga-Thie GM, de Ruijter-Heijstek FC, et al. Effect of intensive lipid-lowering strategy on low-density lipoprotein particle size in patients with type 2 diabetes mellitus. Atherosclerosis. 2001. UI 11369016. Lipid lowering
Nishikawa O, Mune M, Miyano M, et al. Effect of simvastatin on the lipid profile of hemodialysis patients. Kidney International - Supplement. 1999. UI 10412781. Simvastatin
Noda K, Zhang B, Uehara Y, et al. Potent capillary isotachophoresis (cITP) for analyzing a marker of coronary heart disease risk and electronegative low-density lipoprotein (LDL) in small dense LDL fraction. Circulation Journal. 2005. UI 16308511. Fenofibrate
Nordoy A, Hansen JB, Brox J, Svensson B. Effects of atorvastatin and omega-3 fatty acids on LDL subfractions and postprandial hyperlipemia in patients with combined hyperlipemia. Nutrition Metabolism & Cardiovascular Diseases. 2001. UI 11383326. Atorvastatin
O'Keefe JH, Captain BK, Jones PG, Harris WS. Atorvastatin reduces remnant lipoproteins and small, dense low-density lipoproteins regardless of the baseline lipid pattern. Preventive Cardiology. 2004. UI 15539961. Atorvastatin
Olson RE, Patsch W, Epstein M, et al. Effect of egg feeding on serum lipids and lipoproteins in young men. American Journal of Clinical Nutrition. 1980. UI 19801407709. Eggs
O'Neal DN, Hew FL, Best JD, Alford F. The effect of 24 months recombinant human growth hormone (rh-GH) on LDL cholesterol, triglyceride-rich lipoproteins and apo in hypopituitary adults previously treated with conventional replacement therapy. Growth Hormone & Igf Research. 1999. UI 10502452. Growth hormone
O'Neal DN, O'Brien RC, Timmins KL, et al. Gemfibrozil treatment increases low-density lipoprotein particle size in Type 2 diabetes mellitus but does not alter in vitro oxidizability. Diabetic Medicine. 1998. UI 9796889. Gemfibrozil
Onishi Y, Fujisawa T, Sakaguchi K, Maeda M. Effect of nateglinide on the size of LDL particles in patients with type 2 diabetes. Advances in Therapy. 2006. UI 17050498. Nateglinide
Otvos JD, Shalaurova I, Freedman DS, Rosenson RS. Effects of pravastatin treatment on lipoprotein subclass profiles and particle size in the PLAC-I trial. Atherosclerosis. 2002. UI 11755921. Pravastatin
Ovalle F, Bell DS. Lipoprotein effects of different thiazolidinediones in clinical practice. Endocrine Practice. 2002. UI 15251829. Troglitazone, Rosiglitazone
Pan J, Lin M, Kesala RL, et al. Niacin treatment of the atherogenic lipid profile and Lp(a) in diabetes. Diabetes, Obesity & Metabolism. 2002. UI 12099974. Niacin
Pan J, Van JT, Chan E, et al. Extended-release niacin treatment of the atherogenic lipid profile and lipoprotein(a) in diabetes. Metabolism: Clinical & Experimental. 2002. UI 12200755. Niacin
Patti L, Maffettone A, Iovine C, et al. Long-term effects of fish oil on lipoprotein subfractions and low density lipoprotein size in non-insulin-dependent diabetic patients with hypertriglyceridemia. Atherosclerosis. 1999. UI 10532692. Fish oil
Pedersen A, Baumstark MW, Marckmann P, et al. An olive oil-rich diet results in higher concentrations of LDL cholesterol and a higher number of LDL subfraction particles than rapeseed oil and sunflower oil diets. Journal of Lipid Research. 2000. UI 11108723. Oils
Perez A, Khan M, Johnson T, Karunaratne M. Pioglitazone plus a sulphonylurea or metformin is associated with increased lipoprotein particle size in patients with type 2 diabetes. Diabetes & Vascular Disease Research. 2004. UI 16305056. Pioglitazone, Metformin, Sulfphonylurea
Petersen M, Pedersen H, Major-Pedersen A, et al. Effect of fish oil versus corn oil supplementation on LDL and HDL subclasses in type 2 diabetic patients. Diabetes Care. 2002. UI 12351465. Fish oil
Pettee KK, Kriska AM, Johnson BD, et al. The relationship between physical activity and lipoprotein subclasses in postmenopausal women: the influence of hormone therapy. Menopause. 2007. UI 17023874. Hormone treatment
Pieke B, von EA, Gulbahce E, et al. Treatment of hypertriglyceridemia by two diets rich either in unsaturated fatty acids or in carbohydrates: effects on lipoprotein subclasses, lipolytic enzymes, lipid transfer proteins, insulin and leptin. International Journal of Obesity & Related Metabolic Disorders: Journal of the International Association for the Study of Obesity. 2000. UI 11093290. Diet
Pirwany IR, Sattar N, Greer IA, et al. Supraphysiological concentrations of estradiol in menopausal women given repeated implant therapy do not adversely affect lipid profiles. Human Reproduction. 2002. UI 11870144. Estrogen
Pollock CA, Wyndham R, Collett PV, et al. Effects of erythropoietin therapy on the lipid profile in end-stage renal failure. Kidney International. 1994. UI 8196294. Erythropoietin
Pontrelli L, Parris W, Adeli K, Cheung RC. Atorvastatin treatment beneficially alters the lipoprotein profile and increases low-density lipoprotein particle diameter in patients with combined dyslipidemia and impaired fasting glucose/type 2 diabetes. Metabolism: Clinical & Experimental. 2002. UI 11887170. Atorvastatin
Purnell JQ, Kahn SE, Albers JJ, et al. Effect of weight loss with reduction of intra-abdominal fat on lipid metabolism in older men. Journal of Clinical Endocrinology & Metabolism. 2000. UI 10720026. Dietary weight loss
Purnell JQ, Marcovina SM, Hokanson JE, et al. Levels of lipoprotein(a), apolipoprotein B, and lipoprotein cholesterol distribution in IDdiabetes. Results from follow-up in the Diabetes Control and Complications Trial. Diabetes. 1995. UI 7556961. Intensive diabetes treatment
Rajman I, Lip GY, Cramb R, et al. Adverse change in low-density lipoprotein subfractions profile with oestrogen-only hormone replacement therapy. Qjm. 1996. UI 8944233. Hormone treatment
Raslova K, Nagyova A, Dobiasova M, et al. Effect of ciprofibrate on lipoprotien metabolism and oxidative stress parameters in patients with type 2 diabetes mellitus and atherogenic lipoprotein phenotype. Acta Diabetologica. 2000. UI 11277313. Ciprofibrate
Rivellese AA, Maffettone A, Vessby B, et al. Effects of dietary saturated, monounsaturated and n-3 fatty acids on fasting lipoproteins, LDL size and post-prandial lipid metabolism in healthy subjects. Atherosclerosis. 2003. UI 12618280. Dietary fats
Rivellese AA, Patti L, Romano G, et al. Effect of insulin and sulfonylurea therapy, at the same level of blood glucose control, on low density lipoprotein subfractions in type 2 diabetic patients. Journal of Clinical Endocrinology & Metabolism. 2000. UI 11095452. Insulin, sulfonylurea
Rizzo M, Berneis K. The clinical significance of the size of low-density-lipoproteins and the modulation of subclasses by fibrates. Current Medical Research & Opinion. 2007. UI 17519077. Fibrate
Rizzo M, Trepp R, Berneis K, Christ ER. Atherogenic lipoprotein phenotype and low-density lipoprotein size and subclasses in patients with growth hormone deficiency before and after short-term replacement therapy. European Journal of Endocrinology. 2007. UI 17322496. Growth hormone
Romano G, Tilly-Kiesi MK, Patti L, et al. Effects of dietary cholesterol on plasma lipoproteins and their subclasses in IDdiabetes patients. Diabetologia. 1998. UI 9498653. Cholesterol supplementation
Roscini AR, Lupattelli G, Siepi D, et al. Low-density lipoprotein size in primary hypothyroidism. Effects of hormone replacement therapy. Annals of Nutrition & Metabolism. 1999. UI 10725771. Hormone treatment
Rosenson RS. Colesevelam HCl reduces LDL particle number and increases LDL size in hypercholesterolemia. Atherosclerosis. 2006. UI 16009365. Colesevelam
Saiki A, Ohira M, Endo K, et al. The angiotensin II receptor antagonist valsartan enhances lipoprotein lipase mass in preheparin serum in type 2 diabetes with hypertension. Diabetes Research & Clinical Practice. 2006. UI 16713009. Valsartan
Sakabe K, Fukuda N, Wakayama K, et al. Lipid-altering changes and pleiotropic effects of atorvastatin in patients with hypercholesterolemia. American Journal of Cardiology. 2004. UI 15325939. Atorvastatin
Sakabe K, Fukuda N, Wakayama K, et al. Effects of atorvastatin therapy on the low-density lipoprotein subfraction, remnant-like particles cholesterol, and oxidized low-density lipoprotein within 2 weeks in hypercholesterolemic patients. Circulation Journal. 2003. UI 14578621. Atorvastatin
Sanchez-Quesada JL, Perez A, Caixas A, et al. Electronegative low density lipoprotein subform is increased in patients with short-duration IDdiabetes and is closely related to glycaemic control. Diabetologia. 1996. UI 8960828. Intensive diabetes treatment
Sasaki S, Kuwahara N, Kunitomo K, et al. Effects of atorvastatin on oxidized low-density lipoprotein, low-density lipoprotein subfraction distribution, and remnant lipoprotein in patients with mixed hyperlipoproteinemia. American Journal of Cardiology. 2002. UI 11835916. Atorvastatin
Schaefer EJ, Lichtenstein AH, Lamon-Fava S, et al. Effects of National Cholesterol Education Program Step 2 diets relatively high or relatively low in fish-derived fatty acids on plasma lipoproteins in middle-aged and elderly subjects. American Journal of Clinical Nutrition. 1996. UI 8561065. Step 2 Diet, Fish
Schaefer EJ, McNamara JR, Tayler T, et al. Effects of atorvastatin on fasting and postprandial lipoprotein subclasses in coronary heart disease patients versus control subjects. American Journal of Cardiology. 2002. UI 12356379. Atorvastatin
Schamberger BM, Geiss HC, Ritter MM, et al. Influence of LDL apheresis on LDL subtypes in patients with coronary heart disease and severe hyperlipoproteinemia. Journal of Lipid Research. 2000. UI 10787433. LDL apheresis
Scharnagl H, Winkler K, Mantz S, et al. Inhibition of HMG-CoA reductase with cerivastatin lowers dense low density lipoproteins in patients with elevated fasting glucose, impaired glucose tolerance and type 2 diabetes mellitus. Experimental & Clinical Endocrinology & Diabetes. 2004. UI 15146374. Cerivastatin
Seip RL, Otvos J, Bilbie C, et al. The effect of apolipoprotein E genotype on serum lipoprotein particle response to exercise. Atherosclerosis. 2006. UI 16842800. Exercise
Seshadri P, Iqbal N, Stern L, et al. A randomized study comparing the effects of a low-carbohydrate diet and a conventional diet on lipoprotein subfractions and C-reactive protein levels in patients with severe obesity. American Journal of Medicine. 2004. UI 15380496. Diet, low carb
Shadid S, LaForge R, Otvos JD, Jensen MD. Treatment of obesity with diet/exercise versus pioglitazone has distinct effects on lipoprotein particle size. Atherosclerosis. 2006. UI 16313908. Pioglitazone, Diet & Exercise
Sharman MJ, Gomez AL, Kraemer WJ, Volek JS. Very low-carbohydrate and low-fat diets affect fasting lipids and postprandial lipemia differently in overweight men. Journal of Nutrition. 2004. UI 15051841. Diet, low carb
Sharman MJ, Kraemer WJ, Love diabetes, et al. A ketogenic diet favorably affects serum biomarkers for cardiovascular disease in normal-weight men. Journal of Nutrition. 2002. UI 12097663. Diet, ketogenic
Shimada K, Kawarabayashi T, Tanaka A, et al. Oolong tea increases plasma adiponectin levels and low-density lipoprotein particle size in patients with coronary artery disease. Diabetes Research & Clinical Practice. 2004. UI 15331202. Oolong tea
Shirai K, Itoh Y, Sasaki H, et al. The effect of insulin sensitizer, troglitazone, on lipoprotein lipase mass in preheparin serum. Diabetes Research & Clinical Practice. 1999. UI 10580614. Troglitazone
Shrestha S, Freake HC, McGrane MM, et al. A combination of psyllium and plant sterols alters lipoprotein metabolism in hypercholesterolemic subjects by modifying the intravascular processing of lipoproteins and increasing LDL uptake. Journal of Nutrition. 2007. UI 17449576. Psyllium, Sterols
Shrestha S, Volek JS, Udani J, et al. A combination therapy including psyllium and plant sterols lowers LDL cholesterol by modifying lipoprotein metabolism in hypercholesterolemic individuals. Journal of Nutrition. 2006. UI 16988115. Psyllium, Sterols
Sirtori CR, Calabresi L, Pisciotta L, et al. Effect of statins on LDL particle size in patients with familial combined hyperlipidemia: a comparison between atorvastatin and pravastatin. Nutrition Metabolism & Cardiovascular Diseases. 2005. UI 15871851. Atorvastatin, Pravastatin
Sjogren P, Rosell M, Skoglund-Andersson C, et al. Milk-derived fatty acids are associated with a more favorable LDL particle size distribution in healthy men. Journal of Nutrition. 2004. UI 15226461. Dietary fats
Soedamah-Muthu SS, Colhoun HM, Thomason MJ, et al. The effect of atorvastatin on serum lipids, lipoproteins and NMR spectroscopy defined lipoprotein subclasses in type 2 diabetic patients with ischaemic heart disease. Atherosclerosis. 2003. UI 12818407. Atorvastatin
Sone H, Takahashi A, Shimano H, et al. HMG-CoA reductase inhibitor decreases small dense low-density lipoprotein and remnant-like particle cholesterol in patients with type-2 diabetes. Life Sciences. 2002. UI 12231401. Pitavastatin
Stalenhoef AF, de GJ, Wittekoek ME, et al. The effect of concentrated n-3 fatty acids versus gemfibrozil on plasma lipoproteins, low density lipoprotein heterogeneity and oxidizability in patients with hypertriglyceridemia. Atherosclerosis. 2000. UI 11058707. Gemfibrozil, Omega 3
St-Onge MP, Lamarche B, Mauger JF, Jones PJ. Consumption of a functional oil rich in phytosterols and medium-chain triglyceride oil improves plasma lipid profiles in men. Journal of Nutrition. 2003. UI 12771322. "Good" oils
Superko HR, Berneis KK, Williams PT, et al. Gemfibrozil reduces small low-density lipoprotein more in normolipemic subjects classified as low-density lipoprotein pattern B compared with pattern A. American Journal of Cardiology. 2005. UI 16253595. Gemfibrozil
Superko HR, Krauss RM. Garlic powder, effect on plasma lipids, postprandial lipemia, low-density lipoprotein particle size, high-density lipoprotein subclass distribution and lipoprotein(a). Journal of the American College of Cardiology. 2000. UI 10676676. Garlic
Superko HR, Krauss RM. Differential effects of nicotinic acid in subjects with different LDL subclass patterns. Atherosclerosis. 1992. UI 1642694. Nicotinic acid
Superko HR, Krauss RM, DiRicco C. Effect of fluvastatin on low-density lipoprotein peak particle diameter. American Journal of Cardiology. 1997. UI 9205026. Fluvastatin
Superko HR, McGovern ME, Raul E, Garrett B. Differential effect of two nicotinic acid preparations on low-density lipoprotein subclass distribution in patients classified as low-density lipoprotein pattern A, B, or I. American Journal of Cardiology. 2004. UI 15342288. Nicotinic acid
Suzukawa M, Abbey M, Howe PR, Nestel PJ. Effects of fish oil fatty acids on low density lipoprotein size, oxidizability, and uptake by macrophages. Journal of Lipid Research. 1995. UI 7775859. Fish oil
Tack CJ, Smits P, Demacker PN, Stalenhoef AF. Troglitazone decreases the proportion of small, dense LDL and increases the resistance of LDL to oxidation in obese subjects. Diabetes Care. 1998. UI 9589243. Troglitazone
Tamasawa N, Matsui J, Ogawa Y, et al. Effect of doxazosin on the size of LDL particle in the type 2 diabetic patients with hypertension. Journal of Diabetes & its Complications. 2000. UI 10989321. Doxazosin
Tan CE, Chew LS, Tai ES, et al. Benefits of micronised Fenofibrate in type 2 diabetes mellitus subjects with good glycemic control. Atherosclerosis. 2001. UI 11166781. Fenofibrate
Tan KC, Pang RW, Tiu SC, Lam KS. Effects of treatment with Sandostatin LAR on small dense LDL and remnant-like lipoproteins in patients with acromegaly. Clinical Endocrinology. 2003. UI 14616878. Sandostatin
Tan KC, Shiu SW, Kung AW. Alterations in hepatic lipase and lipoprotein subfractions with transdermal testosterone replacement therapy. Clinical Endocrinology. 1999. UI 10619982. Testosterone
Theodoraki TG, Tsoukatos DC, Karabina SA, et al. LDL subfractions in patients with myocardial infarction: effect of smoking and beta-blocker treatment. Annals of Clinical Biochemistry. 2000. UI 10817244. Tobacco, Betablocker
Thomas TR, Smith BK, Donahue OM, et al. Effects of omega-3 fatty acid supplementation and exercise on low-density lipoprotein and high-density lipoprotein subfractions. Metabolism: Clinical & Experimental. 2004. UI 15164323. Omega 3, Exercise
Tilly-Kiesi M, Lappi M, Puolakka J, et al. Different effects of continuous oestrogen-progestin and transdermal oestrogen with cyclic progestin regimens on low-density lipoprotein subclasses. European Journal of Clinical Investigation. 1996. UI 9013088. Hormone treatment
Tricon S, Burdge GC, Jones EL, et al. Effects of dairy products naturally enriched with cis-9,trans-11 conjugated linoleic acid on the blood lipid profile in healthy middle-aged men. American Journal of Clinical Nutrition. 2006. UI 16600923. Conjugated linoleic acid
Tsai MY, Yuan J, Hunninghake DB. Effect of gemfibrozil on composition of lipoproteins and distribution of LDL subspecies. Atherosclerosis. 1992. UI 1642690. Gemfibrozil
Tsai MY, Yuan J, Hunninghake DB. Effect of gemfibrozil on composition of lipoproteins and distribution of LDL subspecies. Atherosclerosis. 1992. UI 1642690. Gemfibrozil
Tsimihodimos V. Comparison of the effects of atorvastatin and fenofibrate on apolipoprotein B-containing lipoprotein subfractions in patients with combined dyslipidemia. Hellenic Journal of Cardiology. 2004. UI 516496. Atorvastatin, Fenofibrate
Tsimihodimos V, Karabina SA, Tambaki A, et al. Effect of atorvastatin on the concentration, relative distribution, and chemical composition of lipoprotein subfractions in patients with dyslipidemias of type IIA and IIB. Journal of Cardiovascular Pharmacology. 2003. UI 12883336. Atorvastatin
Tu L, Liu X, Li R, et al. The lipid-regulating effects of atorvastatin on type 2 elder diabetes patients with hyperlipidemia. Journal of Huazhong University of Science and Technology. 2004. UI 15315163. Atorvastatin
Vadlamudi S, MacLean P, Israel RG, et al. Effects of oral combined hormone replacement therapy on plasma lipids and lipoproteins. Metabolism: Clinical & Experimental. 1998. UI 9781625. Hormone treatment
Vakkilainen J, Mero N, Schweizer A, et al. Effects of nateglinide and glibenclamide on postprandial lipid and glucose metabolism in type 2 diabetes. Diabetes/Metabolism Research Reviews. 2002. UI 12469362. Nateglinide, Glibenclamide
Vakkilainen J, Steiner G, Ansquer JC, et al. Relationships between low-density lipoprotein particle size, plasma lipoproteins, and progression of coronary artery disease: the Diabetes Atherosclerosis Intervention Study (DAIS). Circulation. 2003. UI 12665498. Fenofibrate
van den Akker JM, Bredie SJ, Diepenveen SH, et al. Atorvastatin and simvastatin in patients on hemodialysis: effects on lipoproteins, C-reactive protein and in vivo oxidized LDL. Journal of Nephrology. 2003. UI 12768071. Atrovastatin, Simvastatin
Wagner AM, Jorba O, Rigla M, et al. Effect of improving glycemic control on low-density lipoprotein particle size in type 2 diabetes. Metabolism: Clinical & Experimental. 2003. UI 14669158. Glycemic control
Wakatsuki A, Ikenoue N, Izumiya C, et al. Effect of estrogen and simvastatin on low-density lipoprotein subclasses in hypercholesterolemic postmenopausal women. Obstetrics & Gynecology. 1998. UI 9721772. Estrogen, Simvastatin
Wakatsuki A, Ikenoue N, Okatani Y, Fukaya T. Estrogen-induced small low density lipoprotein particles may be atherogenic in postmenopausal women. Journal of the American College of Cardiology. 2001. UI 11216957. Estrogen
Wakatsuki A, Ikenoue N, Sagara Y. Estrogen-induced small low-density lipoprotein particles in postmenopausal women. Obstetrics & Gynecology. 1998. UI 9469282. Estrogen
Wakatsuki A, Ikenoue N, Sagara Y. Effect of estrogen on the size of low-density lipoprotein particles in postmenopausal women. Obstetrics & Gynecology. 1997. UI 9207806. Estrogen
Wakatsuki A, Ikenoue N, Shinohara K, et al. Small low-density lipoprotein particles and endothelium-dependent vasodilation in postmenopausal women. Atherosclerosis. 2004. UI 15530907. Estrogen
Wakatsuki A, Ogawa Y, Saibara T, et al. Size and oxidative susceptibility of low-density lipoprotein particles in breast cancer patients with tamoxifen-induced fatty liver. Journal of Clinical Endocrinology & Metabolism. 2002. UI 12161495. Tamoxifen
Wakatsuki A, Okatani Y, Ikenoue N. Effects of combination therapy with estrogen plus simvastatin on lipoprotein metabolism in postmenopausal women with type IIa hypercholesterolemia. Atherosclerosis. 2000. UI 10781640. Estrogen, Simvastatin
Wakatsuki A, Okatani Y, Ikenoue N, Fukaya T. Different effects of oral conjugated equine estrogen and transdermal estrogen replacement therapy on size and oxidative susceptibility of low-density lipoprotein particles in postmenopausal women. Circulation. 2002. UI 12356628. Estrogen
Wakatsuki A, Okatani Y, Ikenoue N, et al. Effect of lower dose of oral conjugated equine estrogen on size and oxidative susceptibility of low-density lipoprotein particles in postmenopausal women. Circulation. 2003. UI 12900341. Estrogen, low dose
Wallace AJ, Humphries SE, Fisher RM, et al. Genetic factors associated with response of LDL subfractions to change in the nature of dietary fat. Atherosclerosis. 2000. UI 10729389. Dietary fat
Wiemer J, Winkler K, Baumstark M, et al. Influence of low molecular weight heparin compared to conventional heparin for anticoagulation during haemodialysis on low density lipoprotein subclasses. Nephrology Dialysis Transplantation. 2002. UI 12454238. Low molecular weight heparin, Heparin
Williams PT, Blanche PJ, Rawlings R, Krauss RM. Concordant lipoprotein and weight responses to dietary fat change in identical twins with divergent exercise levels 1. American Journal of Clinical Nutrition. 2005. UI 16002817. Dietary fat
Williams PT, Krauss RM. Associations of age, adiposity, menopause, and alcohol intake with low-density lipoprotein subclasses. Arteriosclerosis, Thrombosis & Vascular Biology. 1997. UI 9194758. Alcohol
Williams PT, Krauss RM, Vranizan KM, et al. Effects of exercise-induced weight loss on low density lipoprotein subfractions in healthy men. Arteriosclerosis. 1989. UI 2783076. Exercise
Williams PT, Krauss RM, Vranizan KM, Wood PD. Changes in lipoprotein subfractions during diet-induced and exercise-induced weight loss in moderately overweight men. Circulation. 1990. UI 2317911. Calorie, restriction, Exercise
Williams PT, Krauss RM, Wood PD, et al. Lipoprotein subfractions of runners and sedentary men. Metabolism: Clinical & Experimental. 1986. UI 3941608. Endurance training
Winkler K, Abletshauser C, Friedrich I, et al. Fluvastatin slow-release lowers platelet-activating factor acetyl hydrolase activity: a placebo-controlled trial in patients with type 2 diabetes. Journal of Clinical Endocrinology & Metabolism. 2004. UI 15001601. Fluvastatin
Winkler K, Abletshauser C, Hoffmann MM, et al. Effect of fluvastatin slow-release on low density lipoprotein (LDL) subfractions in patients with type 2 diabetes mellitus: baseline LDL profile determines specific mode of action. Journal of Clinical Endocrinology & Metabolism. 2002. UI 12466341. Fluvastatin
Winkler K, Konrad T, Fullert S, et al. Pioglitazone reduces atherogenic dense LDL particles in nondiabetic patients with arterial hypertension: a double-blind, placebo-controlled study. Diabetes Care. 2003. UI 12941723. Pioglitazone
Wolever TMS, Tsihlias EB, McBurney MI, Le NA. Long-term effect of reduced carbohydrate or increased fiber intake on LDL particle size and HDL composition in subjects with type 2 diabetes. Nutrition Research. 2003. UI 20033029325. Fiber, Monounsaturated fatty acids
Yamamoto K, Takeshita M, Tokimitsu I, et al. Diacylglycerol oil ingestion in type 2 diabetic patients with hypertriglyceridemia. Nutrition. 2006. UI 16289977. Diacylglycerol oil
Yang CY, Gu ZW, Xie YH, et al. Effects of gemfibrozil on very-low-density lipoprotein composition and low-density lipoprotein size in patients with hypertriglyceridemia or combined hyperlipidemia. Atherosclerosis. 1996. UI 8879439. Gemfibrozil
Yoshino G, Hirano T, Kazumi T, et al. Fluvastatin increases LDL particle size and reduces oxidative stress in patients with hyperlipidemia. Journal of Atherosclerosis & Thrombosis. 2003. UI 15037823. Fluvastatin
Yu D, Murdoch SJ, Parikh SJ, et al. Rosiglitazone increases LDL particle size and buoyancy and decreases C-reactive protein in patients with type 2 diabetes on statin therapy. Diabetes & Vascular Disease Research. 2006. UI 17160915. Rosiglitazone
Yu HH, Ginsburg GS, O'Toole ML, et al. Acute changes in serum lipids and lipoprotein subclasses in triathletes as assessed by proton nuclear magnetic resonance spectroscopy. Arteriosclerosis, Thrombosis & Vascular Biology. 1999. UI 10446075. Endurance training
Yuan J, Tsai MY, Hunninghake DB. Changes in composition and distribution of LDL subspecies in hypertriglyceridemic and hypercholesterolemic patients during gemfibrozil therapy. Atherosclerosis. 1994. UI 7857363. Gemfibrazole
Yuan JN, Tsai MY, Hegland J, Hunninghake DB. Effects of fluvastatin (XU 62320), an HMG-CoA reductase inhibitor, on the distribution and composition of low density lipoprotein subspecies in humans. Atherosclerosis. 1991. UI 1854361. Fluvastatin
Zambon A, Deeb SS, Brown BG, et al. Common hepatic lipase gene promoter variant determines clinical response to intensive lipid-lowering treatment. Circulation. 2001. UI 11171785. Lipid lowering
Zambon A, Hokanson JE, Brown BG, Brunzell JD. Evidence for a new pathophysiological mechanism for coronary artery disease regression: hepatic lipase-mediated changes in LDL density. Circulation. 1999. UI 10208998. Lovastatin, Niacin
Zambon S, Cortella A, Sartore G, et al. Pravastatin treatment in combined hyperlipidaemia. Effect on plasma lipoprotein levels and size. European Journal of Clinical Pharmacology. 1994. UI 8070502. Pravastatin
Zhang B, Katafuchi R, Arishima H, et al. Effects of atorvastatin and apoA-I/phosphatidylcholine discs on triglyceride-rich lipoprotein subfractions as characterized by capillary isotachophoresis. Clinica Chimica Acta. 2006. UI 16806136. Atorvastatin
Zhao SP, Hollaar L, Van 't Hooft FM, et al. Effect of simvastatin on the apparent size of LDL particles in patients with type IIB hyperlipoproteinemia. Clinica Chimica Acta. 1991. UI 1777975. Simvastatin
Ziogas GG, Thomas TR, Harris WS. Exercise training, postprandial hypertriglyceridemia, and LDL subfraction distribution. Medicine & Science in Sports & Exercise. 1997. UI 9268954. Exercise