# Rejected Articles

Adler L, Hill JS, Frohlich J. Chemical precipitation of apolipoprotein B-containing lipoproteins facilitates determination of LDL particle size. Clinical Biochemistry. 2000. UI 10913516. comparison of different techniques of the same method
Akanji AO, Suresh CG, Fatania HR, et al. Associations of apolipoprotein E polymorphism with low-density lipoprotein size and subfraction profiles in Arab patients with coronary heart disease. Metabolism: Clinical & Experimental. 2007. UI 17379005. LDL immediately after CAD event
Alabakovska SB, Todorova BB, Labudovic DD, Tosheska KN. Gradient gel electrophoretic separation of LDL and HDL subclasses on BioRad Mini Protean II and size phenotyping in healthy Macedonians. Clinica Chimica Acta. 2002. UI 11814466. No relevant info
Ala-Korpela M, Lankinen N, Salminen A, et al. The inherent accuracy of 1H NMR spectroscopy to quantify plasma lipoproteins is subclass dependent. Atherosclerosis. 2007. UI 16730730. Not comparison of 2 methods
Alvarez JJ, Lasuncion MA, Olmos JM, Herrera E. Interindividual variation in the partition of lipoprotein(a) into lipoprotein subfractions. Clinical Biochemistry. 1993. UI 8299210. Not LDL subfractions
Austin MA, Hokanson JE, Edwards KL. Hypertriglyceridemia as a cardiovascular risk factor. American Journal of Cardiology. 1998. UI 9526807. No relevant info
Ballantyne FC, Clark RS, Simpson HS, Ballantyne D. High density and low density lipoprotein subfractions in survivors of myocardial infarction and in control subjects. Metabolism: Clinical & Experimental. 1982. UI 6952064. No relevant info
Bathen TF, Engan T, Krane J. Principal component analysis of proton nuclear magnetic resonance spectra of lipoprotein fractions from patients with coronary heart disease and healthy subjects. Scandinavian Journal of Clinical & Laboratory Investigation. 1999. UI 10533847. LDL immediately after CAD event
Baumstark MW, Kreutz W, Berg A, et al. Structure of human low-density lipoprotein subfractions, determined by X-ray small-angle scattering. Biochimica et Biophysica Acta. 1990. UI 2294970. No relevant info
Berneis K, Jeanneret C, Muser J, et al. Low-density lipoprotein size and subclasses are markers of clinically apparent and non-apparent atherosclerosis in type 2 diabetes. Metabolism: Clinical & Experimental. 2005. UI 15690318. N<10 per arm
Berneis K, La BM, Blanche PJ, Krauss RM. Analysis and quantitation of biotinylated apoB-containing lipoproteins with streptavidin-Cy3. Journal of Lipid Research. 2002. UI 12091501. Not LDL subfractions
Bickerstaffe R, Desmond FB. Lipoprotein classification by analytical ultracentrifugation. Pathology. 1982. UI 7099724. No relevant info
Bittolo-Bon G, Cazzolato G. Analytical capillary isotachophoresis of total plasma lipoproteins: a new tool to identify atherogenic low density lipoproteins. Journal of Lipid Research. 1999. UI 9869664. No relevant info
Bokemark L, Wikstrand J, Attvall S, et al. Insulin resistance and intima-media thickness in the carotid and femoral arteries of clinically healthy 58-year-old men. The Atherosclerosis and Insulin Resistance Study (AIR). Journal of Internal Medicine. 2001. UI 11168785. Same dataset as other study
Bozoky Z, Fulop L, Kohidai L. A short-run new analytical ultracentrifugal micromethod for determining low-density lipoprotein subfractions using Schlieren refractometry. European Biophysics Journal. 2001. UI 11288837. Not LDL subfractions
Braun LT, Rosenson RS. Asessing coronary heart disease risk and managing lipids. Nurse Practitioner. 2001. UI 11809040. No relevant info
Brook RD, Bard RL, Rubenfire M, et al. Usefulness of visceral obesity (waist/hip ratio) in predicting vascular endothelial function in healthy overweight adults. American Journal of Cardiology. 2001. UI 11728354. No clinical CVD outcome
Brook RD, Kansal M, Bard RL, et al. Usefulness of low-density lipoprotein particle size measurement in cardiovascular disease prevention. Clinical Cardiology. 2005. UI 16450798. No clinical CVD outcome
Busbee DL, Payne DM, Jasheway DW, et al. Separation and detection of lipoproteins in human serum by use of size-exclusion liquid chromatography: a preliminary report. Clinical Chemistry. 1981. UI 6171365. Not LDL subfractions
Camejo G, Rosengren B, Olsson U, Bondjers G. Agarose isoelectric focusing of plasma low and very low density lipoproteins using the PhastSystem. Analytical Biochemistry. 1989. UI 2604050. No relevant info
Campbell DJ, Neal BC, Chalmers JP, et al. Low-density lipoprotein particles and risk of intracerebral haemorrhage in subjects with cerebrovascular disease. European Journal of Cardiovascular Prevention & Rehabilitation. 2007. UI 17568241. LDL immediately after CAD event
Cazzolato G, Avogaro P, Bittolo-Bon G. Characterization of a more electronegatively charged LDL subfraction by ion exchange HPLC. Free Radical Biology & Medicine. 1991. UI 1937142. No relevant info
Ceriotti L, Shibata T, Folmer B, et al. Low-density lipoprotein analysis in microchip capillary electrophoresis systems. Electrophoresis. 2002. UI 12412132. Not LDL subfractions
Felmeden DC, Spencer CG, Blann AD, et al. Low-density lipoprotein subfractions and cardiovascular risk in hypertension: relationship to endothelial dysfunction and effects of treatment. Hypertension. 2003. UI 12623954. No clinical CVD outcome
Fonda M, Semolic AM, Soranzo MR, Cattin L. Production of polyacrylamide gradient gel for lipoprotein electrophoretic separation. Clinica Chimica Acta. 2003. UI 14637269. No relevant info
Foucar E. Diagnostic certainty is sometimes certainly an error. American Journal of Clinical Pathology. 2003. UI 12645348. Letter
Garvey WT, Kwon S, Zheng D, et al. Effects of insulin resistance and type 2 diabetes on lipoprotein subclass particle size and concentration determined by nuclear magnetic resonance. Diabetes. 2003. UI 12540621. No relevant info
Griffin BA, Caslake MJ, Yip B, et al. Rapid isolation of low density lipoprotein (LDL) subfractions from plasma by density gradient ultracentrifugation. Atherosclerosis. 1990. UI 2390137. N<10 per arm
Gylling H, Miettinen TA. Cholesterol absorption and lipoprotein metabolism in type II diabetes mellitus with and without coronary artery disease. Atherosclerosis. 1996. UI 8902158. N<10 per arm
Hirano T, Ito Y, Saegusa H, Yoshino G. A novel and simple method for quantification of small, dense LDL. Journal of Lipid Research. 2003. UI 12897184. sdLDL fraction only
Hulthe J, Wiklund O, Olsson G, et al. Computerized measurement of LDL particle size in human serum. Reproducibility studies and evaluation of LDL particle size in relation to metabolic variables and the occurrence of atherosclerosis. Scandinavian Journal of Clinical & Laboratory Investigation. 1999. UI 10691057. No relevant info
Inano K, Tezuka S, Miida T, Okada M. Capillary isotachophoretic analysis of serum lipoproteins using a carrier ampholyte as spacer ion. Annals of Clinical Biochemistry. 2000. UI 11026526. No relevant info
Jaakkola O, Solakivi T, Tertov VV, et al. Characteristics of low-density lipoprotein subfractions from patients with coronary artery disease. Coronary Artery Disease. 1993. UI 8261211. No relevant info
Jungner I, Sniderman AD, Furberg C, et al. Does low-density lipoprotein size add to atherogenic particle number in predicting the risk of fatal myocardial infarction?. American Journal of Cardiology. 2006. UI 16563891. Not LDL subfractions
Kahlon TS, Adamson GL, Glines LA, et al. Partial specific volume and preferential hydration of low density lipoprotein subfractions. Lipids. 1986. UI 3702615. No relevant info
Kahlon TS, Adamson GL, Shen MM, Lindgren FT. Sedimentation equilibrium of human low density lipoprotein subfractions. Lipids. 1982. UI 7098773. No relevant info
Krauss RM, Burke DJ. Identification of multiple subclasses of plasma low density lipoproteins in normal humans. Journal of Lipid Research. 1982. UI 7057116. No relevant info
Kulkarni KR. Cholesterol profile measurement by vertical auto profile method. Clinics in Laboratory Medicine. 2006. UI 17110240. Technical description of specific measure
laKorpela M, Hiltunen Y, Bell JD. Quantification of biomedical NMR data using artificial neural network analysis: lipoprotein lipid profiles from 1H NMR data of human plasma. NMR in Biomedicine. 1995. UI 8732179. No relevant info
laKorpela M, Korhonen A, Keisala J, et al. 1H NMR-based absolute quantitation of human lipoproteins and their lipid contents directly from plasma. Journal of Lipid Research. 1994. UI 7897326. No relevant info
laKorpela M, Pentikainen MO, Korhonen A, et al. Detection of low density lipoprotein particle fusion by proton nuclear magnetic resonance spectroscopy. Journal of Lipid Research. 1998. UI 9717732. No relevant info
Lamarche B, St-Pierre AC, Ruel IL, et al. A prospective, population-based study of low density lipoprotein particle size as a risk factor for ischemic heart disease in men. Canadian Journal of Cardiology. 2001. UI 11521128. Same dataset as other study
Lamarche B, Tchernof A, Mauriege P, et al. Fasting insulin and apolipoprotein B levels and low-density lipoprotein particle size as risk factors for ischemic heart disease. JAMA. 1998. UI 9643858. Same dataset as other study
Lamarche B, Tchernof A, Moorjani S, et al. Small, dense low-density lipoprotein particles as a predictor of the risk of ischemic heart disease in men. Prospective results from the Quebec Cardiovascular Study. Circulation. 1997. UI 8994419. Same dataset as other study
Le GD, Nouvelot A, Chermant JL. Determination of size and molecular weight distributions of lipoproteins using automatic image analysis and density gradient ultracentrifugation. Journal of Biochemical & Biophysical Methods. 1990. UI 2345267. No relevant info
Lee DM, Alaupovic P. Apolipoproteins B, C-III and E in two major subpopulations of low-density lipoproteins. Biochimica et Biophysica Acta. 1986. UI 3768392. No relevant info
Lee DM, Alaupovic P. Physiocochemical properties of low-density lipoproteins of normal human plasma. Evidence for the occurrence of lipoprotein B in associated and free forms. Biochemical Journal. 1974. UI 4363108. No relevant info
Lee LT, Lefevre M, Wong L, et al. Gradient acrylamide/agarose gels for electrophoretic separation of intact human very low density lipoproteins, intermediate density lipoproteins, lipoprotein a, and low density lipoproteins. Analytical Biochemistry. 1987. UI 2440347. No relevant info
Lee LT, Lefevre M, Wong L, et al. Gradient acrylamide/agarose gels for electrophoretic separation of intact human very low density lipoproteins, intermediate density lipoproteins, lipoprotein a, and low density lipoproteins. Analytical Biochemistry. 1987. UI 2440347. Not LDL subfractions
Leonsson M, Hulthe J, Oscarsson J, et al. Intimamedia thickness in cardiovascularly asymptomatic hypopituitary adults with growth hormone deficiency: relation to body mass index, gender, and other cardiovascular risk factors. Clinical Endocrinology. 2002. UI 12460325. Very atypical population
Liu ML, Ylitalo K, Salonen R, et al. Circulating oxidized low-density lipoprotein and its association with carotid intima-media thickness in asymptomatic members of familial combined hyperlipidemia families. Arteriosclerosis, Thrombosis & Vascular Biology. 2004. UI 15205217. Same dataset as other study
Liu MY, McNeal CJ, Macfarlane RD. Charge density profiling of circulating human low-density lipoprotein particles by capillary zone electrophoresis. Electrophoresis. 2004. UI 15349939. Not LDL subfractions
Luc G, De Gennes JL, Chapman MJ. Further resolution and comparison of the heterogeneity of plasma low-density lipoproteins in human hyperlipoproteinemias: type III hyperlipoproteinemia, hypertriglyceridemia and familial hypercholesterolemia. Atherosclerosis. 1988. UI 3401287. No relevant info
Lupattelli G, Lombardini R, Schillaci G, et al. Flow-mediated vasoactivity and circulating adhesion molecules in hypertriglyceridemia: association with small, dense LDL cholesterol particles. American Heart Journal. 2000. UI 10966556. No clinical CVD outcome
Lyons TJ, Jenkins AJ, Zheng D, et al. Nuclear magnetic resonance-determined lipoprotein subclass profile in the DCCT/EDIC cohort: associations with carotid intima-media thickness. Diabetic Medicine. 2006. UI 16922701. Subfraction as "predictor" of 4 yo CVD outcomes
Mackey RH, Kuller LH, Sutton-Tyrrell K, et al. Hormone therapy, lipoprotein subclasses, and coronary calcification: the Healthy Women Study. Archives of Internal Medicine. 2005. UI 15767525. Same dataset as other study
Makimattila S, Liu ML, Vakkilainen J, et al. Impaired endothelium-dependent vasodilation in type 2 diabetes. Relation to LDL size, oxidized LDL, and antioxidants. Diabetes Care. 1999. UI 10372251. No clinical CVD outcome
McNamara JR, Jenner JL, Li Z, et al. Change in LDL particle size is associated with change in plasma triglyceride concentration. Arteriosclerosis & Thrombosis. 1992. UI 1420088. Not day-to-day comparison, No clinical CVD outcome
Melish JS, Waterhouse C. Concentration gradient electrophoresis of plasma from patients with hyperbetalipoproteinemia. Journal of Lipid Research. 1972. UI 4335796. No relevant info
Menys VC, Liu Y, Mackness MI, et al. Isolation of plasma small-dense low-density lipoprotein using a simple air-driven ultracentrifuge and quantification using immunoassay of apolipoprotein B. Clinical Chemistry & Laboratory Medicine. 2004. UI 15061377. sdLDL fraction only
Menys VC, Liu Y, Mackness MI, et al. Measurement of plasma small-dense LDL concentration by a simplified ultracentrifugation procedure and immunoassay of apolipoprotein B. Clinica Chimica Acta. 2003. UI 12867279. sdLDL fraction only
Nosadini R, Manzato E, Solini A, et al. Peripheral, rather than hepatic, insulin resistance and atherogenic lipoprotein phenotype predict cardiovascular complications in NIDDM. European Journal of Clinical Investigation. 1994. UI 8050454. No relevant info
Ohmori R, Momiyama Y, Tanaka N, et al. LDL fractions assessed by anion-exchange high-performance liquid chromatography in patients with coronary artery disease. Atherosclerosis. 2006. UI 16620833. No relevant info
Okabe M. The high occurrence of low density lipoprotein subfractions in coronary heart disease. Japanese Circulation Journal. 1979. UI 232192. LDL subfraction analysis not comparable to modern methods
Okada M, Matsui H, Ito Y, et al. Low-density lipoprotein cholesterol can be chemically measured: a new superior method. Journal of Laboratory & Clinical Medicine. 1998. UI 9735925. No relevant info
Okazaki M, Usui S, Ishigami M, et al. Identification of unique lipoprotein subclasses for visceral obesity by component analysis of cholesterol profile in high-performance liquid chromatography. Arteriosclerosis, Thrombosis & Vascular Biology. 2005. UI 15637308. No relevant info
Olsson AG, Eklund B. Studies in asymptomatic primary hyperlipidaemia. V. Peripheral circulation. Acta Medica Scandinavica. 1975. UI 170797. No clinical CVD outcome
Opplt JJ, Chick LL, Opplt MA. Correlative design of electrophoretic and ultracentrifugal investigation of metabolic effects of probucol. Artery. 1982. UI 7092580. Not LDL subfractions
Opplt JJ, Holzberg ES. Ultracentrifugal subclasses of low and intermediate density lipoproteins. Journal of Lipid Research. 1994. UI 8014586. No relevant info
O'Sullivan JJ, Matthew A, Conroy RM, et al. Relation of angiographically defined coronary artery disease to serum lipoprotein levels. Clinical Cardiology. 1990. UI 2282727. Not LDL subfractions
Otvos JD, Jeyarajah EJ, Bennett DW, Krauss RM. Development of a proton nuclear magnetic resonance spectroscopic method for determining plasma lipoprotein concentrations and subspecies distributions from a single, rapid measurement. Clinical Chemistry. 1992. UI 1326420. No relevant info
Packard CJ. LDL subfractions and atherogenicity: an hypothesis from the University of Glasgow. Current Medical Research & Opinion. 1996. UI 8862937. Not original data
Park I, Paeng KJ, Yoon Y, et al. Separation and selective detection of lipoprotein particles of patients with coronary artery disease by frit-inlet asymmetrical flow field-flow fractionation. Journal of Chromatography B: Analytical Technologies in the Biomedical & Life Sciences. 2002. UI 12401369. No relevant info
Pauciullo P, Carlson LA, Eklund B, et al. Concentration and chemical composition of plasma lipoprotein subfractions in patients with peripheral vascular disease. Evidence for normal apolipoprotein B but low cholesteryl ester content in small VLDL. Atherosclerosis. 1985. UI 4091876. No relevant info
Petersen M, Dyrby M, Toubro S, et al. Quantification of lipoprotein subclasses by proton nuclear magnetic resonance-based partial least-squares regression models. Clinical Chemistry. 2005. UI 15961551. No relevant info
Rainwater DL, Moore PH, Shelledy WR, et al. Characterization of a composite gradient gel for the electrophoretic separation of lipoproteins. Journal of Lipid Research. 1997. UI 9215553. No relevant info
Rainwater DL. Electrophoretic separation of LDL and HDL subclasses. Methods in Molecular Biology. 1998. UI 9918045. No relevant info
Rizzo M, Rini GB, Berneis K. The clinical relevance of LDL size and subclasses modulation in patients with type-2 diabetes. Experimental & Clinical Endocrinology & Diabetes. 2007. UI 17853329. No relevant info
Rubenstein B, Steiner G. Fractionation of human low density lipoprotein by column chromatography. Canadian Journal of Biochemistry. 1976. UI 189881. No relevant info
Ruotolo G, Tettamanti C, Garancini MP, et al. Smaller, denser LDL particles are not a risk factor for cardiovascular disease in healthy nonagenarian women of the Cremona Population Study. Atherosclerosis. 1998. UI 9733216. No clinical CVD outcome
Sawle A, Higgins MK, Olivant MP, Higgins JA. A rapid single-step centrifugation method for determination of HDL, LDL, and VLDL cholesterol, and TG, and identification of predominant LDL subclass. Journal of Lipid Research. 2002. UI 11861676. No relevant info
Scheffer PG, Bakker SJ, Heine RJ, Teerlink T. Measurement of LDL particle size in whole plasma and serum by high performance gel-filtration chromatography using a fluorescent lipid probe. Clinical Chemistry. 1998. UI 9761248. comparison of different techniques of the same method
Schlenck A, Herbeth B, Siest G, Visvikis S. Characterization and quantification of serum lipoprotein subfractions by capillary isotachophoresis: relationships with lipid, apolipoprotein, and lipoprotein levels. Journal of Lipid Research. 1999. UI 10553016. No relevant info
Shahrul BS, Faridah AR. Simplified gradient gel electrophoresis for quantification of low-density lipoprotein subclass. Clinica Chimica Acta. 2003. UI 14500048. No relevant info
Slyper AH, Zvereva S, Schectman G, et al. Low-density lipoprotein particle size is not a discriminating marker for atherogenic risk in male offspring of parents with early coronary artery disease. Metabolism: Clinical & Experimental. 1997. UI 9258281. No clinical CVD outcome
St-Pierre AC, Ruel IL, Cantin B, et al. Comparison of various electrophoretic characteristics of LDL particles and their relationship to the risk of ischemic heart disease. Circulation. 2001. UI 11696468. Same dataset as other study
Swinkels DW, Hak-Lemmers HL, Demacker PN. Single spin density gradient ultracentrifugation method for the detection and isolation of light and heavy low density lipoprotein subfractions. Journal of Lipid Research. 1987. UI 3681148. No relevant info
Terpstra AH, Woodward CJ, Sanchez-Muniz FJ. Improved techniques for the separation of serum lipoproteins by density gradient ultracentrifugation: visualization by prestaining and rapid separation of serum lipoproteins from small volumes of serum. Analytical Biochemistry. 1981. UI 6165257. Not LDL subfractions
Tornvall P, Karpe F, Carlson LA, Hamsten A. Relationships of low density lipoprotein subfractions to angiographically defined coronary artery disease in young survivors of myocardial infarction. Atherosclerosis. 1991. UI 1799399. No relevant info
Tsukamoto H, Takei I, Ishii K, Watanabe K. Simplified method for the diameter sizing of serum low-density lipoprotein using polyacrylamide gradient gel electrophoresis. Clinical Chemistry & Laboratory Medicine. 2004. UI 15497465. No relevant info
Usui S, Nakamura M, Jitsukata K, et al. Assessment of between-instrument variations in a HPLC method for serum lipoproteins and its traceability to reference methods for total cholesterol and HDL-cholesterol. Clinical Chemistry. 2000. UI 10620573. Not day-to-day comparison, Not repeated measures
Vakkilainen J, Makimattila S, Seppala-Lindroos A, et al. Endothelial dysfunction in men with small LDL particles. Circulation. 2000. UI 10942737. No clinical CVD outcome
Warnick GR, McNamara JR, Boggess CN, et al. Polyacrylamide gradient gel electrophoresis of lipoprotein subclasses. Clinics in Laboratory Medicine. 2006. UI 17110241. No relevant info
Westhuyzen J, Graham SD, Rasiah RL, Saltissi D. Simplified sizing of low-density lipoprotein using polyacrylamide gradient gel electrophoresis of plasma. European Journal of Clinical Chemistry & Clinical Biochemistry. 1997. UI 9156560. No relevant info
Williams PT, Krauss RM, Nichols AV, et al. Identifying the predominant peak diameter of high-density and low-density lipoproteins by electrophoresis. Journal of Lipid Research. 1990. UI 2373962. Not comparison of 2 methods
Williams PT, Vranizan KM, Krauss RM. Correlations of plasma lipoproteins with LDL subfractions by particle size in men and women. Journal of Lipid Research. 1992. UI 1619368. No relevant info
Yohannes G, Sneck M, Varjo SJ, et al. Miniaturization of asymmetrical flow field-flow fractionation and application to studies on lipoprotein aggregation and fusion. Analytical Biochemistry. 2006. UI 16750506. No relevant info
Zhang B, Kaneshi T, Ohta T, Saku K. Relation between insulin resistance and fast-migrating LDL subfraction as characterized by capillary isotachophoresis. Journal of Lipid Research. 2005. UI 16061945. No relevant info
Zhang B, Maeda N, Okada K, et al. Association between fast-migrating low-density lipoprotein subfraction as characterized by capillary isotachophoresis and intima-media thickness of carotid artery. Atherosclerosis. 2006. UI 16236285. Not LDL subfractions
Zorn U, Haug C, Celik E, et al. Characterization of modified low density lipoprotein subfractions by capillary isotachophoresis. Electrophoresis. 2001. UI 11358140. Not LDL subfractions
Zorn U, Wolf CF, Wennauer R, et al. Separation of lipoproteins by capillary isotachophoresis combined with enzymatic derivatization of cholesterol and triglycerides. Electrophoresis. 1999. UI 10424488. No relevant info