# Search Strategy

LDL Lipoprotein Subfractions | Aug 22, 2007
Ovid MEDLINE(R) (mesz), CAB Abs (caba), CCTR, CDSR (coch)

# | Search History | Results
1 | (ldl or ldl-c).mp. or exp Cholesterol, LDL/ or exp Lipoproteins, LDL/ | 65262
2 | ldl cholesterol.mp. | 18455
3 | or/1-2 | 65262
4 | particle size.mp. or exp Particle Size/ | 43827
5 | (subfraction$ or subclass$).mp. | 27004
6 | particle density.mp. | 982
7 | exp Nuclear Magnetic Resonance, Biomolecular/ or exp Magnetic Resonance Spectroscopy/ | 132032
8 | (nuclear magnetic resonance or nmr or magnetic resonance spectroscopy).mp. | 145366
9 | exp Chromatography, High Pressure Liquid/ or exp Chromatography/ | 484708
10 | (chromatography or hplc or fplc).mp. | 570172
11 | ultracentrifugation.mp. or exp Ultracentrifugation/ | 62272
12 | centrifugation.mp. or exp Centrifugation/ | 95595
13 | exp Electrophoresis/ or electrophoresis.mp. | 428986
14 | or/4-13 | 1183751
15 | 3 and 14 | 9676
16 | limit 15 to (humans and english language) [Limit not valid in: CAB Abs,CCTR,CDSR; records were retained] | 7591
17 | remove duplicates from 16 | 6369
| Ovid MEDLINE(R) <1950 to June Week 4 2007> | (5997)
| CAB Abstracts <1973 to May 2007> | (321)
| EBM Reviews - Cochrane Central Register of Controlled Trials <3rd Quarter 2007> | (47)
| EBM Reviews - Cochrane Database of Systematic Reviews <3rd Quarter 2007> | (4)