# References and Included Studies

1 World Health Organization. Preventing Chronic Disease: A Vital Investment: WHO Global Report. Geneva, Switzerland. WHO Press, World Health Organization. 2005.
2 Zatonski WA, Willett W. Changes in dietary fat and declining coronary heart disease in Poland: population based study. BMJ. 2005;331(7510):187-8. [pmid: 16037448].
3 Zatonski WA, McMichael AJ, Powles JW. Ecological study of reasons for sharp decline in mortality from ischaemic heart disease in Poland since 1991. BMJ. 1998;316(7137):1047-51. [pmid: 9552904].
4 Robertson TL, Kato H, Rhoads GG, et al. Epidemiologic studies of coronary heart disease and stroke in Japanese men living in Japan, Hawaii and California. Incidence of myocardial infarction and death from coronary heart disease. Am J Cardiol. 1977;39(2):239-43. [pmid: 835482].
5 Mente A, de Koning L, Shannon HS, et al. A systematic review of the evidence supporting a causal link between dietary factors and coronary heart disease. Arch Intern Med. 2009;169(7):659-69. [pmid: 19364995].
6 American Diabetes Association. Diabetes Statistics American Diabetes Association. 2010. Available from: URL: http://www.diabetes.org/diabetes-basics/diabetes-statistics/.
7 Lloyd-Jones D, Adams R, Carnethon M, et al. Heart disease and stroke statistics--2009 update: a report from the American Heart Association Statistics Committee and Stroke Statistics Subcommittee. Circulation. 2009;119(3):480-6. [pmid: 19171871].
8 Centers for Disease Control and Prevention. National diabetes fact sheet, 2007. Centers for Disease Control and Prevention. 2007.
9 Ford ES, Giles WH, Mokdad AH. Increasing prevalence of the metabolic syndrome among U.S. adults. Diabetes Care. 2004;27(10):2444-9. [pmid: 15451914].
10 American Diabetes Association. Prediabetes. http://www.diabetes org/diabetes-basics/prevention/pre-diabetes/. 2011.
11 Charfen MA, Ipp E, Kaji AH, et al. Detection of undiagnosed diabetes and prediabetic states in high-risk emergency department patients. Acad Emerg Med. 2009;16(5):394-402. [pmid: 19302369].
12 Ervin R. Prevalence of metabolic syndrome among adults 20 years of age and over, by sex, age, race and ethnicity, and body mass index: United States, 2003–2006. National Health Statistics Report. 2009:13.
13 Alexander CM, Landsman PB, Grundy SM. The influence of age and body mass index on the metabolic syndrome and its components. Diabetes Obes Metab. 2008;10(3):246-50. [pmid: 18269640].
14 Park YW, Zhu S, Palaniappan L, et al. The metabolic syndrome: prevalence and associated risk factor findings in the US population from the Third National Health and Nutrition Examination Survey, 1988–1994. Arch Intern Med. 2003;163(4):427-36. [pmid: 12588201].
15 National Cancer Institute. Breast Cancer. National Cancer Institute. 2010. Available from: URL: http://www.cancer.gov/cancertopics/types/breast.
16 Ahn J, Schatzkin A, Lacey JV Jr, et al. Adiposity, adult weight change, and postmenopausal breast cancer risk. Arch Intern Med. 2007;167(19):2091-102. [pmid: 17954804].
17 Renehan AG, Tyson M, Egger M, et al. Body-mass index and incidence of cancer: a systematic review and meta-analysis of prospective observational studies. Lancet. 2008;371(9612):569-78. [pmid: 18280327].
18 Cleary MP, Grossmann ME. Minireview: Obesity and breast cancer: the estrogen connection. Endocrinology. 2009;150(6):2537-42. [pmid: 19372199].
19 Lee IM. Physical activity and cancer prevention--data from epidemiologic studies. Med Sci Sports Exerc. 2003;35(11):1823-7. [pmid: 14600545].
20 Monninkhof EM, Elias SG, Vlems FA, et al. Physical activity and breast cancer: a systematic review. Epidemiology. 2007;18(1):137-57. [pmid: 17130685].
21 American Cancer Society. Cancer Facts and Figures 2010. 2010.
22 Key TJ, Allen N, Appleby P, et al. Fruits and vegetables and prostate cancer: no association among 1,104 cases in a prospective study of 130,544 men in the European Prospective Investigation into Cancer and Nutrition (EPIC). Int J Cancer. 2004;109(1):119-24. [pmid: 14735477].
23 Shike M, Latkany L, Riedel E, et al. Lack of effect of a low-fat, high-fruit, -vegetable, and -fiber diet on serum prostate-specific antigen of men without prostate cancer: results from a randomized trial. J Clin Oncol. 2002;20(17):3592-8. [pmid: 12202659].
24 Kolonel LN, Hankin JH, Whittemore AS, et al. Vegetables, fruits, legumes and prostate cancer: a multiethnic case-control study. Cancer Epidemiol Biomarkers Prev. 2000;9(8):795-804. [pmid: 10952096].
25 MacInnis RJ, English DR. Body size and composition and prostate cancer risk: systematic review and meta-regression analysis. Cancer Causes Control. 2006;17(8):989-1003. [pmid: 16933050].
26 Oliveria SA, Lee IM. Is exercise beneficial in the prevention of prostate cancer?. Sports Med. 1997;23(5):271-8. [pmid: 9181665].
27 Torti DC, Matheson GO. Exercise and prostate cancer. Sports Med. 2004;34(6):363-9. [pmid: 15157121].
28 Kung HC, Hoyert DL, Xu JQ, Murphy SL. Deaths: final data for 2005. Hyattsville, MD. National Center for Health Statistics. 2008. Report No.: 56.
29 Knoops KT, de Groot LC, Kromhout D, et al. Mediterranean diet, lifestyle factors, and 10-year mortality in elderly European men and women: the HALE project. JAMA. 2004;292(12):1433-9. [pmid: 15383513].
30 de Groot LC, Verheijden MW, de Henauw S, et al. Lifestyle, nutritional status, health, and mortality in elderly people across Europe: a review of the longitudinal results of the SENECA study. J Gerontol A Biol Sci Med Sci. 2004;59(12):1277-84. [pmid: 15699526].
31 Centers for Disease Control and Prevention. Prevalence of self-reported physically active adults: United States, 2007. Washington, DC. U.S. Government Printing Office (GPO). 2008. Report No.: 57.
32 National Center for Chronic Disease Prevention and Health Promotion. BRFSS prevalence and trends data 2007. National Center for Health Statistics. 2007. Available from: URL: http://apps.nccd.cdc.gov/brfss/page.asp?cat=AC&yr=2007&state=US#AC.
33 Joshipura KJ, Hu FB, Manson JE, et al. The effect of fruit and vegetable intake on risk for coronary heart disease. Ann Intern Med. 2001;134(12):1106-14. [pmid: 11412050].
34 Joshipura KJ, Ascherio A, Manson JE, et al. Fruit and vegetable intake in relation to risk of ischemic stroke. JAMA. 1999;282(13):1233-9. [pmid: 10517425].
35 Ogden CL, Carroll MD, McDowell MA, Flegal KM. Obesity among adults in the United States--no statistically significant change since 2003–2004. Hyattsville, MD. Centers for Disease Control and Prevention. 2007. Report No.: 1.
36 Calle EE, Thun MJ, Petrelli JM, et al. Body-mass index and mortality in a prospective cohort of U.S. adults. N Engl J Med. 1999;341(15):1097-105. [pmid: 10511607].
37 Adams KF, Schatzkin A, Harris TB, et al. Overweight, obesity, and mortality in a large prospective cohort of persons 50 to 71 years old. N Engl J Med. 2006;355(8):763-78. [pmid: 16926275].
38 Kumar V, Abbas A. Robbins & Contran Pathologic Basis of Disease. 7th ed. Philadelphia. Elsevier Saunders. 2005.
39 Mokdad AH, Bowman BA, Ford ES, et al. The continuing epidemics of obesity and diabetes in the United States. JAMA. 2001;286(10):1195-200. [pmid: 11559264].
40 King H, Aubert RE, Herman WH. Global burden of diabetes, 1995–2025: prevalence, numerical estimates, and projections. Diabetes Care. 1998;21(9):1414-31. [pmid: 9727886].
41 Intensive blood-glucose control with sulphonylureas or insulin compared with conventional treatment and risk of complications in patients with type 2 diabetes (UKPDS 33). UK Prospective Diabetes Study (UKPDS) Group. Lancet. 1998;352(9131):837-53. [pmid: 9742976].
42 Gerstein HC, Miller ME, Byington RP, et al. Effects of intensive glucose lowering in type 2 diabetes. N Engl J Med. 2008;358(24):2545-59. [pmid: 18539917].
43 Duckworth W, Abraira C, Moritz T, et al. Glucose control and vascular complications in veterans with type 2 diabetes. N Engl J Med. 2009;360(2):129-39. [pmid: 19092145].
44 Patel A, MacMahon S, Chalmers J, et al. Intensive blood glucose control and vascular outcomes in patients with type 2 diabetes. N Engl J Med. 2008;358(24):2560-72. [pmid: 18539916].
45 Holman RR, Paul SK, Bethel MA, et al. 10-year follow-up of intensive glucose control in type 2 diabetes. N Engl J Med. 2008;359(15):1577-89. [pmid: 18784090].
46 Tight blood pressure control and risk of macrovascular and microvascular complications in type 2 diabetes: UKPDS 38. UK Prospective Diabetes Study Group. BMJ. 1998;317(7160):703-13. [pmid: 9732337].
47 Chan JM, Rimm EB, Colditz GA, et al. Obesity, fat distribution, and weight gain as risk factors for clinical diabetes in men. Diabetes Care. 1994;17(9):961-9. [pmid: 7988316].
48 Hanson RL, Narayan KM, McCance DR, et al. Rate of weight gain, weight fluctuation, and incidence of NIDDM. Diabetes. 1995;44(3):261-6. [pmid: 7883111].
49 Resnick HE, Valsania P, Halter JB, et al. Relation of weight gain and weight loss on subsequent diabetes risk in overweight adults. J Epidemiol Community Health. 2000;54(8):596-602. [pmid: 10890871].
50 Holbrook TL, Barrett-Connor E, Wingard DL. The association of lifetime weight and weight control patterns with diabetes among men and women in an adult community. Int J Obes. 1989;13(5):723-9. [pmid: 2583926].
51 Ford ES, Williamson DF, Liu S. Weight change and diabetes incidence: findings from a national cohort of US adults. Am J Epidemiol. 1997;146(3):214-22. [pmid: 9247005].
52 Colditz GA, Willett WC, Rotnitzky A, et al. Weight gain as a risk factor for clinical diabetes mellitus in women. Ann Intern Med. 1995;122(7):481-6. [pmid: 7872581].
53 Fox CS, Pencina MJ, Wilson PW, et al. Lifetime risk of cardiovascular disease among individuals with and without diabetes stratified by obesity status in the Framingham heart study. Diabetes Care. 2008;31(8):1582-4. [pmid: 18458146].
54 Eeg-Olofsson K, Cederholm J, Nilsson PM, et al. Risk of cardiovascular disease and mortality in overweight and obese patients with type 2 diabetes: an observational study in 13,087 patients. Diabetologia. 2009;52(1):65-73. [pmid: 18985314].
55 Anderson JW, Kendall CW, Jenkins DJ. Importance of weight management in type 2 diabetes: review with meta-analysis of clinical studies. J Am Coll Nutr. 2003;22(5):331-9. [pmid: 14559925].
56 Williamson DF, Thompson TJ, Thun M, et al. Intentional weight loss and mortality among overweight individuals with diabetes. Diabetes Care. 2000;23(10):1499-504. [pmid: 11023143].
57 Lean ME, Powrie JK, Anderson AS, et al. Obesity, weight loss and prognosis in type 2 diabetes. Diabet Med. 1990;7(3):228-33. [pmid: 2139394].
58 Collins R, Armitage J, Parish S, et al. MRC/BHF Heart Protection Study of cholesterol-lowering with simvastatin in 5963 people with diabetes: a randomised placebo-controlled trial. Lancet. 2003;361(9374):2005-16. [pmid: 12814710].
59 Colhoun HM, Betteridge DJ, Durrington PN, et al. Primary prevention of cardiovascular disease with atorvastatin in type 2 diabetes in the Collaborative Atorvastatin Diabetes Study (CARDS): multicentre randomised placebo-controlled trial. Lancet. 2004;364(9435):685-96. [pmid: 15325833].
60 Shenoy S, Guglani R, Sandhu JS. Effectiveness of an aerobic walking program using heart rate monitor and pedometer on the parameters of diabetes control in Asian Indians with type 2 diabetes. Prim Care Diabetes. 2010;4(1):41-5. [pmid: 19945929].
61 Boule NG, Haddad E, Kenny GP, et al. Effects of exercise on glycemic control and body mass in type 2 diabetes mellitus: a meta-analysis of controlled clinical trials. Scand J Med Sci Sports. 2002;12(1):60-1.
62 Schneider SH, Khachadurian AK, Amorosa LF, et al. Ten-year experience with an exercise-based outpatient life-style modification program in the treatment of diabetes mellitus. Diabetes Care. 1992;15(11):1800-10. [pmid: 1468318].
63 Wei M, Gibbons LW, Kampert JB, et al. Low cardiorespiratory fitness and physical inactivity as predictors of mortality in men with type 2 diabetes. Ann Intern Med. 2000;132(8):605-11. [pmid: 10766678].
64 Hu FB, Stampfer MJ, Solomon C, et al. Physical activity and risk for cardiovascular events in diabetic women. Ann Intern Med. 2001;134(2):96-105. [pmid: 11177312].
65 Alberti KG, Zimmet PZ. Definition, diagnosis and classification of diabetes mellitus and its complications. Part 1: diagnosis and classification of diabetes mellitus provisional report of a WHO consultation. Diabet Med. 1998;15(7):539-53. [pmid: 9686693].
66 Third Report of the National Cholesterol Education Program (NCEP) Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel III) final report. Circulation. 2002;106(25):3143-421. [pmid: 12485966].
67 Grundy SM, Cleeman JI, Daniels SR, et al. Diagnosis and management of the metabolic syndrome: an American Heart Association/National Heart, Lung, and Blood Institute Scientific Statement. Circulation. 2005;112(17):2735-52. [pmid: 16157765].
68 Sattar N, McConnachie A, Shaper AG, et al. Can metabolic syndrome usefully predict cardiovascular disease and diabetes? Outcome data from two prospective studies. Lancet. 2008;371(9628):1927-35. [pmid: 18501419].
69 Resnick HE, Jones K, Ruotolo G, et al. Insulin resistance, the metabolic syndrome, and risk of incident cardiovascular disease in nondiabetic American Indians: the Strong Heart Study. Diabetes Care. 2003;26(3):861-7. [pmid: 12610050].
70 Cameron AJ, Magliano DJ, Zimmet PZ, et al. The metabolic syndrome as a tool for predicting future diabetes: the Aus Diab study. J Intern Med. 2008;264(2):177-86. [pmid: 18298479].
71 Wilson PW, D’Agostino RB, Parise H, et al. Metabolic syndrome as a precursor of cardiovascular disease and type 2 diabetes mellitus. Circulation. 2005;112(20):3066-72. [pmid: 16275870].
72 Gerstein HC, Santaguida P, Raina P, et al. Annual incidence and relative risk of diabetes in people with various categories of dysglycemia: a systematic overview and meta-analysis of prospective studies. Diabetes Res Clin Pract. 2007;78(3):305-12. [pmid: 17601626].
73 Ford ES, Zhao G, Li C. Pre-diabetes and the risk for cardiovascular disease: a systematic review of the evidence. J Am Coll Cardiol. 2010;55(13):1310-7. [pmid: 20338491].
74 Flegal KM, Carroll MD, Ogden CL, et al. Prevalence and trends in obesity among US adults, 1999–2000. JAMA. 2002;288(14):1723-7. [pmid: 12365955].
75 Hsueh WA, Orloski L, Wyne K. Prediabetes: the importance of early identification and intervention. Postgrad Med. 2010;122(4):129-43. [pmid: 20675976].
76 Grundy SM, Cleeman JI, Daniels SR, et al. Diagnosis and management of the metabolic syndrome: an American Heart Association/National Heart, Lung, and Blood Institute Scientific Statement. Circulation. 2005;112(17):2735-52. [pmid: 16157765].
77 Case CC, Jones PH, Nelson K, et al. Impact of weight loss on the metabolic syndrome. Diabetes Obes Metab. 2002;4(6):407-14. [pmid: 12406040].
78 Gazzaruso C, Giordanetti S, La MA, et al. Weight loss after Swedish Adjustable Gastric Banding: relationships to insulin resistance and metabolic syndrome. Obes Surg. 2002;12(6):841-5. [pmid: 12568192].
79 Morimoto LM, White E, Chen Z, et al. Obesity, body size, and risk of postmenopausal breast cancer: the Women’s Health Initiative (United States). Cancer Causes Control. 2002;13(8):741-51. [pmid: 12420953].
80 Ryu SY, Kim CB, Nam CM, et al. Is body mass index the prognostic factor in breast cancer?: a meta-analysis. J Korean Med Sci. 2001;16(5):610-4. [pmid: 11641531].
81 Protani M, Coory M, Martin JH. Effect of obesity on survival of women with breast cancer: systematic review and meta-analysis. Breast Cancer Res Treat. 2010;123(3):627-35. [pmid: 20571870].
82 Irwin ML, Smith AW, McTiernan A, et al. Influence of pre- and postdiagnosis physical activity on mortality in breast cancer survivors: the health, eating, activity, and lifestyle study. J Clin Oncol. 2008;26(24):3958-64. [pmid: 18711185].
83 Holick CN, Newcomb PA, Trentham-Dietz A, et al. Physical activity and survival after diagnosis of invasive breast cancer. Cancer Epidemiol Biomarkers Prev. 2008;17(2):379-86. [pmid: 18250341].
84 Ibrahim EM, Al-Homaidh A. Physical activity and survival after breast cancer diagnosis: meta-analysis of published studies. Med Oncol. 2010. Epub ahead of print.
85 McNeely ML, Campbell KL, Rowe BH, et al. Effects of exercise on breast cancer patients and survivors: a systematic review and meta-analysis. CMAJ. 2006;175(1):34-41. [pmid: 16818906].
86 Rock CL, demark-Wahnefried W. Nutrition and survival after the diagnosis of breast cancer: a review of the evidence. J Clin Oncol. 2002;20(15):3302-16. [pmid: 12149305].
87 Chlebowski RT, Blackburn GL, Thomson CA, et al. Dietary fat reduction and breast cancer outcome: interim efficacy results from the Women’s Intervention Nutrition Study. J Natl Cancer Inst. 2006;98(24):1767-76. [pmid: 17179478].
88 Pierce JP, Natarajan L, Caan BJ, et al. Influence of a diet very high in vegetables, fruit, and fiber and low in fat on prognosis following treatment for breast cancer: the Women’s Healthy Eating and Living (WHEL) randomized trial. JAMA. 2007;298(3):289-98. [pmid: 17635889].
89 Norman SA, Potashnik SL, Galantino ML, et al. Modifiable risk factors for breast cancer recurrence: what can we tell survivors?. J Womens Health (Larchmt ). 2007;16(2):177-90. [pmid: 17388734].
90 Rose DP, Connolly JM. Dietary fat, fatty acids and prostate cancer. Lipids. 1992;27(10):798-803. [pmid: 1435098].
91 Armstrong B, Doll R. Environmental factors and cancer incidence and mortality in different countries, with special reference to dietary practices. Int J Cancer. 1975;15(4):617-31. [pmid: 1140864].
92 Rodriguez C, Patel AV, Calle EE, et al. Body mass index, height, and prostate cancer mortality in two large cohorts of adult men in the United States. Cancer Epidemiol Biomarkers Prev. 2001;10(4):345-53. [pmid: 11319175].
93 Snowdon DA, Phillips RL, Choi W. Diet, obesity, and risk of fatal prostate cancer. Am J Epidemiol. 1984;120(2):244-50. [pmid: 6465122].
94 Gong Z, Neuhouser ML, Goodman PJ, et al. Obesity, diabetes, and risk of prostate cancer: results from the prostate cancer prevention trial. Cancer Epidemiol Biomarkers Prev. 2006;15(10):1977-83. [pmid: 17035408].
95 Giovannucci E, Liu Y, Platz EA, et al. Risk factors for prostate cancer incidence and progression in the health professionals follow-up study. Int J Cancer. 2007;121(7):1571-8. [pmid: 17450530].
96 Freedland SJ, Aronson WJ, Kane CJ, et al. Impact of obesity on biochemical control after radical prostatectomy for clinically localized prostate cancer: a report by the Shared Equal Access Regional Cancer Hospital database study group. J Clin Oncol. 2004;22(3):446-53. [pmid: 14691122].
97 Strom SS, Kamat AM, Gruschkus SK, et al. Influence of obesity on biochemical and clinical failure after external-beam radiotherapy for localized prostate cancer. Cancer. 2006;107(3):631-9. [pmid: 16802288].
98 Jayachandran J, Banez LL, Aronson WJ, et al. Obesity as a predictor of adverse outcome across black and white race: results from the Shared Equal Access Regional Cancer Hospital (SEARCH) Database. Cancer. 2009;115(22):5263-71. [pmid: 19670453].
99 Strom SS, Wang X, Pettaway CA, et al. Obesity, weight gain, and risk of biochemical failure among prostate cancer patients following prostatectomy. Clin Cancer Res. 2005;11(19 Pt 1):6889-94. [pmid: 16203779].
100 Amling CL, Riffenburgh RH, Sun L, et al. Pathologic variables and recurrence rates as related to obesity and race in men with prostate cancer undergoing radical prostatectomy. J Clin Oncol. 2004;22(3):439-45. [pmid: 14691120].
101 Rodriguez C, Freedland SJ, Deka A, et al. Body mass index, weight change, and risk of prostate cancer in the Cancer Prevention Study II Nutrition Cohort. Cancer Epidemiol Biomarkers Prev. 2007;16(1):63-9. [pmid: 17179486].
102 Moore SC, Peters TM, Ahn J, et al. Physical activity in relation to total, advanced, and fatal prostate cancer. Cancer Epidemiol Biomarkers Prev. 2008;17(9):2458-66. [pmid: 18725512].
103 Orsini N, Bellocco R, Bottai M, et al. A prospective study of lifetime physical activity and prostate cancer incidence and mortality. Br J Cancer. 2009;101(11):1932-8. [pmid: 19861965].
104 Giovannucci EL, Liu Y, Leitzmann MF, et al. A prospective study of physical activity and incident and fatal prostate cancer. Arch Intern Med. 2005;165(9):1005-10. [pmid: 15883238].
105 Thorsen L, Courneya KS, Stevinson C, et al. A systematic review of physical activity in prostate cancer survivors: outcomes, prevalence, and determinants. Support Care Cancer. 2008;16(9):987-97. [pmid: 18274783].
106 Roberts SG, Blute ML, Bergstralh EJ, et al. PSA doubling time as a predictor of clinical progression after biochemical failure following radical prostatectomy for prostate cancer. Mayo Clin Proc. 2001;76(6):576-81. [pmid: 11393495].
107 Doyle C, Kushi LH, Byers T, et al. Nutrition and physical activity during and after cancer treatment: an American Cancer Society guide for informed choices. CA Cancer J Clin. 2006;56(6):323-53. [pmid: 17135691].
108 Higgins JPT, Altman DG. Chapter 8: Assessing risk of bias in included studies. Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions. Chichester, UK. John Wiley & Sons. 2008:187-241.
109 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. 2010;63(5):513-23. [pmid: 19595577].
110 Christian JG, Bessesen DH, Byers TE, et al. Clinic-based support to help overweight patients with type 2 diabetes increase physical activity and lose weight. Arch Intern Med. 2008;168(2):141-6. [pmid: 18227359].
111 Keyserling TC, Samuel-Hodge CD, Ammerman AS, et al. A randomized trial of an intervention to improve self-care behaviors of African-American women with type 2 diabetes: impact on physical activity. Diabetes Care. 2002;25(9):1576-83. [pmid: 12196430].
112 Look AHEAD Research Group. Reduction in weight and cardiovascular disease risk factors in individuals with type 2 diabetes: one-year results of the look AHEAD trial. Diabetes Care. 2007;30(6):1374-83. [pmid: 17363746].
113 Menard J, Payette H, Baillargeon J-P, et al. Efficacy of intensive multitherapy for patients with type 2 diabetes mellitus: a randomized controlled trial. Can Med Assoc J. 2005;173(12):1457-63. [pmid: 16293781].
114 Mayer-Davis EJ, D’Antonio AM, Smith SM, et al. Pounds off with empowerment (POWER): a clinical trial of weight management strategies for black and white adults with diabetes who live in medically underserved rural communities. Am J Public Health. 2004;94(10):1736-42. [pmid: 15451743].
115 Toobert DJ, Glasgow RE, Strycker LA, et al. Biologic and quality-of-life outcomes from the Mediterranean Lifestyle Program: a randomized clinical trial. Diabetes Care. 2003;26(8):2288-93. [pmid: 12882850].
116 Aubert RE, Herman WH, Waters J, et al. Nurse case management to improve glycemic control in diabetic patients in a health maintenance organization. a randomized, controlled trial. Ann Intern Med. 1998;129(8):605-12. [pmid: 9786807].
117 Vanninen E, Uusitupa M, Siitonen O, et al. Habitual physical activity, aerobic capacity and metaboic control in patients with newly-diagnosed Type 2 (non-insulin-dependent) diabetes mellitus: effect of 1-year diet and exercise intervention. Diabetologia. 1992;35(4):340-6. [pmid: 1516762].
118 Samuel-Hodge CD, Keyserling TC, Park S, et al. A randomized trial of a church-based diabetes self-management program for African Americans with type 2 diabetes. Diabetes Educ. 2009;35(3):439-54. [pmid: 19383882].
119 Gaede P, Vedel P, Parving HH, et al. Intensified multifactorial intervention in patients with type 2 diabetes mellitus and microalbuminuria: the Steno type 2 randomised study. Lancet. 1999;353(9153):617-22. [pmid: 10030326].
120 Pinkston MM, Poston WS, Reeves RS, et al. Does metabolic syndrome mitigate weight loss in overweight Mexican American women treated for 1-year with orlistat and lifestyle modification?. Eat Weight Disord. 2006;11(1):e35-e41. [pmid: 16801738].
121 Mensink M, Feskens EJ, Saris WH, et al. Study on Lifestyle Intervention and Impaired Glucose Tolerance Maastricht (SLIM): preliminary results after one year. Int J Obes Relat Metab Disord. 2003;27(3):377-84. [pmid: 12629566].
122 Knowler WC, Barrett-Connor E, Fowler SE, et al. Reduction in the incidence of type 2 diabetes with lifestyle intervention or metformin. N Engl J Med. 2002;346(6):393-403. [pmid: 11832527].
123 Eriksson J, Lindstrom J, Valle T, et al. Prevention of Type II diabetes in subjects with impaired glucose tolerance: the Diabetes Prevention Study (DPS) in Finland. Study design and 1-year interim report on the feasibility of the lifestyle intervention programme. Diabetologia. 1999;42(7):793-801. [pmid: 10440120].
124 Oldroyd JC, Unwin NC, White M, et al. Randomised controlled trial evaluating the effectiveness of behavioural interventions to modify cardiovascular risk factors in men and women with impaired glucose tolerance: outcomes at 6 months. Diabetes Res Clin Pract. 2001;52(1):29-43. [pmid: 11182214].
125 Bo S, Ciccone G, Baldi C, et al. Effectiveness of a lifestyle intervention on metabolic syndrome. a randomized controlled trial. J Gen Intern Med. 2007;22(12):1695-703. [pmid: 17922167].
126 Pan XR, Li GW, Hu YH, et al. Effects of diet and exercise in preventing NIDDM in people with impaired glucose tolerance: The Da Qing IGT and diabetes study. Diabetes Care. 1997;20(4):537-44. [pmid: 9096977].
127 Morey MC, Snyder DC, Sloane R, et al. Effects of home-based diet and exercise on functional outcomes among older, overweight long-term cancer survivors: RENEW: a randomized controlled trial. JAMA. 2009;301(18):1883-91. [pmid: 19436015].
128 Ornish D, Weidner G, Fair WR, et al. Intensive lifestyle changes may affect the progression of prostate cancer. J Urol. 2005;174(3):1065-9. [pmid: 16094059].
129 demark-Wahnefried W, Clipp EC, Morey MC, et al. Lifestyle intervention development study to improve physical function in older adults with cancer: outcomes from Project LEAD. J Clin Oncol. 2006;24(21):3465-73. [pmid: 16849763].
130 Gaede P, Beck M, Vedel P, et al. Limited impact of lifestyle education in patients with Type 2 diabetes mellitus and microalbuminuria: results from a randomized intervention study. Diabet Med. 2001;18(2):104-8. [pmid: 11251672].
131 Gaede P, Lund-Andersen H, Parving HH, et al. Effect of a multifactorial intervention on mortality in type 2 diabetes. N Engl J Med. 2008;358(6):580-91. [pmid: 18256393].
132 Gaede P, Vedel P, Larsen N, et al. Multifactorial intervention and cardiovascular disease in patients with type 2 diabetes. N Engl J Med. 2003;348(5):383-93. [pmid: 12556541].
133 Keyserling TC, Ammerman AS, Samuel-Hodge CD, et al. A diabetes management program for African American women with type 2 diabetes. Diabetes Educ. 2000;26(5):797-805.
134 Bray GA. Baseline characteristics of the randomised cohort from the Look AHEAD (Action for Health in Diabetes) study. Diab Vasc Dis Res. 2006;3(3):202-15. [pmid: 17160917].
135 Espeland M. Look AHEAD (Action for Health in Diabetes): Design and methods for a clinical trial of weight loss for the prevention of cardiovascular disease in type 2 diabetes. Control Clin Trials. 2003;24(5):610-28. [pmid: 14500058].
136 Gorin AA, Niemeier HM, Hogan P, et al. Binge eating and weight loss outcomes in overweight and obese individuals with type 2 diabetes: results from the Look AHEAD trial. Arch Gen Psychiatry. 2008;65(12):1447-55. [pmid: 19047532].
137 Jakicic JM, Jaramillo SA, Balasubramanyam A, et al. Effect of a lifestyle intervention on change in cardiorespiratory fitness in adults with type 2 diabetes: results from the Look AHEAD Study. Int J Obes. 2009;33(3):305-16.
138 Wadden TA. The look AHEAD study: A description of the lifestyle intervention and the evidence supporting it. Obesity. 2006;14(5):737-52. [pmid: 16855180].
139 Wadden TA, West DS, Neiberg RH, et al. One-year weight losses in the Look AHEAD study: factors associated with success. Obesity. 2009;17(4):713-22. [pmid: 19180071].
140 Williamson DA, Rejeski J, Lang W, et al. Impact of a weight management program on health-related quality of life in overweight adults with type 2 diabetes. Arch Intern Med. 2009;169(2):163-71. [pmid: 19171813].
141 Culturally appropriate lifestyle interventions promote weight loss in rural dwelling people with type 2 diabetes. Evidence-Based Healthcare and Public Health. 2005;9(3):231-2.
142 Mayer-Davis EJ, D’antonio A, Martin M, et al. Pilot study of strategies for effective weight management in type 2 diabetes: Pounds off with empowerment (POWER). Fam Commun Health. 2001;24(2):27-35.
143 Parra-Medina D, D’antonio A, Smith SM, et al. Successful recruitment and retention strategies for a randomized weight management trial for people with diabetes living in rural, medically underserved counties of South Carolina: the POWER study. J Am Diet Assoc. 2004;104(1):70-5. [pmid: 14702587].
144 Menard J, Payette H, Dubuc N, et al. Quality of life in type 2 diabetes patients under intensive multitherapy. Diabetes Metab. 2007;33(1):54-60. [pmid: 17258926].
145 Barrera M Jr, Toobert DJ, Angell KL, et al. Social support and social-ecological resources as mediators of lifestyle intervention effects for type 2 diabetes. J Health Psychol. 2006;11(3):483-95. [pmid: 16774900].
146 Toobert DJ, Glasgow RE, Strycker LA, et al. Long-term effects of the Mediterranean lifestyle program: A randomized clinical trial for postmenopausal women with type 2 diabetes. Int J Behav Nutr Phys Act. 2007;4(1).
147 Toobert DJ, Strycker LA, Glasgow RE, et al. Effects of the mediterranean lifestyle program on multiple risk behaviors and psychosocial outcomes among women at risk for heart disease. Ann Behav Med. 2005;29(2):128-37. [pmid: 15823786].
148 Toobert DJ, Strycker LA, Glasgow RE, et al. Enhancing support for health behavior change among women at risk for heart disease: the Mediterranean Lifestyle Trial. Health Educ Res. 2002;17(5):574-85. [pmid: 12408202].
149 Bo S, Ciccone G, Baldi I, et al. Plasma visfatin concentrations after a lifestyle intervention were directly associated with inflammatory markers. Nutr Metab Cardiovasc Dis. 2009;19(6):423-30. [pmid: 19073361].
150 Bo S, Ciccone G, Guidi S, et al. Diet or exercise: What is more effective in preventing or reducing metabolic alterations?. Eur J Endocrinol. 2008;159(6):685-91. [pmid: 18772269].
151 Bo S, Gambino R, Ciccone G, et al. Effects of TCF7L2 polymorphisms on glucose values after a lifestyle intervention. Am J Clin Nutr. 2009;90(6):1502-8. [pmid: 19864407].
152 Evans MF. Can we prevent high-risk patients from getting type 2 diabetes?. Can Fam Phys. 2002;48:279-81.
153 Hamalainen H, Ronnemaa T, Virtanen A, et al. Improved fibrinolysis by an intensive lifestyle intervention in subjects with impaired glucose tolerance. The Finnish Diabetes Prevention Study. Diabetologia. 2005;48(11):2248-53. [pmid: 16205886].
154 Herder C, Peltonen M, Koenig W, et al. Anti-inflammatory effect of lifestyle changes in the Finnish Diabetes Prevention Study. Diabetologia. 2009;52(3):433-42. [pmid: 19130041].
155 Kilpelainen TO, Lakka TA, Laaksonen DE, et al. Physical activity modifies the effect of SNPs in the SLC2A2 (GLUT2) and ABCC8 (SUR1) genes on the risk of developing type 2 diabetes. Physiological Genomics. 2007;31(2):264-72. [pmid: 17636114].
156 Kubaszek A, Pihlajamaki J, Komarovski V, et al. Promoter polymorphisms of the TNF-alpha (G-308A) and IL-6 (C-174G) genes predict the conversion from impaired glucose tolerance to type 2 diabetes: The Finnish Diabetes Prevention study. Diabetes. 2003;52(7):1872-6. [pmid: 12829659].
157 Laaksonen DE, Lindstrom J, Lakka TA, et al. Physical activity in the prevention of type 2 diabetes: the Finnish diabetes prevention study. Diabetes. 2005;54(1):158-65. [pmid: 15616024].
158 Lindstrom J. Sustained reduction in the incidence of type 2 diabetes by lifestyle intervention: follow-up of the Finnish Diabetes Prevention Study. Lancet. 2006;368(9548):1673-9. [pmid: 17098085].
159 Lindstrom J, Eriksson JG, Valle TT, et al. Prevention of diabetes mellitus in subjects with impaired glucose tolerance in the Finnish Diabetes Prevention Study: results from a randomized clinical trial. J Am Soc Nephrol. 2003;14(7:Suppl 2):Suppl-13.
160 Lindstrom J, Louheranta A, Mannelin M, et al. The Finnish Diabetes Prevention Study (DPS): Lifestyle intervention and 3-year results on diet and physical activity. Diabetes Care. 2003;26(12):3230-6. [pmid: 14633807].
161 Tuomilehto J, Lindstrom J, Eriksson JG, et al. Prevention of type 2 diabetes mellitus by changes in lifestyle among subjects with impaired glucose tolerance. N Engl J Med. 2001;344(18):1343-50. [pmid: 11333990].
162 Tuomilehto H, Peltonen M, Partinen M, et al. Sleep duration, lifestyle intervention, and incidence of type 2 diabetes in impaired glucose tolerance: The Finnish Diabetes Prevention Study. Diabetes Care. 2009;32(11):1965-71. [pmid: 19651919].
163 Uusitupa M, Peltonen M, Lindstrom J, et al. Ten-year mortality and cardiovascular morbidity in the Finnish Diabetes Prevention Study - Secondary analysis of the randomized trial. PLoS ONE. 2009;4(5).
164 Wikstrom K, Peltonen M, Eriksson JG, et al. Educational attainment and effectiveness of lifestyle intervention in the Finnish Diabetes Prevention Study. Diabetes Res Clin Pract. 2009;86(1).
165 Diabetes Prevention Program Research Group. Crandall J, Schade D, et al. The influence of age on the effects of lifestyle modification and metformin in prevention of diabetes. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2006;61(10):1075-81.
166 Diabetes Prevention Program Research Group. Knowler WC, Fowler SE, et al. 10-year follow-up of diabetes incidence and weight loss in the Diabetes Prevention Program Outcomes Study. Lancet. 2009;374(9702):1677-86. [pmid: 19878986].
167 Fujimoto WY, Jablonski KA, Bray GA, et al. Body size and shape changes and the risk of diabetes in the diabetes prevention program. Diabetes. 2007;56(6):1680-5. [pmid: 17363740].
168 Haffner S, Temprosa M, Crandall J, et al. Intensive lifestyle intervention or metformin on inflammation and coagulation in participants with impaired glucose tolerance. Diabetes. 2005;54(5):1566-72. [pmid: 15855347].
169 Orchard TJ, Temprosa M, Goldberg R, et al. The effect of metformin and intensive lifestyle intervention on the metabolic syndrome: the Diabetes Prevention Program randomized trial. Ann Intern Med. 2005;142(8):611-9. [pmid: 15838067].
170 Perreault L, Ma Y, gogo-Jack S, et al. Sex differences in diabetes risk and the effect of intensive lifestyle modification in the Diabetes Prevention Program. Diabetes Care. 2008;31(7):1416-21. [pmid: 18356403].
171 The Diabetes Prevention Program (DPP): Description of lifestyle intervention. Diabetes Care. 2002;25(12):2165-71. [pmid: 12453955].
172 The Diabetes Prevention Program. Design and methods for a clinical trial in the prevention of type 2 diabetes. Diabetes Care. 1999;22(4):623-34. [pmid: 10189543].
173 Corpeleijn E, Feskens EJ, Jansen EH, et al. Improvements in glucose tolerance and insulin sensitivity after lifestyle intervention are related to changes in serum fatty acid profile and desaturase activities: the SLIM study. Diabetologia. 2006;49(10):2392-401. [pmid: 16896932].
174 Corpeleijn E, Feskens EJ, Jansen EH, Mensink M, Saris WH, Blaak EE. Lifestyle intervention and adipokine levels in subjects at high risk for type 2 diabetes: the Study on Lifestyle intervention and Impaired glucose tolerance Maastricht (SLIM). Diabetes Care. 2007;(12):3125-7. [pmid: 17890316].
175 Mensink M, Blaak EE, Corpeleijn E, et al. Lifestyle intervention according to general recommendations improves glucose tolerance. Obes Res. 2003;11(12):1588-96. [pmid: 14694225].
176 Mensink M, Blaak EE, Wagenmakers AJ, et al. Lifestyle intervention and fatty acid metabolism in glucose-intolerant subjects. Obes Res. 2005;13(8):1354-62. [pmid: 16129717].
177 Mensink M, Corpeleijn E, Feskens EJ, et al. Study on lifestyle-intervention and impaired glucose tolerance Maastricht (SLIM): design and screening results. Diabetes Res Clin Pract. 2003;61(1):49-58. [pmid: 12849923].
178 Roumen C, Corpeleijn E, Feskens EJ, et al. Impact of 3-year lifestyle intervention on postprandial glucose metabolism: the SLIM study. Diabet Med. 2008;25(5):597-605. [pmid: 18445174].
179 Oldroyd JC, Unwin NC, White M, et al. Randomised controlled trial evaluating lifestyle interventions in people with impaired glucose tolerance. Diabetes Res Clin Pract. 2006;72(2):117-27. [pmid: 16297488].
180 Li G, Hu Y, Yang W, et al. Effects of insulin resistance and insulin secretion on the efficacy of interventions to retard development of type 2 diabetes mellitus: the DA Qing IGT and Diabetes Study. Diabetes Res Clin Pract. 2002;58(3):193-200. [pmid: 12413779].
181 Li G, Zhang P, Wang J, et al. The long-term effect of lifestyle interventions to prevent diabetes in the China Da Qing Diabetes Prevention Study: a 20-year follow-up study. Lancet. 2008;371(9626):1783-9. [pmid: 18502303].
182 demark-Wahnefried W, Morey MC, Clipp EC, et al. Leading the Way in Exercise and Diet (Project LEAD): Intervening to improve function among older breast and prostate cancer survivors. Control Clin Trials. 2003;24(2):206-23. [pmid: 12689742].
183 Mosher CE, Sloane R, Morey MC, et al. Associations between lifestyle factors and quality of life among older long-term breast, prostate, and colorectal cancer survivors. Cancer. 2009;115(17):4001-9. [pmid: 19637244].
184 Snyder DC, Morey MC, Sloane R, et al. Reach out to ENhancE Wellness in Older Cancer Survivors (RENEW): design, methods and recruitment challenges of a home-based exercise and diet intervention to improve physical function among long-term survivors of breast, prostate, and colorectal cancer. PSYCHO ONCOL. 2009;18(4):429-39.
185 Daubenmier JJ, Weidner G, Marlin R, et al. Lifestyle and health-related quality of life of men with prostate cancer managed with active surveillance. Urology. 2006;67(1):125-30. [pmid: 16413347].
186 Frattaroli J, Weidner G, Dnistrian AM, et al. Clinical events in prostate cancer lifestyle trial: results from two years of follow-up. Urology. 2008;72(6):1319-23. [pmid: 18602144].
187 Ornish DM, Lee KL, Fair WR, Pettengill EB, Carroll PR. Dietary trial in prostate cancer: Early experience and implications for clinical trial design. Urology. 2001;4(Suppl 1):200-1. [pmid: 11295627].
188 Ganda OP. A targeted, multifactorial intervention reduced mortality in patients with type 2 diabetes and microalbuminuria. ACP J Club. 2008;149(2):4. [pmid: 18710177].
189 Sustained effect of intensive treatment of type 1 diabetes mellitus on development and progression of diabetic nephropathy: the Epidemiology of Diabetes Interventions and Complications (EDIC) study. JAMA. 2003;290(16):2159-67. [pmid: 14570951].
190 White NH, Sun W, Cleary PA, et al. Prolonged effect of intensive therapy on the risk of retinopathy complications in patients with type 1 diabetes mellitus: 10 years after the Diabetes Control and Complications Trial. Arch Ophthalmol. 2008;126(12):1707-15. [pmid: 19064853].
191 Wing RR. Long-term effects of a lifestyle intervention on weight and cardiovascular risk factors in individuals with type 2 diabetes mellitus: four-year results of the Look AHEAD trial. Arch Intern Med. 2010;170(17):1566-75. [pmid: 20876408].
192 Yki-Jarvinen H. Combination therapies with insulin in type 2 diabetes. Diabetes Care. 2001;24(4):758-67. [pmid: 11315844].
193 Guare JC, Wing RR, Grant A. Comparison of obese NIDDM and nondiabetic women: short- and long-term weight loss. Obes Res. 1995;3(4):329-35. [pmid: 8521149].
194 Pyorala K, Pedersen TR, Kjekshus J, et al. Cholesterol lowering with simvastatin improves prognosis of diabetic patients with coronary heart disease. A subgroup analysis of the Scandinavian Simvastatin Survival Study (4S). Diabetes Care. 1997;20(4):614-20. [pmid: 9096989].
195 Ravid M, Lang R, Rachmani R, et al. Long-term renoprotective effect of angiotensin-converting enzyme inhibition in non-insulin-dependent diabetes mellitus. A 7-year follow-up study. Arch Intern Med. 1996;156(3):286-9. [pmid: 8572838].
196 Yusuf S, Sleight P, Pogue J, et al. Effects of an angiotensin-converting-enzyme inhibitor, ramipril, on cardiovascular events in high-risk patients. The Heart Outcomes Prevention Evaluation Study Investigators. N Engl J Med. 2000;342(3):145-53. [pmid: 10639539].
197 Franz MJ, Monk A, Barry B, et al. Effectiveness of medical nutrition therapy provided by dietitians in the management of non-insulin-dependent diabetes mellitus: a randomized, controlled clinical trial. J Am Diet Assoc. 1995;95(9):1009-17. [pmid: 7657902].
198 Thomas DE, Elliott EJ, Naughton GA. Exercise for type 2 diabetes mellitus. Cochrane Database Syst Rev. 2006;3:CD002968. [pmid: 16855995].
199 Stratton IM, Cull CA, Adler AI, et al. Additive effects of glycaemia and blood pressure exposure on risk of complications in type 2 diabetes: a prospective observational study (UKPDS 75). Diabetologia. 2006;49(8):1761-9. [pmid: 16736131].
200 Horton ES. Effects of lifestyle changes to reduce risks of diabetes and associated cardiovascular risks: results from large scale efficacy trials. Obesity (Silver Spring). 2009;17(Suppl 3):S43-S48. [pmid: 19927146].
201 Gillies CL, Abrams KR, Lambert PC, et al. Pharmacological and lifestyle interventions to prevent or delay type 2 diabetes in people with impaired glucose tolerance: systematic review and meta-analysis. BMJ. 2007;334(7588):299. [pmid: 17237299].
202 Herman WH, Hoerger TJ, Brandle M, et al. The cost-effectiveness of lifestyle modification or metformin in preventing type 2 diabetes in adults with impaired glucose tolerance. Ann Intern Med. 2005;142(5):323-32. [pmid: 15738451].
203 Prestigiacomo AF, Stamey TA. Physiological variation of serum prostate specific antigen in the 4.0 to 10.0 ng./ml. range in male volunteers. J Urol. 1996;155(6):1977-80. [pmid: 8618301].
204 Ornstein DK, Smith DS, Rao GS, et al. Biological variation of total, free and percent free serum prostate specific antigen levels in screening volunteers. J Urol. 1997;157(6):2179-82. [pmid: 9146610].
205 Soletormos G, Semjonow A, Sibley PE, et al. Biological variation of total prostate-specific antigen: a survey of published estimates and consequences for clinical practice. Clin Chem. 2005;51(8):1342-51. [pmid: 15961552].
206 Carter HB, Pearson JD, Metter EJ, et al. Longitudinal evaluation of prostate-specific antigen levels in men with and without prostate disease. JAMA. 1992;267(16):2215-20. [pmid: 1372942].
207 Boddy JL, Pike DJ, Al-Hayek S, et al. An elevated PSA, which normalizes, does not exclude the presence of prostate cancer. Prostate Cancer Prostatic Dis. 2005;8(4):349-52. [pmid: 16010283].
208 Connolly D, Black A, Murray LJ, et al. Repeating an abnormal prostate-specific antigen (PSA) level: how relevant is a decrease in PSA?. Prostate Cancer Prostatic Dis. 2009;12(1):47-51. [pmid: 18762815].
209 Cancer Control Population Sciences: Research Findings. National Cancer Institute Office of Cancer Survivorship. 2010.
210 Bellizzi KM, Rowland JH, Jeffery DD, et al. Health behaviors of cancer survivors: examining opportunities for cancer control intervention. J Clin Oncol. 2005;23(34):8884-93. [pmid: 16314649].
211 Goldstein MG, Whitlock EP, DePue J. Multiple behavioral risk factor interventions in primary care. Summary of research evidence. Am J Prev Med. 2004;27(2 Suppl):61-79. [pmid: 15275675].
212 Simons-Morton DG, Calfas KJ, Oldenburg B, et al. Effects of interventions in health care settings on physical activity or cardiorespiratory fitness. Am J Prev Med. 1998;15(4):413-30. [pmid: 9838981].
213 Williams NH, Hendry M, France B, et al. Effectiveness of exercise-referral schemes to promote physical activity in adults: systematic review. Br J Gen Pract. 2007;57(545):979-86. [pmid: 18252074].
214 Hudon C, Fortin M, Soubhi H. Single risk factor interventions to promote physical activity among patients with chronic diseases: systematic review. Can Fam Physician. 2008;54(8):1130-7. [pmid: 18697975].
215 Wister A, Loewen N, Kennedy-Symonds H, et al. One-year follow-up of a therapeutic lifestyle intervention targeting cardiovascular disease risk. CMAJ. 2007;177(8):859-65. [pmid: 17923653].
216 Shaw K, Gennat H, O’Rourke P, et al. Exercise for overweight or obesity. Cochrane Database Syst Rev. 2006;(4):CD003817. [pmid: 17054187].
217 Gutt R, Tonlaar N, Kunnavakkam R, et al. Statin use and risk of prostate cancer recurrence in men treated with radiation therapy. J Clin Oncol. 2010;28(16):2653-9. [pmid: 20421534].
218 Schulz KF, Altman DG, Moher D. CONSORT 2010 statement: updated guidelines for reporting parallel group randomised trials. PLoS Med. 2010;7(3):e1000251. [pmid: 20352064].