# Executive Summary

## Introduction

Chronic diseases are the leading cause of death and disability worldwide. According to the World Health Organization, 88 percent of deaths in the United States in 2002 were attributable to chronic disease.1 Prevention of the onset or progression of chronic disease is often promoted as the gold standard,1 although the optimal interventions to achieve this have not been well documented. A number of lifestyle behaviors contribute to overall morbidity and mortality of chronic disease. Among these, physical activity and diet have been identified as two modifiable risk factors that may impact onset or progression of disease.

Previous research has suggested that improved diet may decrease the burden of chronic disease, particularly coronary heart disease.2–5 However, the benefits of lifestyle modifications in preventing progression or recurrence of disease is not as well documented. In addition, it remains unclear how effective interventions are in modifying risk factors, and which chronic diseases, if any, would benefit.

The chronic diseases examined in this review are type 2 diabetes, metabolic syndrome, breast and prostate cancer. Type 2 diabetes is a major cause of morbidity and mortality. Diabetes was the seventh leading cause of death in the U.S. in 2006;^6^ cardiovascular disease (CVD) accounted for more than 65 percent of all diabetic deaths.7 Diabetes is also the leading cause of kidney failure, nontraumatic lower-extremity amputations, and blindness among adults in the U.S.8

Metabolic syndrome is defined as a constellation of interrelated metabolic risk factors that promote the development of CVD and type 2 diabetes. The most widely recognized metabolic risk factors are dyslipidemia, elevated plasma glucose, and hypertension. Its clinical utility for risk prediction is controversial. Prediabetes, which includes impaired fasting glucose (IFG) and impaired glucose tolerance (IGT), has been suggested to be equally effective in identifying those at risk of developing type 2 diabetes. Our operational definition of metabolic syndrome included metabolic syndrome, insulin resistance, prediabetes, IFG, IGT, syndrome X, dysmetabolic syndrome X, and Reaven syndrome. Approximately 64 million or 25 percent of adults in the U.S. had metabolic syndrome in 2000.^9^ As of 2011, the American Diabetes Association estimated that 57 million people in the U.S. had prediabetes.10

Many risk factors for the development of metabolic syndrome have been proposed, one of which is obesity.11 Additional risk factors include increasing age12,13 and physical inactivity.14

Breast cancer is defined as the development of malignant cells in the breast which usually originate from the ducts or lobules of the breast. The National Cancer Institute estimates that in 2010 there will be 209,060 new cases of breast cancer diagnosed, with 40,230 deaths.15 Survival and recurrence rates depend on a number of factors including stage of the cancer at diagnosis. There is a strong correlation between obesity and increased risk of breast cancer.16–18 Studies have suggested that increased physical activity reduces the incidence of breast cancer.19 A recent systematic review found that physical activity could reduce the incidence of breast cancer in postmenopausal women by 20 to 80 percent.20

Prostate cancer. Prostate cancer is defined as a malignant growth of cells in the prostate gland. It is the second leading cause of death of males in the U.S. It is estimated that 217,730 men will be diagnosed with and 32,050 will die of prostate cancer in the U.S. in 2010.^21^ The impact of lifestyle factors on the incidence or recurrence of prostate cancer is unclear. Results from studies of the association between dietary intake and risk of prostate cancer are inconsistent.22–24 Research has shown an association between body mass index (BMI) and incidence of prostate cancer.25 The effect of physical activity on the incidence prostate cancer continues to be debated.26,27

### Key Questions

The objective of this report was to synthesize the evidence from randomized controlled trials (RCTs) for the following key questions.

1. What is the evidence on the effectiveness of lifestyle interventions for breast cancer, prostate cancer, metabolic syndrome, and type 2 diabetes mellitus?
2. What is the generalizability of the evidence to the Medicare population (> 65 years)?
3. What is the evidence on whether specific components of the interventions, composition of the team, and/or patient characteristics contribute to better outcomes?

## Methods

### Literature Search

We systematically searched the following bibliographic databases for studies published from 1980 to March 2010: MEDLINE®, Embase, Cochrane Controlled Trials Register (CENTRAL), CINAHL®, and SCOPUS. Language restrictions were applied to restrict results to English language only. A filter for RCTs was applied to search results. Ongoing studies were identified by searching clinical trials registers; reference lists of relevant studies were searched to identify additional studies.

### Study Selection

Two reviewers independently screened titles and abstracts using broad inclusion criteria. The full text of all articles identified as “include” or “unclear” were retrieved for formal review. Each article was independently assessed by two reviewers using a standardized form. Disagreements were resolved by consensus or third-party adjudication.

RCTs that included adults ( 18 years) who were survivors of breast cancer, survivors of prostate cancer, have type 2 diabetes, or metabolic syndrome were considered. The lifestyle intervention had to include an exercise component, a diet component, and at least one other component (e.g., counseling, smoking cessation, behavior modification). The comparison could be usual care, the diet and/or exercise components alone, or wait list. The duration of the intervention was at least 3 months with a minimum 6 month followup period. We made a post hoc modification to also include RCTs that had no followup if the duration of the intervention was at least 1 year. The primary outcomes were recurrence of breast or prostate cancer, progression of type 2 diabetes to additional medication or insulin or to cardiovascular problems, hypertension or neuropathies, or progression of metabolic syndrome to diabetes, heart disease, or stroke. Secondary outcomes included physical activity, dietary or nutrient intake, body composition, and metabolic variables.

### Quality Assessment and Rating the Body of Evidence

Two reviewers independently assessed the methodological quality of included studies using the Cochrane Collaboration’s risk of bias tool. Discrepancies were resolved through consensus or third-party adjudication.

The body of evidence was rated by one reviewer using the EPC GRADE approach. The strength of evidence was assessed for our primary outcomes and secondary outcomes related to physical activity, dietary or nutrient intake, body composition, and metabolic variables. The overall strength of evidence was graded as high, moderate, low, or insufficient.

### Data Extraction

Data were extracted by one reviewer using a standardized form and verified for accuracy and completeness by a second reviewer. Reviewers resolved discrepancies by consensus or in consultation with a third party. Extracted data included study characteristics, inclusion/exclusion criteria, participant characteristics, interventions, and outcomes.

### Data Analysis

Evidence tables and qualitative descriptions of results are presented. When appropriate, results were combined using random effects models. Statistical heterogeneity was quantified using the I-squared (I^2^) statistic.

## Results

### Description of Included Studies

The search identified 1,288 studies; 20 unique RCTs (reporting data from 80 articles) were included in the review. Ten studies addressed type 2 diabetes, seven addressed metabolic syndrome, and three addressed prostate and/or breast cancer.

All studies included a diet and exercise component plus at least one additional component, including, but not limited to, individual and/or group counseling, behavior modification, a smoking cessation program, regular telephone contact, individual goal setting, stress management, medication, and regular blood glucose and blood monitoring.

The interventions were administered or delivered by a range of care providers including, but not limited to, dietitians, case managers or nurses, physicians, qualified exercise trainers, behavioral therapists, peer counselors, lay leaders, and trained support group leaders.

### KQ1a What is the evidence on the effectiveness of lifestyle interventions for type 2 diabetes mellitus?

Ten RCTs assessed the effectiveness of lifestyle interventions for type 2 diabetes. The interventions ranged from 6 to 48 months; followup periods ranged from 6 to 93 months. The number of participants ranged from 72 to 5,145 (median = 194; IQR 143, 259). Two RCTs were considered at high risk of bias; eight were unclear.

Results are presented in Table ES1 and are summarized below.

- Primary outcomes. One study, which included medication as part of the lifestyle intervention, found that the intervention decreased the number of nonfatal strokes, nonfatal myocardial infarctions, amputations, and death at 13.3 year followup. There was also a difference between groups for the progression of autonomic neuropathy in favor of the lifestyle intervention, but no difference was seen in the progression of peripheral neuropathy at all followup time points.
- Change in body composition. Five studies reported change in weight. At the end of intervention, there was a statistically significant difference in favor of lifestyle interventions, and no difference between the groups at 6 month followup. Five studies reported change in BMI (kg/m^2^). At the end of the intervention, there was a statistically significant difference in favor of the lifestyle intervention. Effect of the intervention at different postintervention timepoints was inconsistent.
- Change in metabolic variables. Ten studies reported on changes in metabolic variables. For lifestyle interventions that did not include medication as part of the intervention, there was no statistically significant difference between groups for any of the metabolic variables at the end of intervention. For lifestyle interventions that included medication, the results were statistically significant in favor of lifestyle for fasting plasma glucose, HDL cholesterol, and HbA1c. These differences were not always sustained during followup.
- Systolic and diastolic blood pressure. Eight studies reported changes in systolic and diastolic blood pressure (mmHg). For lifestyle interventions that did not include medication as a component, there was no statistically significant difference between groups for either outcome at the end of intervention. For lifestyle interventions that included medication, the results were statistically significant in favor of lifestyle for diastolic, but not systolic blood pressure. Effect of the intervention at different followup timepoints was inconsistent.
- Change in physical activity. Seven studies reported changes in physical activity using different outcome measures. At the end of intervention, there was a statistically significant difference in favor of the lifestyle intervention. There was a significant difference between groups at 1 and 2 years of followup.
- Change in dietary or nutrient intake. Four studies measured change in dietary or nutrient intake. There was a significant difference in energy intake favoring the lifestyle intervention at end of intervention. There was no difference between groups at any followup timepoint. There was no significant difference between groups in consumption of saturated fats at end of intervention; however, the lifestyle intervention was favored at all followup timepoints.

Table ES1 Summary table: type 2 diabetes

Outcome | # RCTs | Strength of evidence | Summary
Primary outcomes
All-cause mortality (13 yr followup) | 1 | Low | Significant effect in favor of lifestyle intervention (RR_meds_ = 0.60; 95% CI: 0.4, 0.9)
Cumulative incidence of CVD events (13 yr followup) | 1 | Low | Significant effect in favor of lifestyle intervention (RR_meds_ = 0.49; 95% CI: 0.34, 0.71)
Autonomic neuropathy progression (13 yr followup) | 1 | Low | Significant effect in favor of lifestyle intervention (RR_meds_ = 0.75; 95% CI: 0.57, 0.99)
Development of nephropathy (13 yr followup) | 1 | Low | Significant effect in favor of lifestyle intervention (RR_meds_ = 0.54; 95% CI: 035, 0.85)
Development of retinopathy (13 yr followup) | 1 | Low | Significant effect in favor of lifestyle intervention (RR_meds_ = 0.76; 95% CI: 0.58, 0.99)
Peripheral neuropathy progression (13 yr followup) | 1 | Low | No significant difference between groups (RR_meds_ = 0.96; 95% CI: 0.73, 1.26)
Change in body composition
BMI (EoI) | 5 | Moderate | Significant effect in favor of lifestyle intervention (MD_all_ = −0.48; 95% CI: −0.92, −0.05)
BMI (6 mo postintervention) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD_meds_ = 1.0; 95%CI: −1.84, 3.84)
BMI (13 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD_meds_ = −1.1; 95% CI: −3.14, 0.94)
Weight change (EoI) | 5 | Moderate | No significant difference between groups (MD_no meds_ = −1.53; 95% CI: −2.09, −0.97; MD_meds_ = −15.4; 95% CI: −16.1, −14.5)
Weight change (6 mo postintervention) | 1 | Insufficient | Effect favors usual care, though not significantly (RR_meds_ = 1.14; 95% CI: −5.39, 7.67)
Weight change (4 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD_meds_ = −11.62; 95% CI: −12.37, −10.87)
Metabolic variables
Fasting plasma glucose (EoI) | 4 | Low | Significant effect in favor of lifestyle intervention (MD_no meds_ = 0.33; 95% CI: −0.83, 1.49; MD_meds_ = −1.02; 95% CI: −1.85, −0.19)
Fasting plasma glucose (6 mo postintervention) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD_meds_ = −1.0; 95% CI: −2.61, 0.61)
Fasting plasma glucose (13 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD_meds_= −0.16; 95% CI: −1.47, 1.15)
HbA1c (EoI) | 10 | Low | Significant effect in favor of lifestyle intervention (MD_no meds_ = −0.09; 95% CI: −0.58, 0.75; MD_meds_ = 0.77; 95% CI: −1.18, −0.36)
HbA1c (6 mo postintervention) | 2 | Insufficient | No significant difference between groups (MD_all_ = 0.09; 95% CI: −0.58, 0.75)
HbA1c (13 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD_meds_ = −0.70; 95% CI: −1.41, 0.01)
HDL cholesterol (EoI) | 6 | Low | Significant effect in favor of lifestyle intervention (MD_no meds_ = −0.01; −0.04, 0.05; MD_meds_ = 0.05; 95% CI: 0.03, 0.07)
HDL cholesterol (6 mo postintervention) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD _no meds_ = −0.04; 95% CI: −0.16, 0.09)
HDL cholesterol (13 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD_meds_ = 0.08; 95% CI: −0.07, 0.22)
LDL cholesterol (EoI) | 5 | Low | No significant difference between groups (MD_no meds_ = −0.09; 95% CI: −0.26, 0.08; MD_meds_ = −0.27; 95% CI: −0.92, 0.37)
LDL cholesterol (6 mo postintervention) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD_meds_ = −0.59; 95% CI: −1.07, −0.11)
LDL cholesterol (13 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD_meds_= −0.05; 95% CI: −0.4, 0.3)
Total cholesterol (EoI) | 5 | Low | No significant difference between groups (MD_all_ = −0.13; 95% CI: −0.27, 0.01),
Total cholesterol (6 mo postintervention) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD_no meds_ = 0.01; 95% CI: −0.35, 0.36)
Total cholesterol (13 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD_meds_ = 0.38; 95% CI: −0.06, 0.82)
Triglycerides (EoI) | 5 | Low | Significant effect in favor of lifestyle intervention (MD_all_ = −0.17; 95% CI: −0.23, −0.12)
Triglycerides (6 mo postintervention) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD_meds_ = −0.18; 95% CI: −1.47, 1.11)
Triglycerides (13 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD_meds_ = −0.03; 95% CI: −0.67, 0.61)
Blood pressure
Diastolic BP (EoI) | 6 | Low | No significant difference between groups (MD_no meds_ = 0.32; 95% CI: −1.43, 20.7; MD_meds_ = −1.2; 95% CI: −1.75, 0.65)
Diastolic BP (6 mo postintervention) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD_meds_ = 0; 95% CI: −5.07, 5.07)
Diastolic BP (13 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD_meds_ = 2.0; 95% CI: −1.90, 5.90)
Systolic BP (EoI) | 6 | Low | No significant difference between groups (MD_no meds_ = −1.89; 95% CI: −0.57, 4.35; MD_meds_ −6.89; 95% CI: −14.42, 0.64)
Systolic BP (6 mo postintervention) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD_meds_ = −3.0; 95% CI: −12.4, 6.4)
Systolic BP (13 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD_meds_ = −3.0; 95% CI: −9.79, 3.79)
Change in physical activity
Exercise (EoI) | 6 | Low | Significant effect in favor of lifestyle intervention (SMD_all_ = 0.45; 95% CI: 0.2, 0.71)
Exercise (6 mo postintervention) | 4 | Low | Significant effect in favor of lifestyle intervention (SMD_all_ = 0.5; 95% CI: 0.1, 0.89)
Exercise (2 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (SMD _no meds_ = 0.41; 95% CI: 0.16, 0.67)
Exercise (8 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (SMD_meds_ = 0.11; 95% CI: −0.24, 0.45)
Change in dietary or nutrient intake
Energy intake (EoI) | 5 | Low | Significant effect in favor of lifestyle intervention (SMD_all_ = −0.17; 95% CI: −0.33, −0.01)
Energy intake (6 mo postintervention) | 1 | Insufficient | The evidence was too limited to draw a conclusion (SMD_meds_ = −0.12; 95% CI: −0.59, 0.36)
Energy intake (8 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (SMD_meds_ = 0; 95% CI: −0.35, 0.34)
SFA intake (EoI) | 5 | Low | No significant difference between groups (SMD_all_ = −0.31; 95% CI: −0.68, 0.07)
SFA intake (6 mo postintervention | 2 | Insufficient | Significant effect in favor of lifestyle intervention (SMD_all_ = −0.45 95% CI: −0.79, −0.10)
SFA intake (8 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (SMD_meds_ = −0.68; 95% CI: −1.03, −0.32)

BMI = body mass index; BP = blood pressure; CI = confidence interval; CVD = cardiovascular disease; EoI = end of intervention; HbA1c = glycosylated haemoglobin; HDL = high density lipoprotein; LDL = low density lipoprotein; MD = mean difference; meds = medication (as part of the lifestyle intervention); mo = month(s); RCT = randomized controlled trial; RR = risk ratio; SFA = saturated fatty acid; SMD = standardized mean difference; yr = year(s)

### KQ1b What is the evidence on the effectiveness of lifestyle interventions for metabolic syndrome?

Seven RCTs assessed the effectiveness of lifestyle interventions for metabolic syndrome. The duration of the interventions ranged from 6 to 72 months, with followup periods ranging from 3 to 14 years. The number of participants ranged from 39 to 3,234 (median = 375; IQR = 113, 437). Three RCTs were considered to be at high risk of bias; four were unclear.

Results are presented in Table ES2 and are summarized below.

- Primary outcomes. Four studies assessed CVD complications, development of type 2 diabetes, and death. There were no significant differences between the groups except for the development of type 2 diabetes. Two long-term studies found that lifestyle interventions significantly decreased the risk of developing type 2 diabetes.
- Change in body composition. Six studies reported change in weight. At 4 years postintervention, two studies reported a statistically significant difference in favor of the lifestyle intervention. At 10 years, there was no longer a difference between groups. Four studies reported change in BMI. At both end of intervention and 4 years followup, there was a statistically significant difference favoring the lifestyle intervention. Five studies reported change in waist circumference and reported a significant difference in favor of the lifestyle group at end of intervention and 4 years followup.
- Change in metabolic variables. Six studies reported on changes in different metabolic variables. For fasting plasma glucose, the lifestyle group was significantly favored at end of intervention and 4 year followup. At 10 years, there was a significant difference favoring the usual care group. For HbA1C, the lifestyle group was significantly favored at both 4 and 10 year followup. For all other metabolic variables, there was no significant difference between groups at the followup timepoints.
- Systolic and diastolic blood pressure. Five studies reported change in systolic and diastolic blood pressure. There was a significant difference between groups for both measures at the end of intervention and at followup.
- Change in physical activity. Four studies reported on the change in general exercise. At end of intervention and at 4 year followup, the lifestyle group was significantly favored.
- Change in dietary or nutrient intake. Four studies measured change in energy intake. The lifestyle group had a significantly lower energy intake and lower consumption of saturated fat at the end of the intervention compared with usual care.

Table ES2 Summary table: metabolic syndrome

Outcome | # RCTs | Strength of evidence | Precision
Primary outcomes
CVD events (Followup: 6–10 yr) | 2 | Insufficient | The evidence was too limited to draw a conclusion (RR = 1.02; 95% CI: 0.73, 1.42) (HR = 0.96; 95% CI: 0.76–1.44)
CVD events (20 yr) | 1 | Insufficient | No significant difference between groups (HR = 0.98; 95% CI: 0.71–1.37)
Development of type 2 diabetes (EoI: duration 1–6 yr) | 3 | Moderate | Significant effect in favor of lifestyle intervention (RR = 0.44; 95% CI: 0.2, 0.93)
Development of type 2 diabetes (Followup: 4–10 yr) | 3 | Moderate | Significant effect in favor of lifestyle intervention (RR_4 yr_ = 0.56; 95% CI: 0.48, 0.64; RR_6 yr_ = 0.44; 95% CI: 0.29, 0.68)
Death (Followup: 10–20 yr) | 2 | Insufficient | The evidence was too limited to draw a conclusion (RR_10 yr_ = 0.58; 95% CI: 0.21, 1.57; HR_20 yr_ = 0.83; 95% CI: 0.48, 1.40)
Body Composition
BMI (EoI) | 4 | Moderate | Significant effect in favor of lifestyle intervention (MD = −0.95; 95% CI: −1.49, −0.41)
BMI (4 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = −0.92; 95% CI: −1.32, −0.53)
Waist circumference (EoI) | 5 | Moderate | Significant effect in favor of lifestyle intervention (MD = −3.73; 95% CI: −4.87, −2.59)
Waist circumference (4 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD= −1.86; 95% CI: −3.49, −0.22)
Weight change (EoI) | 6 | Moderate | Significant effect in favor of lifestyle intervention (MD = −7.8; 95% CI: −11.92, −3.67)
Weight change ( 4 yr followup) | 2 | Low | The evidence was too limited to draw a conclusion (MD = −5.88; 95% CI: −8.05, −3.71)
Weight change (10 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = −0.94; 95% CI: −5.07, 3.19)
Metabolic variables
Fasting plasma glucose (EoI) | 5 | Moderate | Significant effect in favor of lifestyle intervention (MD = −0.29; 95% CI: −0.35, −0.23)
Fasting plasma glucose (10 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = 0.10; 95% CI: 0.03, 0.18)
HbA1c (EoI) | 2 | Insufficient | No significant difference between groups (MD = −0.10; 95% CI: −0.28, 0.08)
HbA1c (10 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = −0.05; 95% CI: −0.09, −0.02)
HDL cholesterol (EoI) | 4 | Moderate | Significant effect in favor of lifestyle intervention (MD = 0.08; 95% CI: 0.05, 0.10)
HDL cholesterol (4 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = 0.05; 95% CI: 0.0, 0.10)
Impaired plasma glucose (EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = 0.34; 95% CI: 0.23, 0.52)
LDL cholesterol (EoI) | 3 | Low | No significant difference between groups (MD = 0.04; 95% CI: −0.16, 0.25)
Total cholesterol (EoI) | 5 | Low | No significant difference between groups (MD = 0.0; 95% CI: −0.12, 0.13)
Triglycerides (EoI) | 4 | Low | No significant difference between groups (MD = −0.11; 95% CI: −0.26, 0.04)
Triglycerides (4 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = 0.09; 95% CI: −0.22, 0.05)
Blood pressure
Diastolic BP (EoI) | 5 | Moderate | Significant effect in favor of lifestyle intervention (MD=−2.70; 95% CI: −3.21, −2.18)
Diastolic BP (4 yr followup) | 2 | Low | The evidence was too limited to draw a conclusion (MD =−1.88; 95% CI: −2.65, −1.12)
Systolic BP (EoI) | 5 | Moderate | Significant effect in favor of lifestyle intervention (MD =−3.17; 95% CI: −5.02, −1.33)
Systolic BP (4 yr followup) | 2 | Low | The evidence was too limited to draw a conclusion (MD =−4.41; 95% CI: −8.47, −0.35)
Change in physical activity
Exercise (EoI) | 4 | Moderate | Significant effect in favor of lifestyle intervention (SMD = 0.40; 95% CI: 0.2, 0.59)
Exercise (4 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (SMD = 0.23; 95% CI: 0.10, 0.35)
Change in dietary or nutrient intake
Energy intake (EoI) | 4 | Moderate | Significant effect in favor of lifestyle intervention (SMD = −0.23; 95% CI: −0.31, −0.16)
SFA intake (EoI) | 2 | Low | Significant effect in favor of lifestyle intervention (SMD = −0.53; 95% CI: −0.73, −0.34)

BMI = body mass index; BP = blood pressure; CI = confidence interval; CVD = cardiovascular disease; EoI = end of intervention; HbA1c = glycosylated haemoglobin; HDL = high density lipoprotein; HR = hazard ratio; LDL = low density lipoprotein; MD = mean difference; RCT = randomized controlled trial; RR = risk ratio; SFA = saturated fatty acid; SMD = standardized mean difference

### KQ1c What is the evidence on the effectiveness of lifestyle interventions for breast and prostate cancer?

Three RCTs assessed the effectiveness of lifestyle interventions for breast and prostate cancer. One trial was assessed at high risk of bias; two were unclear. Project Leading the Way in Education Against Disease (Project LEAD) tested whether a personally tailored telephone counseling program was effective in improving diet and physical activity behavior among early stage breast and prostate cancer patients. The lifestyle intervention included a home-based diet and exercise program of telephone counseling and mailed materials. The mean age was 71.7±5.0 years. The duration of the intervention was 6 months with a 6 month followup.

Ornish et al. included men with prostate cancer who had declined conventional treatment. The lifestyle group followed a vegan diet, engaged in moderate aerobic exercise, learned stress management techniques, and participated in a weekly support group. The mean age was 65.7+7.4 years. The duration of the intervention was 1 year with no postintervention followup.

The Reach out to ENhancE Wellness in Older Cancer Survivors (RENEW) included overweight patients with breast and prostate cancer. The lifestyle intervention was a home-based program and included personally tailored workbooks, newsletters, telephone counseling, and automated prompts. The mean age was 73.1+5.0 years. The duration of the intervention was 1 year with a planned 1 year followup.

Results are presented in Table ES3 and are summarized below.

- Primary outcomes. One study assessed prostate-specific antigen PSA levels and found a significant decrease in levels for lifestyle intervention participants.
- Change in body composition. Two studies reported change in weight (lbs) at end of intervention. There is no difference between groups for breast cancer patients but a statistically significant difference favoring the lifestyle group for prostate cancer patients. Two studies reported change in BMI (kg/m^2^) and showed no statistically significant difference between groups for breast, prostate, and mixed cancer populations.
- Change in metabolic variables. One study reported metabolic outcomes. Statistically significant differences in favor of the lifestyle intervention were seen in all outcomes except triglycerides.
- Change in physical activity. Two studies looked at changes in exercise level. The difference between groups at end of intervention was statistically significant favoring the lifestyle group. One study reported a statistically significant increase in energy expenditure in favor of the lifestyle intervention at the end of intervention; this difference was no longer present at 6 months followup.
- Change in dietary or nutrient intake. All three studies assessed calories from fat. In two studies there was a statistically significant decrease in calories from fat in breast cancer and prostate cancer patients. One study showed no difference between groups in the mixed breast and prostate cancer populations at end of intervention and 6 months followup.

Table ES3 Summary table: breast and prostate cancer

Outcome | # RCTs | Strength of evidence | Precision
Breast cancer
Change in body composition
BMI (EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = −0.31; 95% CI: −1.19, 0.57)
Weight (EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = −3.9; 95% CI: −10.32, 2.52)
Change in physical activity
Exercise (endurance; EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = 25.6; 95% CI: 16.9, 34.8)
Change in dietary or nutrient intake
F&V intake (EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = 1.08; 95% CI: 0.5, 1.66)
Fat intake (calories from fat) (EoI) | 1 | Insufficient | Significant effect in favor of lifestyle intervention (MD = −1.76; −2.57, −0.95)
Prostate cancer
Primary outcome
PSA levels (EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = −0.63; 95% CI: −1.16, −0.10)
Change in body composition
BMI (EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = −0.61; 95% CI: −1.47, 0.25)
Weight (EoI) | 2 | Insufficient | Significant effect in favor of lifestyle intervention (MD = −7.55; 95% CI: −13.05, −2.05)
Change in metabolic variables
HDL cholesterol (EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = −6.4; 95% CI: −9.65, −3.15)
LDL cholesterol (EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = −28.6; 95% CI: −40.79, −16.41)
Total cholesterol (EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = −34.0; 95% CI: −48.30, −19.7)
Triglycerides (EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD= −9.0; 95% CI: −39.62, 21.62)
Change in physical activity
Exercise (EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (SMD = 0.62; 95% CI: 0.20, 1.03)
Exercise (endurance; EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = 16.3; 95% CI: 4.8, 28.5)
Change in dietary or nutrient intake
Fat intake (calories from fat) (EoI) | 2 | Insufficient | Significant effect in favor of lifestyle intervention (MD = −16.80 [−20.29, −13.31]
F&V intake (EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = 1.4; 95% CI: 0.75, 2.05)
Mixed breast and prostate cancer
Change in body composition
BMI (EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = −0.10; 95% CI: 1.68, 1.48)
BMI (followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = −0.50; 95% CI: −2.13, 1.13)
Change in physical activity
Exercise (EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (SMD = 0.31; 95% CI: 0, 0.61)
Exercise (followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (SMD = 0.13; 95% CI: −0.18, 0.44)
Change in dietary or nutrient intake
F&V intake (EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = 0.4; 95% CI: −0.21, 1.01)
F&V intake (followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = −0.10; 95% CI: −0.75, 0.55)
Fat intake (calories from fat) (EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = −0.30 [−2.41, 1.81]
Fat intake calories from fat) (followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = −0.50 [−2.70, 1.70]

BMI = body mass index; CI = confidence interval; EoI = end of intervention; F&V = fruit and vegetable; HDL = high density lipoprotein; LDL = low density lipoprotein; MD = mean difference; PSA = prostate specific antigen; RCT = randomized controlled trial; RR = risk ratio

### KQ 2 What is the generalizability of the evidence to the Medicare population (> 65 years)?

Type 2 diabetes. The trials included a wide range of patients including varying comorbidities and nationalities. The mean ages from the 10 trials ranged from 53 to 62 years and included participants up to 75 years old. The majority of these addressed our secondary outcomes, thus we believe that the results for our secondary outcomes should be generalizable to individuals aged 65 years or older.

Two trials excluded patients over the age of 65 years, including the only study that provided data for our primary outcomes. Therefore, we are uncertain whether the results for our primary outcomes (progression of diabetes, progression to micro- or macrovascular complications) are generalizable to the Medicare population.

Metabolic syndrome. The mean ages from the seven trials ranged from 44 to 58 years and included participants up to 85 years of age. Two trials excluded patients over the age of 65 years, including studies that provided data for our primary outcomes. Therefore, we are uncertain whether the results for our primary outcomes (progression to diabetes or cardiovascular events) are generalizable to the Medicare population. For our secondary outcomes, we believe that the results should be generalizable to individuals aged 65 or older.

Breast and prostate cancer. The mean age of participants in the three trials ranged from 65 to 75 years. Therefore, the results from these studies should be generalizable to the Medicare population.

### KQ 3 What is the evidence on what components of the interventions, composition of the team, and/or patient characteristics contribute to better outcomes?

We were unable to address this question due to insufficient data.

## Limitations of the Existing Evidence

The strength of the evidence was low or insufficient for the majority of outcomes across the various interventions and conditions. These low grades were driven by a high or unclear risk of bias within individual studies, lack of direct evidence for patient-important outcomes, and lack of consistency and precision among studies.

Although the studies providing data for this report were RCTs, all had a high or unclear risk of bias as assessed using an empirically derived tool for assessing risk of bias developed by The Cochrane Collaboration. Most of the RCTs were rated as having adequately generated the allocation sequence (70 percent); however, less than half adequately concealed allocation (40 percent). Measures to ensure that allocation occurs without foreknowledge of treatment assignments can always be undertaken by study investigators and should be routinely employed in order to avoid selection bias. Blinding of study investigators and participants was mostly unclear (65 percent). Inadequate blinding can lead to exaggerated treatment effects. Blinding of patients may not be feasible when the intervention is a “lifestyle intervention;” however, blinding of patients to the hypothesis, implementing an active intervention for the control groups, and blinding of outcome assessors may reduce the impact of nonblinding of patients, in particular for patient-reported outcomes. Incomplete outcome data was a problem in half of the trials due to loss to followup and inadequate handling of missing data in the reporting and/or analysis. This may exaggerate treatment effects.

Few trials provided data for clinically-important outcomes and we had to rely on surrogate measures to assess the impact of lifestyle interventions on our primary outcomes. Lack of consistency and precision of results across studies also contributed to the low strength of evidence rating for the majority of outcomes. Consistency was often unknown due to the few studies assessing the same outcome at the same timepoint. Precision was often poor due to the small sample sizes in many of the studies, which may have resulted in insufficient power to detect clinically-important differences. Both consistency and precision may have been affected by variations in the clinical populations assessed across the studies, such as the number, type and severity of comorbidities, and composition, intensity and duration of the lifestyle interventions.

Providing long-term data for studies comparing an active treatment with an active control may not be feasible. As such, a systematic review including observational studies might be beneficial in providing data on patients using different interventions over several years to determine the comparative benefits these interventions.

In addition to the methodological issues identified above, there are limitations that need to be discussed regarding systematic reviews. There is a possibility of publication bias in this systematic review. Since we did not include conference proceedings, unpublished literature, or non-English language publications, we may have missed some studies, and therefore may be overestimating the therapeutic benefit of the lifestyle interventions. Nonetheless, we conducted a comprehensive and systematic search of the published literature that was supplemented by reviewing reference lists of included studies and contacting authors. Despite these efforts, we recognize that we may have missed some trials. There is also the possibility of study selection bias. However, we employed at least two independent reviewers and feel confident that the studies that were excluded from this report were done so for consistent and appropriate reasons.

## Future Research

The following general recommendations for future research are based on the preceding discussion regarding the limitations of the current evidence:

- RCTs should be designed and conducted to minimize risk of bias where at all possible. Authors may find tools such as the CONSORT statement helpful in designing and reporting on RCTs.
- Future RCTs should seek to minimize risk of bias by blinding outcome assessors, implementing an active intervention for control groups, adequately concealing allocation, and handling and reporting missing data appropriately.
- Information regarding the benefit of individual components of lifestyle interventions is needed. Determination of the benefit of individual components would allow for standardization of these interventions in the literature, improve reporting, and facilitate comparisons across populations.
- Consensus on clinically- and patient-important outcomes and outcome measures is needed to ensure consistency and comparability across future studies. Moreover, consensus on minimal clinically important differences is needed to guide study design and interpretation of results.
- RCTs that are adequately powered to detect differences in cardiovascular mortality and morbidity in patients at risk for type 2 diabetes are needed.
- A systematic review of the literature, including observational studies, may provide data on the impact of different lifestyle interventions over several years in order to assess the long-term sustainability and comparative effectiveness of these interventions.
- Given that many chronic disease guidelines now recommend healthy dietary and exercise behaviors, RCTs that are designed to assess components that may improve adherence to guidelines would be beneficial.
- Specifically, research to assess which delivery settings are effective in promoting behavioral change would assist in the delivery of these interventions (i.e., primary care level vs. population-based initiatives).

## Conclusions

Overall, comprehensive lifestyle interventions that include exercise, dietary changes, and at least one other component are effective in decreasing the incidence of type 2 diabetes mellitus in high risk patients and the benefit extends beyond the active intervention phase. While the interventions have a positive impact on a number of risk factors for cardiovascular disease, the impact on cardiovascular outcomes is less clear. Further trials that are adequately powered to determine cardiovascular outcomes are required.

In patients who have already been diagnosed with type 2 diabetes, evidence for benefit of comprehensive lifestyle interventions on patient-oriented outcomes is less clear. There is some evidence to suggest long-term benefit on microvascular and macrovascular outcomes, although the evidence is from one trial of high risk diabetic patients and medication was included as part of the active intervention group. One large RCT is currently ongoing in an attempt to address this issue.

The body of evidence looking at lifestyle interventions to prevent cancer recurrence is limited. We found only one RCT that attempted to address this question, however, the clinical significance of their findings is unclear.

Comprehensive lifestyle interventions appear to have a positive impact on behavioral outcomes including exercise and dietary intake, as well as a number of metabolic variables, at least in the short-term in all populations addressed in this report.

No firm conclusions can be drawn from the available evidence on which interventional strategy would be most successful in inducing and maintaining behavioral change or improving patient-oriented outcomes. In addition, it remains unclear whether comprehensive lifestyle interventions as defined by diet, exercise, and at least one other intervention are superior to diet and exercise alone.