# Peer Reviewers

We wish to acknowledge individuals listed below for their review of this report. This report has been reviewed in draft form by individuals chosen for their expertise and diverse perspectives. The purpose of the review was to provide candid, objective, and critical comments for consideration by the EPC in preparation of the final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

- Frank Hu
  Professor of Nutrition and Epidemiology
  Harvard School of Public Health
  Boston, MA
- Jun Ma
  Associate Investigator/Scientist
  Palo Alto Medical Foundation Research Institute
  Palo Alto, CA
- Didac Mauricio
  Department of Endocrinology & Nutrition, Hospital Arnau de Vilanova, University of Lleida
  Lleida, Spain
- Sandra A. Norman
  Research Associate Professor (Retired)
  University of Pennsylvania School of Medicine
  Philadelphia, PA