# Acknowledgments

The authors wish to thank members of the RENEW study team for providing additional information about the RENEW trial: M. C. Morey, D. C. Snyder, R. Sloane, H. J. Cohen, B. Peterson, T. J. Hartman, P. Miller, D. C. Mitchell, and W. Demark-Wahnefried (Principal Investigator).

We thank Carol Spooner for her work in conducting the preliminary literature scan and topic refinement, Amy Beaith and Tamara Durec for conducting the literature searches, and Teodora Radisic for her assistance with literature retrieval