# Discussion

## Type 2 Diabetes Mellitus

Ten RCTs met our inclusion criteria for assessing the effectiveness of lifestyle interventions in patients with type 2 diabetes. Two of the trials reported results for one of our primary outcomes of progression to microvascular or macrovascular complications. See Table 10 for a summary of the findings and Appendix E for GRADE assessments.

Table 10 Summary table: type 2 diabetes

Outcome | # RCTs | Strength of evidence | Summary
Primary outcomes
All-cause mortality (13 yr followup) | 1 | Low | Significant effect in favor of lifestyle intervention (RR_meds_ = 0.60; 95% CI: 0.4, 0.9)
Cumulative incidence of CVD events (13 yr followup) | 1 | Low | Significant effect in favor of lifestyle intervention (RR_meds_ = 0.49; 95% CI: 0.34, 0.71)
Autonomic neuropathy progression (13 yr followup) | 1 | Low | Significant effect in favor of lifestyle intervention (RR_meds_ = 0.75; 95% CI: 0.57, 0.99)
Development of nephropathy (13 yr followup) | 1 | Low | Significant effect in favor of lifestyle intervention (RR_meds_ = 0.54; 95% CI: 035, 0.85)
Development of retinopathy (13 yr followup) | 1 | Low | Significant effect in favor of lifestyle intervention (RR_meds_ = 0.76; 95% CI: 0.58, 0.99)
Peripheral neuropathy progression (13 yr followup) | 1 | Low | No significant difference between groups (RR_meds_ = 0.96; 95% CI: 0.73, 1.26)
Change in body composition
BMI (EoI) | 5 | Moderate | Significant effect in favor of lifestyle intervention (MD_all_ = −0.48; 95% CI: −0.92, −0.05)
BMI (6 mo postintervention) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD_meds_ = 1.0; 95%CI: −1.84, 3.84)
BMI (13 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD_meds_ = −1.1; 95% CI: −3.14, 0.94)
Weight change (EoI) | 5 | Moderate | No significant difference between groups (MD_no meds_ = −1.53; 95% CI: −2.09, −0.97; MD_meds_ = −15.4; 95% CI: −16.1, −14.5)
Weight change (6 mo postintervention) | 1 | Insufficient | Effect favors usual care, though not significantly (RR_meds_ = 1.14; 95% CI: −5.39, 7.67)
Weight change (4 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD_meds_ = −11.62; 95% CI: −12.37, −10.87)
Metabolic variables
Fasting plasma glucose (EoI) | 4 | Low | Significant effect in favor of lifestyle intervention (MD_no meds_ = −0.33; 95% CI: −0.83, 1.49; MD_meds_ = −1.02; 95% CI: −1.85, −0.19)
Fasting plasma glucose (6 mo postintervention) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD_meds_ = −1.0; 95% CI: −2.61, 0.61)
Fasting plasma glucose (13 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD_meds_= −0.16; 95% CI: −1.47, 1.15)
HbA1c (EoI) | 10 | Low | Significant effect in favor of lifestyle intervention (MD_no meds_ = −0.09; 95% CI: −0.58, 0.75; MD_meds_ = 0.77; 95% CI: −1.18, −0.36)
HbA1c (6 mo postintervention) | 2 | Insufficient | No significant difference between groups (MD_all_ = 0.09; 95% CI: −0.58, 0.75)
HbA1c (13 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD_meds_ = −0.70; 95% CI: −1.41, 0.01)
HDL cholesterol (EoI) | 6 | Low | Significant effect in favor of lifestyle intervention (MD_no meds_ = −0.01; 95% CI: −0.04, 0.05; MD_meds_ = 0.05; 95% CI: 0.03, 0.07)
HDL cholesterol (6 mo postintervention) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD _no meds_ = −0.04; 95% CI: −0.16, 0.09)
HDL cholesterol (13 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD_meds_ = 0.08; 95% CI: −0.07, 0.22)
LDL cholesterol (EoI) | 5 | Low | No significant difference between groups (MD_no meds_ = −0.09; 95% CI: −0.26, 0.08; MD_meds_ = −0.27; 95% CI: −0.92, 0.37)
LDL cholesterol (6 mo postintervention) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD_meds_ = −0.59; 95% CI: −1.07, −0.11)
LDL cholesterol (13 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD_meds_= −0.05; 95% CI: −0.4, 0.3)
Total cholesterol (EoI) | 5 | Low | No significant difference between groups (MD_all_ = −0.13; 95% CI: −0.27, 0.01),
Total cholesterol (6 mo postintervention) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD _no meds_ = 0.01; 95% CI: −0.35, 0.36)
Total cholesterol (13 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD_meds_ = 0.38; 95% CI: −0.06, 0.82)
Triglycerides (EoI) | 5 | Low | Significant effect in favor of lifestyle intervention (MD_all_ = −0.17; 95% CI: −0.23, −0.12)
Triglycerides (6 mo postintervention) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD_meds_ = −0.18; 95% CI: −1.47, 1.11)
Triglycerides (13 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD_meds_ = −0.03; 95% CI: −0.67, 0.61)
Blood pressure
Diastolic BP (EoI) | 6 | Low | No significant difference between groups (MD_no meds_ = 0.32; 95% CI: −1.43, 20.7; MD_meds_ = −1.2; 95% CI: −1.75, 0.65)
Diastolic BP (6 mo postintervention) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD_meds_ = 0; 95% CI: −5.07, 5.07)
Diastolic BP (13 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD_meds_ = 2.0; 95% CI: −1.90, 5.90)
Systolic BP (EoI) | 6 | Low | No significant difference between groups (MD_no meds_ = −1.89; 95% CI: −0.57, 4.35; MD_meds_ −6.89; 95% CI: −14.42, 0.64)
Systolic BP (6 mo postintervention) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD_meds_ = −3.0; 95% CI: −12.4, 6.4)
Systolic BP (13 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD_meds_ = −3.0; 95% CI: −9.79, 3.79)
Change in physical activity
Exercise (EoI) | 6 | Low | Significant effect in favor of lifestyle intervention (SMD_all_ = 0.45; 95% CI: 0.2, 0.71)
Exercise (6 mo postintervention) | 4 | Low | Significant effect in favor of lifestyle intervention (SMD_all_ = 0.5; 95% CI: 0.1, 0.89)
Exercise (2 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (SMD _no meds_ = 0.41; 95% CI: 0.16, 0.67)
Exercise (8 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (SMD_meds_ = 0.11; 95% CI: −0.24, 0.45)
Change in dietary or nutrient intake
Energy intake (EoI) | 5 | Low | Significant effect in favor of lifestyle intervention (SMD_all_ = −0.17; 95% CI: −0.33, −0.01)
Energy intake (6 mo postintervention) | 1 | Insufficient | The evidence was too limited to draw a conclusion (SMD_meds_ = −0.12; 95% CI: −0.59, 0.36)
Energy intake (8 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (SMD_meds_ = 0; 95% CI: −0.35, 0.34)
SFA intake (EoI) | 5 | Low | No significant difference between groups (SMD_all_ = −0.31; 95% CI: −0.68, 0.07)
SFA intake (6 mo postintervention | 2 | Insufficient | Significant effect in favor of lifestyle intervention (SMD_all_ = −0.45 95% CI: −0.79, −0.10)
SFA intake (8 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (SMD_meds_ = −0.68; 95% CI: −1.03, −0.32)

BMI = body mass index; BP = blood pressure; CI = confidence interval; CVD = cardiovascular disease; EoI = end of intervention; HbA1c = glycosylated haemoglobin; HDL = high density lipoprotein; LDL = low density lipoprotein; MD = mean difference; mo = month(s); RCT = randomized controlled trial; RR = risk ratio; SFA = saturated fatty acid; SMD = standardized mean difference; yr = year(s)

The Steno-2 trial,119 which looked at multifactorial, intensive treatment of diabetic patients with microalbuminuria was designed with a primary outcome of nephropathy and secondary endpoints of retinopathy and neuropathy. At 4 years, significant improvement in microvascular outcomes including nephropathy, retinopathy, and autonomic neuropathy was observed. These findings were maintained over 13 years. Eight years following initiation of the intervention, the authors reported a statistically significant reduction in cardiovascular events, primarily from a reduction in non-fatal MIs, in the treatment group. The reported number needed to treat (NNT) was five. The strength of evidence is low.

Despite intensive lifestyle interventions and improvement in cardiovascular outcomes, the trial did not maintain significant changes in most lifestyle behaviors at 8 or 13 years. In addition, while benefit was initially seen for a number of cardiovascular risk factors, this was not maintained. The majority of patients also did not achieve target levels. Nonetheless, at 13 years, statistically significant decreases in total mortality, cardiovascular mortality, and composite cardiovascular endpoints were reported in the intensive treatment group (38 percent, 54 percent, and 60 percent, respectively).188 These are arguably the most patient-important outcomes. The strength of evidence is low.

The mechanism by which benefit occurs despite normalization of cardiac risk factors and limited behavioral change is not entirely clear. Trials in type 1 diabetes have demonstrated that early intensive treatment results in an extended benefit in delaying the progression of diabetic outcomes beyond the intervention.189,190 It is important to note however that this trial included medication use as part of its intensive treatment arm which may have overestimated the benefits of lifestyle intervention.

The Look AHEAD trial112 also addressed our primary outcome and was designed to assess cardiovascular morbidity and mortality in type 2 diabetes. At 4 years, significant improvements were reported in a number of cardiovascular risk factors with intensive lifestyle intervention and these results are similar to those in the majority of trials included in this review.

Across the trials, methods of reporting of changes in weight were not consistent. While some reported weight change, others reported change in BMI. The Look AHEAD trial reported weight change as a percentage of initial weight. Despite these differences, results were consistent. The pooled mean difference (MD) of each measurement (weight change and BMI) was statistically significant in favor of lifestyle intervention. Similarly, the Look AHEAD trial found a statistically significant change in weight in the intervention group after 1 year and after 4 years of intervention.191 However, the Look AHEAD trial also employed medication directly targeted for weight loss in those who failed to lose 10 percent of their initial weight. Given that many patients with diabetes require insulin therapy, which is usually associated with weight increases,192 maintenance of stable weight is a positive outcome. It is notable that those interventions that included pharmacotherapy not specifically targeted to weight loss as part of the lifestyle intervention113,119 were unable to demonstrate significant weight loss. However, as exercise was a component of all interventions, it is also possible that change in body composition may have affected the amount of weight lost. It is noteworthy that none of the trials found that the change in weight persisted following the end of the intervention. This is consistent with previous research suggesting that diabetic patients demonstrate poor weight loss maintenance following an intervention compared with their non-diabetic counterparts.193

All studies reported a number of metabolic variables. Sensitivity analyses demonstrated improvement in some metabolic outcomes including HDL and glycemic control in those interventions that included targeted pharmacotherapy; however, no statistical improvement in any metabolic variable was noted for those interventions that did not include pharmacotherapy.. In trials that did not include medication as part of the intervention, the impact of diet and lifestyle alone is difficult to tease out as the control groups in many trials received at minimum the “standard of care,” which includes pharmacotherapy.

Lifestyle interventions appear to be beneficial in increasing physical activity levels in the short term, and in a number of trials this benefit persisted beyond the initial intervention. The Steno-2 trial was the only trial reporting no change in activity at followup even though it reported improvements in cardiovascular outcomes. The interventions and methods of reporting physical activity levels were heterogeneous across studies and many were subject to possible reporting bias. The Look AHEAD trial reported change in fitness as opposed to physical activity levels as an outcome and found that it was significantly improved in the intervention group after 1 year. Other trials such as the one by Vanninen et al.117 reported both changes in physical activity and aerobic capacity. While not analyzed in this review, reporting of fitness levels may help offset the potential bias of personal reporting of physical activity levels.

The impact of lifestyle interventions on dietary intake is not as clear, and also may be subject to reporting bias. Energy intake seems to decrease in the short term, although this improvement does not appear to be sustained beyond the intervention.

Changes in medication potentially reflect overall diabetic control, with increases in the numbers of oral hypoglycemic agents (OHAs) or progression to insulin representing worsening control. However, it is also possible that increased medications may simply reflect an intensive intervention that aims for stricter control of certain diabetic indices. Only two trials113,119 reported medication use, and at the end of both interventions, no significant difference was noted in OHAs or insulin.

A number of trials have demonstrated benefit with single risk factor interventions, such as those to improve blood pressure, lipids, or glycemic control, or to reduce both macrovascular and microvascular complications in type 2 diabetes.41,46,194–196 Pharmacotherapy, exercise, and dietary changes have all been shown to have a positive impact on glycemic control and other diabetic indices,197,198 and there is growing evidence for an additive effect when multiple risk factors are addressed together.199 Few studies have evaluated the impact of diet and exercise plus at least one other intervention.

The Steno-2 trial is the only completed trial to report on the progression to type 2 diabetic outcomes. Unfortunately the sample size was small, and the trial was assessed as having an unclear risk of bias. It does, however, underscore the probability of additional, long-term benefits of a multifactorial intervention in improving patient oriented outcomes in high risk diabetic patients. These results have not been replicated, thus the results of the Look AHEAD trial will be important in validating these findings. It is important to note, however, that targeted pharmacotherapy is part of the lifestyle intervention for both trials.

There remain a number of questions regarding which lifestyle interventions are most effective. None of the trials included in this review were designed to assess this. Improvement in secondary outcomes was seen in trials that utilized more intensive interventions,113,114 and those that employed brief interventions.110 In addition, while statistical improvement was seen for some secondary outcomes, the clinical significance of this is unclear. There was considerable variability among the studies with regard to the dietary and lifestyle interventions. There is currently no consensus on optimal behavioral regimens. In addition, it remains unclear which interventions are sustainable over the long term. There was limited success in the achievement of permanent lifestyle changes. Long-term change is dependent on a number of factors including patient motivation and compliance. In our review we measured compliance by the number of withdrawals. Overall, there were more withdrawals in the lifestyle group, although this was not statistically significant. A true measure of compliance with lifestyle intervention is complex, particularly when a number of trials rely on self-reported data. One of the central objectives of therapeutic lifestyle interventions is to modify and shape healthy lifestyle behaviors over the long term. Improved measurement and reporting of this outcome would be beneficial for the development of future interventions.

## Metabolic Syndrome

Seven studies met our inclusion criteria for our operational definition of metabolic syndrome. See Table 11 for a summary of the findings and Appendix E for GRADE assessments.

Table 11 Summary table: metabolic syndrome

Outcome | # RCTs | Strength of evidence | Precision
Primary outcomes
CVD events (Followup: 6–10 yr) | 2 | Insufficient | The evidence was too limited to draw a conclusion (RR = 1.02; 95% CI: 0.73, 1.42) (HR = 0.96; 95% CI: 0.76–1.44)
CVD events (20 yr) | 1 | Insufficient | No significant difference between groups (HR = 0.98; 95% CI: 0.71–1.37)
Development of type 2 diabetes (EoI: duration 1–6 yr) | 3 | Moderate | Significant effect in favor of lifestyle intervention (RR = 0.44; 95% CI: 0.2, 0.93)
Development of type 2 diabetes (Followup: 4–10 yr) | 3 | Moderate | Significant effect in favor of lifestyle intervention (RR_4 yr_ = 0.56; 95% CI: 0.48, 0.64; RR_6 yr_ = 0.44; 95% CI: 0.29, 0.68)
Death (Followup: 10–20 yr) | 2 | Insufficient | The evidence was too limited to draw a conclusion (RR_10 yr_ = 0.58; 95% CI: 0.21, 1.57; HR_20 yr_ = 0.83; 95% CI: 0.48, 1.40)
Body Composition
BMI (EoI) | 4 | Moderate | Significant effect in favor of lifestyle intervention (MD = −0.95; 95% CI: −1.49, −0.41)
BMI (4 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = −0.92; 95% CI: −1.32, −0.53)
Waist circumference (EoI) | 5 | Moderate | Significant effect in favor of lifestyle intervention (MD = −3.73; 95% CI: −4.87, −2.59)
Waist circumference (4 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD= −1.86; 95% CI: −3.49, −0.22)
Weight change (EoI) | 6 | Moderate | Significant effect in favor of lifestyle intervention (MD = −7.8; 95% CI: −11.92, −3.67)
Weight change ( 4 yr followup) | 2 | Low | The evidence was too limited to draw a conclusion (MD = −5.88; 95% CI: −8.05, −3.71)
Weight change (10 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = −0.94; 95% CI: −5.07, 3.19)
Metabolic variables
Fasting plasma glucose (EoI) | 5 | Moderate | Significant effect in favor of lifestyle intervention (MD = −0.29; 95% CI: −0.35, −0.23)
Fasting plasma glucose (10 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = 0.10; 95% CI: 0.03, 0.18)
HbA1c (EoI) | 2 | Insufficient | No significant difference between groups (MD = −0.10; 95% CI: −0.28, 0.08)
HbA1c (10 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = −0.05; 95% CI: −0.09, −0.02)
HDL cholesterol (EoI) | 4 | Moderate | Significant effect in favor of lifestyle intervention (MD = 0.08; 95% CI: 0.05, 0.10)
HDL cholesterol (4 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = 0.05; 95% CI: 0.0, 0.10)
Impaired plasma glucose (EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = 0.34; 95% CI: 0.23, 0.52)
LDL cholesterol (EoI) | 3 | Low | No significant difference between groups (MD = 0.04; 95% CI: −0.16, 0.25)
Total cholesterol (EoI) | 5 | Low | No significant difference between groups (MD = 0.0; 95% CI: −0.12, 0.13)
Triglycerides (EoI) | 4 | Low | No significant difference between groups (MD = −0.11; 95% CI: −0.26, 0.04)
Triglycerides (4 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = 0.09; 95% CI: −0.22, 0.05)
Blood pressure
Diastolic BP (EoI) | 5 | Moderate | Significant effect in favor of lifestyle intervention (MD=−2.70; 95% CI: −3.21, −2.18)
Diastolic BP (4 yr followup) | 2 | Low | The evidence was too limited to draw a conclusion (MD =−1.88; 95% CI: −2.65, −1.12)
Systolic BP (EoI) | 5 | Moderate | Significant effect in favor of lifestyle intervention (MD =−3.17; 95% CI: −5.02, −1.33)
Systolic BP (4 yr followup) | 2 | Low | The evidence was too limited to draw a conclusion (MD =−4.41; 95% CI: −8.47, −0.35)
Change in physical activity
Exercise (EoI) | 4 | Moderate | Significant effect in favor of lifestyle intervention (SMD = 0.40; 95% CI: 0.2, 0.59)
Exercise (4 yr followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (SMD = 0.23; 95% CI: 0.10, 0.35)
Change in dietary or nutrient intake
Energy intake (EoI) | 4 | Moderate | Significant effect in favor of lifestyle intervention (SMD = −0.23; 95% CI: −0.31, −0.16)
SFA intake (EoI) | 2 | Low | Significant effect in favor of lifestyle intervention (SMD = −0.53; 95% CI: −0.73, −0.34)

BMI = body mass index; BP = blood pressure; CI = confidence interval; CVD = cardiovascular disease; EoI = end of intervention; HbA1c = glycosylated haemoglobin; HDL = high density lipoprotein; HR = hazard ratio; LDL = low density lipoprotein; MD = mean difference; mo = month(s); RCT = randomized controlled trial; RR = risk ratio; SFA = saturated fatty acid; SMD = standardized mean difference; yr = year(s)

Four trials looked at progression to type 2 diabetes (DPP,122,166 FDPS,123 Da Qing,126 Bo et al.125), and all reported a significant reduction in the development of type 2 diabetes with comprehensive lifestyle intervention at timepoints ranging from 1 year to 10 years following the initiation of the intervention. Bo et al. reported a NNT of 19 to prevent one patient progressing to diabetes; the DPP reported a NNT of 7 over 3 years; and the FDPS reported a NNT of five over 4 years. The strength of evidence is moderate. Interestingly, the DPP found that lifestyle interventions were more effective than metformin in preventing the onset of type 2 diabetes during the active intervention phase. Since a diagnosis of diabetes is associated with a significant increase in cardiovascular risk, this is an important outcome. These findings are consistent with those of other reviews that have reported significant benefit of lifestyle intervention in the prevention of type 2 diabetes.200,201

There were some differences in the baseline characteristics of the different study populations. Some trials included patients with impaired glucose tolerance (DPP) while others assessed patients with a predefined “dysmetabolic syndrome” (Bo et al.), although all are at increased risk of developing diabetes.

Two trials reported on cardiovascular outcomes and overall mortality and neither found a statistically significant difference between lifestyle interventions and usual care following the initial intervention period nor at followup over 10 (DPS) to 20 years (Da Qing). The result contrasts with the Steno-2 trial which demonstrated long-term benefit on clinical outcomes with lifestyle intervention; however, the Steno 2 trial assessed high risk diabetic patients (with microalbuminuria), whereas the DPS and Da Qing trials included those who had not yet been diagnosed with diabetes and were at lower risk for macrovascular complications. As a result, the statistical power may not have been sufficient to detect a difference. In addition, the Steno 2 utilized intensive pharmacotherapy in the intervention group. The strength of evidence for the impact of lifestyle interventions on cardiovascular disease and mortality is insufficient.

The Diabetes Prevention Program Outcomes Study,166 which involves long-term followup of patients in the Diabetes Prevention Program, has reported plans for further followup in 2014. Perhaps this will shed further light on whether prevention or delay of diabetes is associated with a delay in development of diabetic complications. In view of the strong relationship between hyperglycemia and long-term diabetes complications, the hypothesis that preventing or delaying the onset of diabetes would also prevent or delay macrovascular and microvascular complications seems reasonable.

Similar to the results for type 2 diabetic patients, lifestyle interventions in patients with metabolic syndrome and/or prediabetes resulted in a significant decrease in body weight, BMI, or percentage of body weight. In contrast to the findings in patients with type 2 diabetes, this effect persisted for up to 4 years beyond the intervention period. It is unclear if the weight loss is easier to maintain in those who have not yet progressed to diabetes. If this were the case, it would underscore the importance of identifying those at risk of developing diabetes and intervening early.

Lifestyle interventions also improve cardiovascular risk factors more than usual care, although the differences were not always statistically significant. Changes in physical activity and diet were also found to be improved with comprehensive lifestyle interventions.

While lifestyle interventions have demonstrated benefit in patients at risk for developing diabetes, the implementation of lifestyle interventions faces a number of barriers. The DPP, for example, was very time and resource intensive and could be difficult to implement on a large population basis.202 The intervention by Bo et al. was intentionally less intensive, and yet maintained a significant reduction in the progression to diabetes in the intervention group.

Patient adherence is another barrier to successful implementation of lifestyle changes. Overall, there was no statistically significant difference in dropout rates between the groups in this review. Because much of the measurement in lifestyle interventions relies on self-reported data, true measures of compliance are difficult to obtain. Bo et al. reported a weak positive correlation between the number of metabolic syndrome components at baseline and patient compliance: the average number of sessions attended increased from 4.1 for those with two components to 4.5 for those with four or more components (p for trend test = 0.28).

There was also significant variability associated with program composition and administration. In particular, the third component of the intervention was variable, limiting our ability to comment on which additional interventions would be beneficial. It is difficult to determine if diet, exercise, and at least one other component had a benefit over diet and exercise alone. Systematic reviews that have assessed diet and exercise included a number of trials that overlap with our review.201 We considered interventions such as smoking cessation, stress reduction, group therapy, and behavior modification as separate components, whereas other reviews may have viewed them as part of the diet and exercise intervention.

## Prostate and Breast Cancer

Three RCTs examined the impact of comprehensive lifestyle interventions on prostate and breast cancer recurrence. Two assessed both breast and prostate cancer and one assessed prostate cancer alone. See Table 12 for a summary of the findings and Appendix E for GRADE assessments.

Table 12 Summary table: breast and prostate cancer

Outcome | # RCTs | Strength of evidence | Precision
Breast cancer
Change in body composition
BMI (EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = −0.31; 95% CI: −1.19, 0.57)
Weight (EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = −3.9; 95% CI: −10.32, 2.52)
Change in physical activity
Exercise (endurance; EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = 25.6; 95% CI: 16.9, 34.8)
Change in dietary or nutrient intake
F&V intake (EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = 1.08; 95% CI: 0.5, 1.66)
Fat intake (calories from fat) (EoI) | 1 | Insufficient | Significant effect in favor of lifestyle intervention (MD = −1.76; −2.57, −0.95)
Prostate cancer
Primary outcome
PSA levels (EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = −0.63; 95% CI: −1.16, −0.10)
Change in body composition
BMI (EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = −0.61; 95% CI: −1.47, 0.25)
Weight (EoI) | 2 | Insufficient | Significant effect in favor of lifestyle intervention (MD = −7.55; 95% CI: −13.05, −2.05)
Change in metabolic variables
HDL cholesterol (EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = −6.4; 95% CI: −9.65, −3.15)
LDL cholesterol (EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = −28.6; 95% CI: −40.79, −16.41)
Total cholesterol (EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = −34.0; 95% CI: −48.30, −19.7)
Triglycerides (EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD= −9.0; 95% CI: −39.62, 21.62)
Change in physical activity
Exercise (EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (SMD = 0.62; 95% CI: 0.20, 1.03)
Exercise (endurance; EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = 16.3; 95% CI: 4.8, 28.5)
Change in dietary or nutrient intake
Fat intake (calories from fat) (EoI) | 2 | Insufficient | Significant effect in favor of lifestyle intervention (MD = −16.80 [−20.29, −13.31]
F&V intake (EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = 1.4; 95% CI: 0.75, 2.05)
Mixed breast and prostate cancer
Change in body composition
BMI (EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = −0.10; 95% CI: 1.68, 1.48)
BMI (followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = −0.50; 95% CI: −2.13, 1.13)
Change in physical activity
Exercise (EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (SMD = 0.31; 95% CI: 0, 0.61)
Exercise (followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (SMD = 0.13; 95% CI: −0.18, 0.44)
Change in dietary or nutrient intake
F&V intake (EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = 0.4; 95% CI: −0.21, 1.01)
F&V intake (followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = −0.10; 95% CI: −0.75, 0.55)
Fat intake (calories from fat) (EoI) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = −0.30; 95% CI: −2.41, 1.81)
Fat intake calories from fat) (followup) | 1 | Insufficient | The evidence was too limited to draw a conclusion (MD = −0.50; 95% CI: −2.70, 1.70)

BMI = body mass index; CI = confidence interval; EoI = end of intervention; F&V = fruit and vegetable; HDL = high density lipoprotein; LDL = low density lipoprotein; MD = mean difference; PSA = prostate specific antigen; RCT = randomized controlled trial; RR = risk ratio

The trial by Ornish et al. was the only study that addressed our primary outcome—recurrence or progression of cancer. The trial reports a modest statistically significant decrease in PSA in the lifestyle intervention group; however, this result should be interpreted with caution as there were methodological limitations and the trial was assessed at high risk of bias. Furthermore, the clinical significance of this outcome is unclear. The natural variability of PSA assays has been previously recognized, with a coefficient of variation (CV) between 10 and 15 percent as reported in prospective studies.203,204 A recent systematic review of 12 studies reported a mean CV of 20 percent.205 There is evidence that PSA increases at a faster rate in men with prostate cancer and that PSA kinetics may enable better selection of men for further investigation.206 In addition, PSA is currently used to measure treatment effect for most cancer treatments. However, there is currently no evidence that directly correlates increased PSA with progression of, or survival following prostate cancer. Indeed PSA can actually decrease and normalize in men with clinically significant prostate cancer.207,208 Ultimately, progression of cancer and survival are the patient-oriented outcomes that we are seeking to improve. The strength of evidence is insufficient.

Similarly for breast cancer, there is insufficient evidence to draw conclusions regarding the impact of comprehensive lifestyle interventions in preventing recurrence.

Practically, recurrence of cancer is a difficult question to address, given the potentially long followup that would be required to obtain sufficient numbers for recurrence. Reported 5-year cure rates for localized breast and prostate cancer are 98 and nearly 100 percent, respectively.209 Direct benefit of any intervention on long-term survivorship will be difficult to demonstrate. There is some evidence, albeit weak, that body composition, physical activity, and dietary intake may affect cancer recurrence.80–88

There is a large body of evidence regarding lifestyle factors on prevention of incident cancers, with most focusing on the impact of obesity and physical activity on the development of cancer.16–20,79 While it may not be appropriate to extrapolate evidence regarding incident cancers to recurrence, it seems plausible that factors that contributed to the incident cancer would also contribute to its recurrence.

Overall, the included trials demonstrated that comprehensive lifestyle interventions were successful in modifying behaviors in cancer survivors. Changes in physical activity, fruit and vegetable intake, and decreased fat intake127,128 were observed in both breast and prostate cancer groups.

The assessment of the impact of lifestyle intervention on behavior is complex. Lifestyle interventions require active participation by participants. Often adherence to the interventions is based on self-report, which has inherent bias. In addition, those who agree to participate in lifestyle interventions trials are generally more motivated for change, as noted in the study by Demark-Wahnefried et al.129 in which 54 percent of those interested in participating reported exercising regularly, contrasting with research that found that only 25 percent of elderly cancer survivors are physically active.210

As in other chronic diseases, optimal interventions to effect behavioral change in cancer survivors remain an area of controversy. Research on interventions to improve physical activity and diet has been conducted in a number of populations with conflicting results.211–213 A recent systematic review suggested there is insufficient evidence for interventions targeting only single risk factors (i.e., physical activity).214 Other research suggests that interventions targeting multiple risk factors may be beneficial in effecting change.215

Two of the included studies reported weight change. While only one demonstrated a statistically significant decrease in body weight,128 the pooled MD was statistically significant with minimal heterogeneity. No difference was seen in BMI. This discrepancy reflects the variability in current evidence and the need for further research in this area. Studies in other populations have shown that exercise, particularly in combination with dietary change, can result in statistically significant weight loss.216

One trial reported on metabolic variable change following lifestyle intervention and found a significant improvement in all lipids except for triglycerides. The importance of metabolic variables in cancer recurrence is largely unknown. Recent trials looking at statin use for prostate cancer prevention suggest that statin use resulted in decreased PSA recurrence and improved relapse-free survival; however, whether the benefit was from the statin or decreased lipids is unknown.217 Outcomes such as comorbidity, functional decline, and quality of life were not included in this review. While prevention of cancer recurrence would be a laudable goal, research assessing the impact of lifestyle changes on these outcomes may be equally as valuable.

Overall, the strength of body of evidence looking at lifestyle interventions to prevent cancer recurrence is insufficient. Considering the magnitude of these conditions, including both the personal and global impact, it is disappointing that more research has not been completed. Given the potentially long latency period before cancer recurrence, observational studies may be better suited to further delineate the benefits of lifestyle interventions in this population. Research looking at a reduction in the incidence of cancer has been top priority for years. As more people are surviving the incident diagnosis of breast and prostate cancer, investigation of potential interventions to decrease cancer recurrence is becoming of key importance.

## Limitations of the Existing Evidence

The strength of the evidence was low or insufficient for the majority of outcomes across the various interventions and conditions (Appendix E). These low grades were driven by a high or unclear risk of bias within individual studies, lack of direct evidence for patient-important outcomes, and lack of consistency and precision among studies.

Although the studies providing data for this report were RCTs, all had a high or unclear risk of bias as assessed using an empirically derived tool for assessing risk of bias developed by The Cochrane Collaboration. Most of the RCTs were rated as having adequately generated the allocation sequence (70 percent); however, less than half adequately concealed allocation (40 percent). Measures to ensure that allocation occurs without foreknowledge of treatment assignments can always be undertaken by study investigators and should be routinely employed in order to avoid selection bias. Blinding of study investigators and participants was mostly unclear (65 percent). Inadequate blinding can lead to exaggerated treatment effects. Blinding of patients may not be feasible when the intervention is a “lifestyle intervention;” however, blinding of patients to the hypothesis, implementing an active intervention for the control groups, and blinding of outcome assessors may reduce the impact of nonblinding of patients, in particular for patient-reported outcomes. Incomplete outcome data was a problem in half of the trials due to loss to followup and inadequate handling of missing data in the reporting and/or analysis. This may exaggerate treatment effects.

Few trials provided data for clinically-important outcomes, and we had to rely on surrogate measures to assess the impact of lifestyle interventions on our primary outcomes. Lack of consistency and precision of results across studies also contributed to the low strength of evidence rating for the majority of outcomes. Consistency was often unknown due to the few studies assessing the same outcome at the same timepoint. Precision was often poor due to the small sample sizes in many of the studies, which may have resulted in insufficient power to detect clinically-important differences. Both consistency and precision may have been affected by variations in the clinical populations assessed across the studies, such as the number, type and severity of comorbidities, and composition, intensity and duration of the lifestyle interventions.

This review included only RCTs because they are considered the highest level of evidence to evaluate the effectiveness of an intervention. However, providing long-term data for studies comparing an active treatment with an active control may not be feasible. While we identified some trials that had very long periods of followup, we acknowledge that observational studies may also provide long-term data to address the questions included in this review. As such, a systematic review including observational studies might be beneficial in providing data on patients using different interventions over several years to determine the comparative benefits these interventions.

In addition to the methodological issues identified above, there are limitations that need to be discussed regarding systematic reviews. There is a possibility of publication bias in this systematic review. Since we did not include conference proceedings, unpublished literature, or non-English language publications, we may have missed some studies, and therefore may be overestimating the therapeutic benefit of the lifestyle interventions. Nonetheless, we conducted a comprehensive and systematic search of the published literature that was supplemented by reviewing reference lists of included studies and contacting authors. Despite these efforts, we recognize that we may have missed some trials. There is also the possibility of study selection bias; however, we employed at least two independent reviewers and feel confident that the studies that were excluded from this report were done so for consistent and appropriate reasons.

## Future Research

The following general recommendations for future research are based on the preceding discussion regarding the limitations of the current evidence:

- RCTs should be designed and conducted to minimize risk of bias where at all possible. Authors may find tools such as the CONSORT218 statement helpful in designing and reporting on RCTs.
- Future research should seek to minimize risk of bias by blinding outcome assessors, including an active intervention for control groups, adequately concealing allocation, and handling and reporting missing data appropriately.
- Information regarding the benefit of individual components of lifestyle interventions is needed. Determination of the benefit of individual components would allow for standardization of these interventions in the literature, improve reporting, and facilitate comparisons across populations.
- Consensus on clinically- and patient-important outcomes and outcome measures is needed to ensure consistency and comparability across future studies. Moreover, consensus on minimal clinically important differences is needed to guide study design and interpretation of results.
- RCTs that are adequately powered to detect differences in cardiovascular mortality and morbidity in patients at risk for type 2 diabetes are needed.
- A systematic review of the literature, including observational studies, may provide data on the impact of different lifestyle interventions over several years in order to assess the long-term sustainability and comparative effectiveness of these interventions.
- Given that many chronic disease guidelines now recommend healthy dietary and exercise behaviors, RCTs that are designed to assess components that may improve adherence to guidelines would be beneficial.
- Specifically, research to assess which delivery settings are effective in promoting behavioral change would assist in the delivery of these interventions (i.e., primary care level vs. population-based initiatives).

## Conclusions

Overall, comprehensive lifestyle interventions that include exercise, dietary changes, and at least one other component are effective in decreasing the incidence of type 2 diabetes mellitus in high risk patients, and the benefit extends beyond the active intervention phase. While the interventions have a positive impact on a number of risk factors for cardiovascular disease, the impact on cardiovascular outcomes is less clear. Further trials that are adequately powered to determine cardiovascular outcomes are required.

In patients who have already been diagnosed with type 2 diabetes, evidence for benefit of comprehensive lifestyle interventions on patient-oriented outcomes is less clear. There is some evidence to suggest long-term benefit on microvascular and macrovascular outcomes, although the evidence is from one trial of high risk diabetic patients and medication was included as part of the active intervention group. One large RCT is currently ongoing in an attempt to address this issue.

The body of evidence looking at lifestyle interventions to prevent cancer recurrence is limited. We found only one RCT that attempted to address this question; however, the clinical significance of their findings is unclear.

Comprehensive lifestyle interventions appear to have a positive impact on behavioral outcomes including exercise and dietary intake, as well as a number of metabolic variables, at least in the short-term in all populations addressed in this report.

No firm conclusions can be drawn from the available evidence on which interventional strategy would be most successful in inducing and maintaining behavioral change or improving patient-oriented outcomes. In addition, it remains unclear whether comprehensive lifestyle interventions as defined by diet, exercise, and at least one other intervention are superior to diet and exercise alone.