# Results

## Literature Search

From our search of the electronic databases, 1,288 studies were identified (Figure 2). After duplicates were removed, 802 citations remained. We screened all the citations and identified 235 that were potentially relevant. Four studies could not be retrieved through the University of Alberta interlibrary loan system, therefore, the full text of 231 publications were reviewed for potential inclusion into this report. Of these, 20 unique RCTs (reporting data from 80 articles) were included. Ten studies110–119 addressed type 2 diabetes, seven addressed metabolic syndrome,120–126 and three addressed prostate and/or breast cancer.127–129

Figure 2 Flow diagram of study retrieval and selection

“Figure 2 is a flow chart that summarizes study retrieval and selection. It begins with the total number of citations retrieved from the literature searches and ends with the number of studies that met all inclusion criteria of the report. This figure is described in the Section entitled ““Literature Search”“ as follows: ““From our search of the electronic databases, 1,287 studies were identified. After duplicates were removed, 803 citations remained. We screened all the citations and identified 235 that were potentially relevant. Four studies could not be retrieved through the University of Alberta’s interlibrary loan system (Appendix D), therefore, the full text of 231 publications were reviewed for potential inclusion into this report. Of these, 20 unique RCTs (reporting data from 80 articles) were included. Ten studies addressed type 2 diabetes, seven addressed metabolic syndrome, and three addressed prostate and/or breast cancer. Many of the included trials were associated with multiple publications that either expanded on the main results, reported secondary outcomes that were not included in the primary report, or reported different followup timepoints. The publication that was the first to report outcome data was considered the primary study. See Appendix C for a list of the associated publications. Relevant baseline and outcome data were taken from the primary publication and supplemented by the data from the associated publications. The main reasons for excluding studies were: (1) insufficient length (n=39); (2) inappropriate intervention (n=33); (3) wrong population (n=28); (4) wrong publication type or study design (n=28), leaving 23 studies excluded for other reasons.”“

Many of the included trials were associated with multiple publications that either expanded on the main results, reported secondary outcomes that were not included in the primary report, or reported different followup timepoints. The publication that was the first to report outcome data was considered the primary study. See Appendix C for a list of the associated publications. Relevant baseline and outcome data were taken from the primary publication and supplemented with data from the associated publications.

The main reasons for excluding studies were: (1) insufficient length (n=39); (2) inappropriate intervention (n=33); (3) wrong population (n=28); (4) wrong publication type or study design (n=28), and other reasons (n=24). See Appendix D for a complete list of the excluded studies.

## Key Question 1 What is the evidence on the effectiveness of lifestyle interventions for type 2 diabetes mellitus, metabolic syndrome, breast cancer, and prostate cancer?

### Type 2 Diabetes

#### Description of Included Studies

Ten RCTs110–119 met the inclusion criteria to address this question. There were 19 associated publications.130–148 Five trials111–113,115,119 had an intervention of at least 3 months and a followup period of at least 6 months postintervention. The interventions ranged from 6 to 48 months; the followup periods ranged from 6 to 93 months. The other five trials110,114,116–118 had interventions that lasted 1 year but had no postintervention followup. One study112 is ongoing and the investigators plan to have 10.5 to 11.5 years of followup data. For one trial, Steno-2 by Gaede et al.,119 we present outcomes at 4 years (interim outcomes), 8 years (end of intervention), and 13 years postintervention. For the remaining trials, outcomes are reported for the end of intervention and at the longest postintervention followup timepoint.

For all 10 trials, the number of participants who were randomized ranged from 72 to 5,145 (median = 194; IQR: 143, 259). The mean ages ranged from 53.0 to 62.4 years. See Table 1 for baseline and study characteristics. From nine studies, the mean duration of diabetes ranged from newly diagnosed to 12.7±10.6 years. Duration of diabetes was not reported in one study.110 The mean BMI ranged from 29.7±3.8 to 37.6±6.5 kg/m^2^. Nine studies reported that all participants were taking oral diabetes medication, insulin, or both; one117 did not report medication use.

Table 1 Description of studies and baseline characteristics of participants: type 2 diabetes

Studies with postintervention followup
Author, Year | Randomized (N); Withdrawals (N) | Age (mean ± SD) Males: N (%);Ethnicity | Socioeconomic status (%≤$20,000/yr income); Education (%≤ high school); Smokers: (%) | Weight (kg); BMI (km/m^2^); Waist circumference (cm) | HbA1c (%); Plasma Fasting Glucose (mmol/L); Insulin Resistance (HOMA: IR); Blood pressure (mmHg) | Duration of Diabetes (yrs); Type of medication: (%)
Gaede, 1999, Steno-2^119^ | I: 80; 13 C: 80; 17 | I: 54.9±7.2; 63.0(79.0); NR C: 55.2±7.2; 56.0(70.0); NR; | I: NR; NR; 40.0 C: NR; NR; 33.8 | I: 91.4±13.6; 29.7±3.8; NR C: 89.9±17.3; 29.9±4.9; NR | I: 8.4±1.6; 10.1±3.1; NR; 146±20/85±10 C: 8.8±1.7; 10.5±3.0; NR; 149±19/86±11 | I: 5.5 (2.0–8.8); OHA: 59; insulin: 63; both: 0; lipid lowering: 38 C: 6.0 (4.0–10.0); OHA: 60; insulin: 13; both: 1; lipid lowering: 1
Keyserling, 2002, New Leaf Program111 | I: 67; 13 C: 67; 9 Grp3: 66; 7 | I: 58.5; 0; 100 Black C: 59.2; 0; 100 Black Grp3: 58.8; 0; 100 Black | I: 34.3 (<$10,000/yr); NR; 14.9 C: 22.4 (<$10,000/yr); NR; 16.4 Grp3: 30.3 (<$10,000/yr); NR; 19.7 | I: 95.0; 36.2; NR C: 95.7; 36.2; NR Grp3: 91.9; 34.6; NR | I: 10.7±0.3; NR; NR; NR C: 11.3±0.3; NR; NR; NR Grp3: 11.1±0.4; NR; NR; NR | I: 10.8; OHA: 57; insulin: 43; both: 12 C: 9.9; OHA: 58; insulin: 42; both: 9 Grp3: 10.7; OHA: 57; insulin 41; both: 8
Look Ahead Research Group, 2009, Look AHEAD112 | I: 2570; 74 C:2575; 112 | I: 58.6±6.8; 1046.0 (40.7); 63.1 White, 15.5 Black, 21.3 Other C: 58.9±6.9; 1040.0 (40.4); 63.3 White, 15.7 Black, 20.9 Other | I: NR; NR; NR C: NR; NR; NR | I: 100.54±19.65; 35.89±6.01; 113.8±14.35 C: 100.86±18.83 36.0±5.76; 114.06±13.55 | I: 7.25±0.02; 151.9±0.9(mg/dl); NR; 128.2±0.4/69.9±0.2 C: 7.29±0.02; 153.6±0.9 (mg/dl); NR; 129.4±0.3/70.4±0.2 | Both groups: 6.7±4.5 yr; I: diabetes medication: 87; insulin: 15; antihypertensives: 75; lipid lowering: 49 C: diabetes medication: 87; insulin: 16; antihypertensives: 74; lipid lowering: 48
Menard, 2005^113^ | I: 36; 4 C: 36; 7 | I: 53.7±7.5; 27 (75); NR C:55.9±8.6; 22 (61); NR | I: NR; NR; 13.9 C: NR; NR; 16.7 | I: 93.5±20.1; 32.8±5.5; NR C: 88.5±18.5; 32.7±5.7; NR | I: 9.1±1.0; 10.8±3.5; NR; 144±21/85±11 C: 9.3±1.0; 10.7±3.0; NR;143 ±17/86± 10 | I: 10.6±6.7; OHA ≥1: 38; insulin: 3; both: 35 C: 10.0±7.7; OHA ≥1: 17; insulin: 11; both: 23
Toobert, 2003; Mediterranean Lifestyle Program115 | I: 163; 26 C: 116; 8 | I: 61.1±8.0; 0; 92 White C:60.7±7.8; 0; 94.8 White | I: 30.3, 33.7, 8.7 C: 36.8, 36.2, 10.3 | I: 92.3±21.2; 35.34±7.93; NR C: 93.9±23.8; 34.87±8.2; NR | I: 7.43±1.3; NR; NR; 136.06±13.91/79.29±9.49 C: 7.4±1.48; NR; NR; 134.01 ±14.17/77.38± 9.2 | I: 8.2±7.3; OHA: 55, insulin: 7, both: 13, lipid lowering: 39, BP lowering: 46 C: 8.5±8.3; OHA: 61, insulin: 12; both: 10; lipid lowering: 41, BP lowering: 47
Studies with no postintervention followup
Aubert, 1998^116^ (T1D & T2D-14% had T1D) | I: 71 C: 67 Total 38 | I: 53 (median); 26 (37); 83 White C: 54 (median); 29 (43); 70 White | I: NR; NR;17 C: NR; NR;11 | I: NR; 32 (median); NR C: NR; 34 (median); NR | I: 8.8 (median); NR; NR; NR C: 8.4 (median); NR; NR; NR | I: 6 (median); insulin: 44 C: 6 (median); insulin: 33
Christian, 2008^110^ | I: 155; 14 C: 155; 23 | I: 53±11.25; 55(35); 100 Hispanic/Latino C:53.4±10.7; 50(32); 100 Hispanic/Latino | I: NR; NR; NR C: NR; NR; NR | I: 207±47.3 lbs; 35.4±6.62; 118.1±14.95 C: 200.2±44.7 lbs; 34.8±7.11; 116.6±15.23 | I: 8.08±2.02; NR; NR; 131.8±17.02/76.56 ±10.53 C: 8.29±1.93; NR; NR; 132.26 ±17.43/77.83± 9.58 | I: NR; diabetic drugs taken by 98% of participants C: NR; diabetic drugs taken by 95% of participants
Mayer-Davis, 2004, POWER114 | Total: 189; 37 | I: 59.7±8.6; 11 (22); 14.3 White, 83.7 Black, 2 Other C: 62.4±9.5; 12 (21); 26.8 White, 73.2 Black Grp 3: 58.9±7.8; 7 (15); 10.6 White, 89.4 Black | I: NR; 38.8 (<High School); NR C: NR; 60 (<High School); NR Grp 3: NR; 44.7 (<High School); NR | I: 99.5±17.1; 37.6±6.5; NR C: 93±20.3; 35.2±7.5; NR Grp 3: 100±19.8; 37.5±6.7; NR | I: 10.2±2.5; NR; NR; NR C: 9.6±2.9; NR; NR; NR Grp 3: 9.7±3.1; NR; NR; NR | I: 8.4±6.5; OHA: 47; insulin: 27, both: 24 C: 12.7±10.6; OHA: 57; insulin: 32; both: 9 Grp 3: 11.6±10; OHA: 53; insulin: 26, both: 17
Samuel-Hodge, 2009, DAWN118 | I: 117;16 C: 84; 15 | I: 57±0.9; 42(35.9); 100 Black C: 61.3±1.3; 31(36.9); 100 Black | I: 43 (<$30,000 household income); NR;10 C:46 (<$30,000 household income); NR; 7 | I: 96.8±2; 34.6±0.7; NR C: 98.2±2.6; 35.1±0.8; NR | I: 7.7±0.2; NR; NR; 139±1.7/75±0.6 C: 7.9±0.3; NR; NR; 140±2.2/76±1.2 | I: 8.8±0.8; OHA: 71; insulin: 32; both: 19; insulin ≥ 1/day: 76 C: 9.2±0.9; OHA: 79; insulin: 25; both: 13; insulin ≥ 1/day: 59
Vanninen, 1992^117^ | Total: 90 total; 12 total | Total: 53.7±7 for males (n=45); 54±6 for females ( n=33) I: 21(55.3) C: 17(44.7) NR | Total: NR; NR; 18 | I: NR; 32.13±5.3; NR C: NR; 31.74±4.96; NR | I: 7.1±1.48; NR; NR; NR C: 7.62±2.02; NR; NR; NR | I: newly diagnosed; NR; NR C: newly diagnosed; NR; NR

AHEAD = Action for Health in Diabetes; BP = blood pressure; DAWN = Diabetes Awareness and Wellness Network; NR = not reported; OHA = oral hypoglycemic agent; POWER = Pounds Off With Empowerment; T1D = Type 1 diabetes; T2D = Type 2 diabetes

While all lifestyle interventions included a diet and exercise component, they had diverse additional components (Table 2). Five studies111,112,114,116,118 used both group and individual counseling, three incorporated only group counseling,115,117,119 and two 110,113 had only individual counseling. Other components included a smoking cessation course,119 regular telephone contact,111,113 individual goal setting,110,115,116,118 regular blood glucose and blood pressure monitoring,118 and stress management.115,118 In one study,115 the participants went on a 3 day nonresidential retreat at the beginning of the intervention. In one,117 physicians were responsible for motivating the participants. Four studies had medication use as one of the intervention components. The results of these studies are presented separately.

Table 2 Description of lifestyle interventions: type 2 diabetes

Studies with postintervention followup
Author, Year, Study name | Duration of intervention; followup | Diet | Exercise | Counseling or other component(s) | Control group
Gaede, 1999, Steno-2^119^ | 3 mo; 13 yr | - Low fat diet: fat < 30% of intake, SFA < 10% of intake, increased complex CHO; - Dietician; every 3 mo for 1 yr; - Educational material, examples of low fat/high CHO lunches and snacks served at the group meetings | - Light to moderate PA ≥ 30 min, 3–5 x/wk; - Educational material, demonstrations of exercise effect on decreasing blood glucose | - Group counseling: dietician; groups of 20 with spouses; 2 sessions; - Smoking cessation course with spouses: 5 meetings in 8 wk, followup at 3 & 6 mo; - Stepwise use of pharmacologic tx if glycemic goals not met including metformin, gliclazide, NPH insulin, thiazides, calcium-channel blockers, β-blockers; - Statins and fibrates were used for dyslipidemia and hypertriglyceridemia; - All received ACE inhibitor, vitamin C & E | - Usual/standard care from primary care physician following the 1998 guidelines of the Danish Medical Association
Keyserling, 2002, New Leaf Program111 | 6 mo; 6 mo | - Food for Heart Program: decreased total fat and SFA; improved distribution of CHO intake; - Educational material, cookbook, logbook, workbook, monthly progress reports | - Followed CDC & ACSM guidelines: >30 min/day moderate PA; - Caltrac accelerometer worn for 1 wk; - Educational materials, logbook, workbook | - Individual counseling: health counselor, 4 sessions; peer counselor, monthly telephone contact; community diabetes advisor, 1 session/mo; - Group counseling: health counselor & research assistant, 3 sessions; - Behavior modification principles, active discovery learning approach | - Usual/standard care from primary care physician; - Mailed educational pamphlets
Look AHEAD Research Group, 2009, Look AHEAD112 | 4 yr completed; projected to end at 11.5 yr | - Minimum wt loss of ≥7% in 1^st^ yr, encouraged wt loss of ≥ 10%; - Caloric restriction, portion control, meal replacements, increased F&V intake, lower fat; - Toolbox options for sub-optimal weight loss, including: written behavioral contracts, additional funds to promote adherence to behavioral goals (gym membership, cooking classes, pre-packaged meals) | - Mainly unsupervised exercise at home; - Started with 50 min/wk moderate PA; increased to >175 min/wk by 6 mo; 5 d/wk; - Strength training encouraged up to 25% of weekly goal; - Educational material, logbook, progress reports, pedometers; - Centers offered supervised activity; - Regularly weighed and tracked min of PA/wk, attendance taken | - Group and individual behavioral program (with curriculum similar to DPP) delivered by lifestyle counselor; - Individual counseling: lifestyle counselor; one visit/mo provided throughout the study; - Group counseling: done in 3 phases; 3 visits/mo for first 1–6 mo; 2 visits/mo for mo 7–12; intermittent group sessions thereafter (typically 6–8 wk session offered 2–3 times/yr); - Orlistat given to pts who did not lose >10% of initial wt | - Attention control; - 3 group educational/social support sessions per yr for 4 yr; - Regular clinic visits and telephone calls for data collection
Menard, 2005^113^ | 12 mo; 6 mo | - Followed Canadian Nutrition Recommendations | - Home-based program on exercise bike; use of elastic exercise bands; - Used HR monitor; - 4 phases: warm-up, cardiovascular, resistance, cool-down stretching; - Aimed for 45–55 min sessions 3–5 x/wk | - Individual counseling: multidisciplinary team; monthly visits at the clinic; - Telephone contact 2 times between visits for information on test results, therapy adjustment and motivation; - Stepwise use of pharmacologic tx if CDA goals not met including glyburide, metformin, α-glucosidase inhibitor, intermediate-acting insulin, fosinopril, amlodipine, hydrocholorothiazide, atenolol, irbesartan, doxazosin, fibrates, statins | - Usual/standard care from primary care physician; - Given general health and diabetes advice at each laboratory visit (baseline, 6, 12, 18 mo)
Toobert, 2003, Mediterranean Lifestyle Program115 | 6 mo; 18 mo | - Followed CDC & ACSM guidelines; - Mediterranean ALA-rich diet: low in SFA, moderately high in MUFA; - Meal planning, recipes, logbook, progress reports, attendance taken, monetary rewards, contests | - 10 strength-training exercises 2d/wk, building to 3 sets of 12 repetitions; - Increase PA by 5 min/session, increase number of d/wk; goal= 1 hr session >3× per wk | - 3 d non-residential retreat at start of intervention; - Initial consultation: exercise physiologist; goal setting; - Group counseling: weekly 4 h meetings involving social support, PA, relaxation, meditation, potluck dinner; - Stress management: 1 hr/d with an audiocassette, included 20 min of yoga, 15 min of progressive deep relaxation techniques, 15 min of meditation and 5 min of directed or receptive imagery | - Usual/standard care from primary care physicians
Studies with no postintervention followup
Aubert, 1998^116^ | 12 mo; 0 | - General healthy eating including meal planning; - Telephone calls, blood glucose log | - General, self-directed increase in PA with reinforcement via telephone calls | - Individual and group counseling: registered dietician, exercise therapist; 5-wk education program; 12 hr; - Included goal setting; - Stepwise use of pharmacologic tx if glycemic or wt loss goals not met after 1–3 mo including sulfonylurea, metformin, precise, regular and NPH insulin | - Attention control; - Given blood glucose meters and strips; - Encouraged to discuss enrollment in diabetes education class with physicians; - Continued to received diabetes care and followup from primary care physician
Christian, 2008^110^ | 12 mo; 0 | - Decreased caloric intake; - Computer generated 4–5 pg individualized, tailored report providing feedback on participant-identified barriers to improve PA and diet; - 30 pg planning guide with supplemental info on diabetes and healthy lifestyle | - Feedback to enhance participants’ motivation to increase PA | - Individual counseling: physician; regularly scheduled study-related visits; included self-management goal setting of 2–3 dietary and/or PA goals; - All subjects received 3 mo of diabetes education prior to randomization | - Usual/standard care from primary care physician; - Health education materials provided at baseline visit addressing diabetes, diet, and exercise
Mayer-Davis, 2004, POWER114 | 12 mo; 0 | - Followed the Intensive Lifestyle Intervention modeled after the DPP study with modifications; - Goal was to achieve and maintain wt loss of 10% over 12 mo; - Aimed for 25% of calories from dietary fat; - Education materials, monetary incentives provided for completing 3, 6 and 12 mo | - Goal of ≥150 min/wk of low to moderate PA; - Suggestions for PA were provided (e.g.: safe places to walk, chair exercises for people with lower-extremity pain); - Written materials, monetary incentives provided for completing 3, 6 and 12 mo | - Individual counseling: nutritionist; gradually decreased frequency over 12 mo; 1 hr sessions; included behavioral strategies to achieve wt loss; - Group counseling: nutritionist; gradually decreased frequency over 12 mo; 1 hr sessions; - 1 individual session for every 3 group sessions | - Attention control; - 1 individual session by nutritionist at the beginning of study; - Information about diet and PA provided from the ADA
Samuel-Hodge, 2009, DAWN118 | 8 mo; 4 mo | - General healthy eating; - Each group session had taste testings of 1–2 recipes; - Telephone calls, postcard messages of encouragement | - General increase in PA; - Every group session had 15 min of chair exercises; - Actigraph monitor worn for 1 wk; - Telephone contact, postcard messages of encouragement | - Individual counseling: registered dietician for 1 session, 1 hr; stress management and goals; - Group counseling: registered dietician for first 7 sessions, health professional from local community for 4 sessions, 1 group potluck for total of 12 sessions (biweekly); 90–120 min; - Prior to each group session, all participants checked their blood glucose and BP, and received feedback | - Attention control; - Received 2 pamphlets in the mail published by the ADA and 3 bimonthly newsletters providing general health information and study updates
Vanninen, 1992^117^ | 12 mo; 0 | - Reduction in total energy, total fat and dietary cholesterol, with emphasis on reduction of SFA; - Moderate increment of MUFA, PUFA, and complex CHO with focus on soluble fiber; - Target food habits were regular eating patterns and to moderate amount of food consumed | - Goal was to increase PA to 3–4 x/wk for 30–60 min; - Recommended mean heart rate was 110–140 beats/min; - Types of exercise were suggested (e.g.: walking, jogging, cycling, swimming) | - Group counseling: physician, dietician, nurse specialized in diabetes; 6 meetings at 2 mo intervals; - Physician was responsible for motivation | - Usual/standard care by primary care physician; - Advised to visit the local community health centers regularly at 2–3 mo intervals; - Visited the outpatient clinic at 6 and 12 mo

ACE = angiotensin-converting enzyme, ACSM = American College of Sports Medicine; AHEAD = Action for Health in Diabetes; ALA = α-linolenic acid; BP = blood pressure; CDC = Centers for Disease Control; CHO =carbohydrate; d = day(s); DAWN = Diabetes Awareness and Wellness Network; DPP = Diabetes Prevention Program; HR=heart rate; info = information; min = minutes; mo = month(s); MUFA = monounsaturated fatty acids; PA = physical activity; pg = page; POWER = Pounds Off With Empowerment; SFA = saturated fatty acids; tx = treatment; wk = week(s); × = times; yr = year

The interventions were administered or delivered by dietitians,111,112,114–119 case managers or nurses,112,116–119 physicians,110,112,116,117,119 a qualified exercise advisor or trainer,112,115,116 a behavioral therapist or physiologist,112,115 a health or nonprofessional peer counselor,111 lay leaders and trained support group leaders,115 and a lifestyle counselor.112 One study113 reported that the intervention was delivered by a multidisciplinary team but did not specify the individual members.

### Methodological Quality

Table 3 summarizes the methodological quality of the RCTs. Two trials114,116 were assessed as high risk of bias; eight110–113,115,117–119 were assessed as unclear. Most of the domains had low risk of bias. The domain in which all studies had unclear or high risk of bias was the blinding of subjective or self-reported outcomes. Two studies stated that outcome assessors were blinded to treatment allocation.112,119 In nine trials,110,112–119 the baseline characteristics of the intervention and control groups were comparable. Seven studies110,111,114,115,117–119 received funding from government, two received funding from foundations,113,117 and two received funding from industry.112,113 One study116 did not report funding.

Table 3 Risk of bias assessment for studies of type 2 diabetes

Author Year | Sequence generation | Allocation concealment | Blinding: Objective outcomes | Blinding: Self-reported outcomes | Incomplete outcome data | Selective outcome reporting | Other sources: Baseline imbalance | Other sources: Funding | Overall risk of bias
Aubert 1998^116^ | Unclear | Unclear | Low | High | Unclear | Low | Low | Unclear | High
Christian 2008^110^ | Low | Unclear | Low | Unclear | Low | Low | Low | Low | Unclear
Gaede 1999^119^ | Low | Low | Low | Unclear | Low | Low | Low | Low | Unclear
Keyserling, 2002^111^ | Low | Low | Low | Unclear | Unclear | Low | Low | Low | Unclear
Look AHEAD Research Group 2009^112^ | Low | Low | Low | Unclear | Low | Low | Low | Low | Unclear
Mayer-Davis 2004^114^ | Unclear | Low | Low | High | Unclear | Low | Low | Low | High
Menard 2005^113^ | Low | Low | Low | Unclear | Unclear | Low | Low | Unclear | Unclear
Samuel-Hodge 2009^118^ | Low | Low | Low | Unclear | Low | Low | Low | Low | Unclear
Toobert 2003^115^ | Low | Low | Low | Unclear | Unclear | Low | Low | Low | Unclear
Vanninen 1992^117^ | Unclear | Unclear | Low | Unclear | Unclear | Low | Low | Low | Unclear

High = high risk of bias; Low = low risk of bias; Unclear = unclear risk of bias

### Results

Primary Outcomes. Our primary outcomes were progression of diabetes (additional medication or insulin treated diabetes) and progression to cardiovascular problems, hypertension, or neuropathies. The Steno-2 trial by Gaede et al.119 was the only study to present data on our primary outcomes (Table 1). Data were provided at 4, 8 and 13.3 years. Medication was one of the components of the lifestyle intervention (Table 2).

Progression of diabetes, CVD complications, and death. There was a statistically significant decrease in the number of nonfatal myocardial infarctions in favor of the lifestyle group at 8 years (RR = 0.29; 95% CI: 0.11, 0.76) and 13.3 years (RR = 0.24; 95% CI: 0.12, 0.48).

At 13.3 years, 24 patients in the lifestyle group compared with 40 in the usual care group died (hazard ratio [HR] = 0.54; 95% CI: 0.32, 0.89). The lifestyle intervention was associated with a lower risk of death from cardiovascular causes (HR = 0.43; 95% CI: 0.19, 0.94) and a lower risk of cardiovascular events (HR = 0.41; 95% CI: 0.25, 0.67) including nonfatal strokes (RR = 0.17; 95% CI: 0.07, 0.42). Also, there was a statistically significant difference in the amputations (RR = 0.31; 95% CI: 0.16, 0.59) at 13 years favoring the lifestyle intervention. There was no statistically significant difference between the lifestyle and usual care groups in the number of coronary bypass grafts (RR = 0.67; 95% CI: 0.29, 1.54).

Retinopathy. At 4 years, there was no difference between groups in the development of retinopathy (RR = 0.60; 95% CI: 0.31, 1.14); at 13.3 years, the difference was statistically significant in favor of the lifestyle intervention (RR = 0.76; 95% CI: 0.58, 0.99). At 4 years and 8 years, there was a difference in progression of retinopathy in favor of the lifestyle intervention. (RR = 0.58; 95% CI: 0.36, 0.92 and RR = 0.75; 95% CI: 0.56, 0.99, respectively). At 13.3 years, progression of retinopathy occurred in 41 patients in the lifestyle intervention group compared with 54 in the control group (RR = 0.76; 95% CI: 0.58, 0.99).

Neuropathy. At both 4 and 8 years, there was a difference in favor of the lifestyle intervention for progression in autonomic neuropathy (RR = 0.36; 95% CI: 0.17, 0.77 and RR = 0.56; 95% CI: 0.38, 0.83, respectively). At 13.3 years, there was still a significant difference between the groups (RR = 0.75; 95% CI: 0.57, 0.99). In contrast, there was no difference at either 4 or 8 years for the progression of peripheral neuropathy (RR = 0.81; 95% CI: 0.50, 1.31 and RR = 0.93; 95% CI: 0.67, 1.28, respectively). Peripheral neuropathy progressed in 44 (lifestyle) and 46 (control) patients (RR = 0.96; 95% CI: 0.73, 1.26) at 13.3 years.

Nephropathy. There was a statistically significant difference in the development of nephropathy in favor of the lifestyle intervention at 4 years (RR = 0.42; 95% CI: 0.20, 0.91) and 8 years (RR = 0.52; 95% CI: 0.31, 0.87). At 13.3 years, 20 patients in the lifestyle group had developed nephropathy compared with 37 in the control group (RR = 0.54; 95% CI: 0.35, 0.85). One patient in the lifestyle group had progressed to end-stage renal disease compared with four in the control group (RR = 0.45; 95% CI: 0.23, 0.86) at 13.3 years.

Secondary Outcomes. Change in body composition. Five studies110–112,114,118 reported change in weight (lbs) at the end of the intervention (Figure 3). In all but one study, the lifestyle groups lost more weight than the usual care groups, although only two studies reported a statistically significant difference. The pooled mean difference (MD) was not statistically significant; however, there was substantial heterogeneity (MD = −3.50; 95% CI: −10.06, 3.06; I^2^ = 99%) (data not shown). We conducted a post hoc sensitivity analysis of lifestyle interventions that included medication as part of their intervention and lifestyle interventions that did not include medications (Table 2). At the end of intervention, lifestyle groups lost more weight than the usual care groups regardless of whether medication was part of the intervention. However, the weight loss was greater in the Look Ahead trial112 that included medication.

Figure 3 Effect of lifestyle interventions vs. control on weight change (lbs): patients with type 2 diabetes

Figure 3 displays a forest plot of studies reporting a mean difference of weight (lbs), lifestyle interventions vs. control in patients with type 2 diabetes. This figure is described further in the section “Change in body composition” as follows: “Five studies reported change in weight (lbs) at the end of the intervention. In all but one study, the lifestyle groups lost more weight than the usual care groups, although only two studies reported a statistically significant difference. The pooled mean difference (MD) was not statistically significant; however, there was substantial heterogeneity (MD = −3.50; 95% CI: −10.06, 3.06; I2 = 99%; data not shown). We conducted a post hoc sensitivity analysis of lifestyle interventions that included medication as part of their intervention and lifestyle interventions that did not include medications. At the end of intervention, lifestyle groups lost more weight than the usual care groups regardless of whether medication was part of the intervention. However, the weight loss was greater in the Look Ahead trial that included medication. The New Leaf study by Keyserling et al. and the Look AHEADtrial reported followup data. There was no statistically significant difference among the groups in the New Leaf trial (MD = 1.14; 95% CI: −5.39, 7.67). However, the significant weight loss in the lifestyle intervention in the Look AHEAD trial was still seen at 4 years (MD = −11.62; 95% CI: −12.37, −10.87).”

The New Leaf study by Keyserling et al.111 and the Look AHEAD112 trial reported followup data (Figure 3). There was no statistically significant difference among the groups in the New Leaf trial (MD = 1.14; 95% CI: −5.39, 7.67; I^2^=0%). However, the significant weight loss in the lifestyle intervention in the Look AHEAD trial was still seen at 4 years (MD = −11.62; 95% CI: −12.37, −10.87).

Five studies113–115,117,119 reported change in BMI (kg/m2; Figure 4). At the end of the intervention, the pooled MD was statistically significant in favor of the lifestyle intervention (MD = −0.48; 95% CI: −0.92, −0.05; I^2^ = 0%). A post hoc sensitivity analysis of lifestyle interventions with113 and without a medication component did not change the results substantially (data not shown).

Figure 4 Effect of lifestyle interventions vs. control on body mass index (kg/m2): patients with type 2 diabetes

“Figure 4 displays a forest plot of studies reporting a mean difference of BMI (kg/m2), lifestyle interventions vs. control in patients with type 2 diabetes. This figure is described further in the section ““Change in body composition”“ as follows: ““Five studies reported change in BMI (kg/m2). At the end of the intervention, the pooled MD was statistically significant in favor of the lifestyle intervention (MD = −0.48; 95% CI: −0.92, −0.05; I2 = 0%). A post hoc sensitivity analysis of lifestyle interventions with and without a medication component did not change the results substantially (data not shown). One study reported BMI at 6 months postintervention and found no difference between the groups (MD = 1.0; 95% CI: −1.84, 3.84). For the Steno-2 study by Gaede et al. at 4 years, there was a statistically significant difference in favor of usual care (MD = 0.77; 95% CI: 0.15, 1.39); at 8 years, there was no difference between the groups (MD = 0.37; 95% CI: −2.12, 2.86).”“

One study113 reported BMI at 6 months postintervention and found no difference between the groups (MD = 1.0; 95% CI: −1.84, 3.84). For the Steno-2 study by Gaede et al.119 at 4 years, there was a statistically significant difference in favor of usual care (MD = 0.77; 95% CI: 0.15, 1.39); at 8 years, there was no difference between the groups (MD = 0.37; 95% CI: −2.12, 2.86).

Change in metabolic variables. Ten studies110–119 reported on changes in different metabolic variables, including fasting plasma glucose112,113,117,119 (Figure 5), triglycerides110,112,113,115,117,119 (Figure 6), total cholesterol110,111,114,115,117,119 (Figure 7), HDL and LDL cholesterol110–115,117,119 (Figure 8, Figure 9), and HbA1c110–119 (Figure 10). For lifestyle interventions that did not include medication as part of the intervention, there was no statistically significant difference between groups for any of the metabolic variables at the end of intervention (these were post hoc sensitivity analyses). For lifestyle interventions that included medication, the results were statistically significant in favor of lifestyle for fasting plasma glucose, HDL cholesterol, and HbA1c; for the remaining variables, there was no statistically significant difference between groups at the end of intervention.

Figure 5 Effect of lifestyle interventions vs. control on fasting plasma glucose (mmol/l): patients with type 2 diabetes

“Figure 5 displays a forest plot of studies reporting a mean difference of fasting plasma glucose (mmol/l), lifestyle interventions vs. control in patients with type 2 diabetes. Four studies reported fasting plasma glucose. A significant difference favoring lifestyle intervention was seen for studies with medication at the end of intervention (MD = −1.02; 95% CI: −1.85, −0.19; I2 = 46%). However, no difference was seen in the one study that did not include medication in their lifestyle intervention (MD = 0.33; 95% CI: −0.83, 1.49). Significant differences were seen at followup timepoints of 4 (MD = −2.40; 95% CI: −3.64, −1.16) and 8 years (MD = −1.89; 95% CI: −3.37, −0.41). No differences were seen at other followup timepoints. All followup studies had medication incorporated into the lifestyle interventions.

Figure 6 Effect of lifestyle interventions vs. control on triglycerides (mmol/l): patients with type 2 diabetes

Figure 6 displays a forest plot of studies reporting a mean difference of triglycerides (mmol/l), lifestyle interventions vs. control in patients with type 2 diabetes. Six studies reported on triglycerides. Though a positive difference was seen at the end of intervention for both studies including medication (MD = −0.43; 95%CI: −1.27, 0.40; I2 = 53%), and those that did not (MD = −0.11; 95% CI: −0.30, 0.09; I2 = 0%) there were no differences between groups at any of the timepoints.

Figure 7 Effect of lifestyle interventions vs. control on total cholesterol (mmol/l): patients with type 2 diabetes

Figure 7 displays a forest plot of studies reporting a mean difference of total cholesterol (mmol/l), lifestyle interventions vs. control in patients with type 2 diabetes. Six studies reported total cholesterol. No difference was seen at the end of intervention (MD = −0.13; 95% CI: −0.27, 0.01; I2 = 0%). A positive difference was seen at the followup at 4 years (MD = −0.39; 95%CI: −0.74, −0.04), and followup at 8 years (MD = −1.20; 95%CI: −1.60, −0.80) but no difference was seen at the longest followup timepoint of 13.3 years (MD = 0.38; 95%CI: −0.06, 0.82). The Steno-2 study that reported the 4, 8, and 13 year followup data had medication use in their lifestyle intervention.

Figure 8 Effect of lifestyle interventions vs. control on HDL cholesterol (mmol/l): patients with type 2 diabetes

Figure 8 displays a forest plot of studies reporting a mean difference of HDL cholesterol (mmol/l), lifestyle interventions vs. control in patients with type 2 diabetes. Seven studies reported HDL cholesterol. At the end of intervention, a positive difference was seen favoring the lifestyle interventions in the Look AHEAD trial that included medication use (MD = 0.05; 95%CI: 0.03, 0.07). No differences were seen for studies without medication at end of intervention nor for any of the followup timepoints.

Figure 9 Effect of lifestyle interventions vs. control on LDL cholesterol (mg/dl): patients with type 2 diabetes

Figure 9 displays a forest plot of studies reporting a mean difference of LDL cholesterol (mg/dl), lifestyle interventions vs. control in patients with type 2 diabetes. Six studies reported LDL cholesterol. A significant difference was seen at the 6 month followup (MD = −0.59; 95%CI: −1.07, −0.11) and 8 year followup (MD = −0.88; 95%CI: −1.27, −0.49) in favor of the lifestyle interventions. Both timepoints included studies with medication use. There were no differences seen at any of the other timepoints.

Figure 10 Effect of lifestyle interventions vs. control on HbA1c (%): patients with type 2 diabetes

Figure 10 displays a forest plot of studies reporting a mean difference of HbA1c (%), lifestyle interventions vs. control in patients with type 2 diabetes. All 10 studies reported HbA1c values. A positive difference was seen at the end of intervention for studies that included medication use (MD = −0.77; 95% CI: −1.18, −0.36; I2 = 72%) but insignificant for studies without medication. No other significant differences were seen at the other timepoints.

In the Steno-2 trial, at 4 and 8 years, changes in most metabolic variables were sustained. At 13.3 years, the differences between the lifestyle intervention and usual care were generally no longer statistically significant. The lifestyle intervention for this trial included medication as part of the intervention.

Systolic and diastolic blood pressure. Changes in systolic and diastolic blood pressures (mmHg) were reported in seven studies.110,112–115,118,119 For lifestyle interventions that did not include medication as a component, there was no statistically significant difference between groups for either outcome at the end of intervention (these were post hoc sensitivity analyses) (Figure 11, Figure 12). For lifestyle interventions that included medication, the results were statistically significant in favor of lifestyle for diastolic, but not systolic blood pressure (Figure 11, Figure 12).

Figure 11 Effect of lifestyle interventions vs. control on systolic blood pressure: patients with type 2 diabetes

“Figure 11 displays a forest plot of studies reporting a mean difference of systolic blood pressure (mmHg), lifestyle interventions vs. control in patients with type 2 diabetes. This figure is described further in the Section entitled ““Systolic and diastolic blood pressure”“ as follows: ““Changes in systolic and diastolic blood pressures (mmHg) were reported in seven studies. For lifestyle interventions that did not include medication as a component, there was no statistically significant difference between groups for either outcome at the end of intervention (these were post hoc sensitivity analyses). For lifestyle interventions that included medication, the results were statistically significant in favor of lifestyle for diastolic, but not systolic blood pressure. For systolic blood pressure, there was a significant difference in favor of the lifestyle intervention at 4 years followup (MD = −2.38; 95% CI: −3.05, −1.72) and at 8 years followup (MD = −11.00 (95% CI: −18.07, −3.93). For diastolic blood pressure, the only significant change was seen at 4 years followup (MD = −0.46; 95% CI: −0.80, −0.12). The lifestyle intervention for these studies included medication as part of the intervention.”“

Figure 12 Effect of lifestyle interventions vs. control on diastolic blood pressure: patients with type 2 diabetes

Figure 12 displays a forest plot of studies reporting a mean difference of diastolic blood pressure (mmHg), lifstyle interventions vs. control in patients with type 2 diabetes. This figure is described further in the Section entitled “Systolic and diastolic blood pressure” as follows: “Changes in systolic and diastolic blood pressures (mmHg) were reported in seven studies. For lifestyle interventions that did not include medication as a component, there was no statistically significant difference between groups for either outcome at the end of intervention (these were post hoc sensitivity analyses). For lifestyle interventions that included medication, the results were statistically significant in favor of lifestyle for diastolic, but not systolic blood pressure. For systolic blood pressure, there was a significant difference in favor of the lifestyle intervention at 4 years followup (MD = −2.38; 95% CI: −3.05, −1.72) and at 8 years followup (MD = −11.00 (95% CI: −18.07, −3.93). For diastolic blood pressure, the only significant change was seen at 4 years followup (MD = −0.46; 95% CI: −0.80, −0.12). The lifestyle intervention for these studies included medication as part of the intervention.”

For systolic blood pressure, there was a significant difference in favor of the lifestyle intervention at 4 years followup (MD = −2.38; 95% CI: −3.05, −1.72; I^2^=0%) and at 8 years followup (MD = −11.00 (95% CI: −18.07, −3.93). For diastolic blood pressure, the only significant change was seen at 4 years followup (MD = −0.46; 95% CI: −0.80, −0.12; I^2^=0%)) (Figure 11, Figure 12). The lifestyle intervention for these studies included medication as part of the intervention.

Change in physical activity. Seven studies110–113,115,118,119 reported changes in physical activity using different outcome measures, including exercise (min/wk, kcal/kg/hr, kcal/day), exercise volume, change in leisure-time physical activity, and exercise tolerance (Figure 13). At the end of intervention, there was a statistically significant difference in favor of the lifestyle intervention (standardized MD [SMD] = 0.45; 95% CI: 0.20, 0.71, I^2^ = 68%). Post hoc sensitivity analyses did not show any substantial difference between lifestyle interventions that did and did not include medication as part of the intervention (data not shown).

Figure 13 Effect of lifestyle interventions vs. control on physical activity outcomes: patients with type 2 diabetes

Figure 13 displays a forest plot of studies reporting a standardized mean difference of physical activity outcomes, lifestyle interventions vs. control in patients with type 2 diabetes. This figure is described further in the Section entitled “Change in physical activity” as follows: “Seven studies reported changes in physical activity using different outcome measures, including exercise (min/wk, kcal/kg/hr, kcal/day), exercise volume, change in leisure-time physical activity, and exercise tolerance (Figure 13). At the end of intervention, there was a statistically significant difference in favor of the lifestyle intervention (SMD = 0.45; 95% CI: 0.20, 0.71, I2 = 68%). At 6 months postintervention, the pooled difference was still statistically significant (SMD = 0.50; 95% CI: 0.10, 0.89, I2 = 74%). Similarly at 1 and 2 years, the difference reported in two studies was statistically significant (SMD = 0.53; 95% CI: 0.44, 0.61; SMD = 0.41; 95% CI: 0.16, 0.67 respectively). In the Steno-2 study by Gaede et al., the difference between groups was not statistically significant at any timepoint. “

At 6 months postintervention, the pooled difference was still statistically significant (SMD = 0.50; 95% CI: 0.10, 0.89, I^2^ = 74%). Similarly at 1 and 2 years, the difference reported in two studies112,115 was statistically significant (SMD = 0.53; 95% CI: 0.44, 0.61; SMD = 0.41; 95% CI: 0.16, 0.67, respectively). In the Steno-2 study by Gaede et al.,119 the difference between groups was not statistically significant at any timepoint.

Change in dietary or nutrient intake. The change in dietary or nutrient intake was measured by energy intake and consumption of saturated fat. The pooled results of four studies110,111,113,118 that reported energy intake at the end of the intervention showed a statistically significant difference in favor of the lifestyle intervention (SMD = −0.17, 95% CI: −0.33, −0.01; I^2^ = 0%; Figure 14). A post hoc sensitivity analysis did not show any substantial difference between lifestyle interventions that did and did not include medication as part of the intervention (data not shown).

Figure 14 Effect of lifestyle interventions vs. control on energy intake: patients with type 2 diabetes

Figure 14 displays a forest plot of studies reporting a standardized mean difference of energy intake, lifestyle interventions vs. control in patients with type 2 diabetes. This figure is described further in the Section entitled “Change in dietary or nutrient intake” as follows: “The change in dietary or nutrient intake was measured by energy intake and consumption of saturated fat. The pooled results of four studies that reported energy intake at the end of the intervention showed a statistically significant difference in favor of the lifestyle intervention (SMD = −0.17, 95% CI: −0.33, −0.01, I2 = 0%; Figure 14). In one trial with 6 month postintervention followup, the difference was no longer significant. The Steno-2 trial found no significant difference between the lifestyle and control groups at 4 and 8 years.”

In one trial113 with 6 month postintervention followup, the difference was no longer significant. The Steno-2 trial found no significant difference between the lifestyle and control groups at 4 and 8 years (Figure 14).

Five studies assessed change in saturated fat consumption (Figure 15).111,113,115,118,119 Immediately postintervention, there was no significant difference between groups (SMD = −0.31; 95%CI: −0.68, 0.07, I^2^ = 79%). A post hoc sensitivity analysis did not show any substantial difference between lifestyle interventions that did and did not include medication as part of the intervention (data not shown). At all followup timepoints, there was a significant difference in favor of lifestyle interventions.

Figure 15 Effect of lifestyle interventions vs. control for consumption of saturated fat: patients with type 2 diabetes

Figure 15 displays a forest plot of studies reporting a standardized mean difference of consumption of saturated fat, lifestyle interventions vs. control in patients with type 2 diabetes. This figure is described further in the Section entitled “Change in dietary or nutrient intake” as follows: “Five studies assessed change in saturated fat consumption. Immediately postintervention, there was no significant difference between groups (SMD = −0.31; 95%CI: −0.68, 0.07, I2 = 79%). However, at all followup timepoints, there was a significant difference in favor of lifestyle interventions.”

Change in medications. Two studies113,119 reported use of medication. The different types of medication were oral hypoglycemic agents (OHA), insulin, OHA plus insulin, antihypertensive agents, and lipid-lowering agents. Both studies included medication use as part of their lifestyle interventions.

OHA. There was no significant difference between groups in the Steno-2 trial by Gaede et al.119 at 4 years (RR = 0.79; 95% CI: 0.55, 1.14) or 8 years (RR = 1.24; 95% CI: 0.97, 1.58). At baseline, 59 percent and 60 percent of participants in the intervention and control groups, respectively, were taking OHA. At 8 years, 75 percent in the lifestyle group were taking OHA compared with 60 percent in the control group. However, at 13.3 years, there was a significant difference between groups favoring usual care (RR = 1.77; 95% CI: 1.24, 2.52). While 84 percent of participants in the intervention group were taking an OHA, only 38 percent were taking some form of OHA in the usual care group.

Menard et al.113 presented use of OHA by the number of people taking one OHA, two OHAs, or three or more OHAs. In total, all participants in the lifestyle group and 91 percent in the control group were taking at least one OHA at baseline. There was no statistically significant change from baseline to the end of intervention or 6 months postintervention in use of OHAs for any of the groups. At the end of intervention, the RR for one OHA was 2.23 (95% CI: 0.96, 5.19); for two OHAs it was 0.77 (95% CI: 0.52, 1.14); and for three or more, the RR was 0.51 (95% CI: 0.05, 5.42). At 6 months, the RRs were 2.54 (95% CI: 1.04, 6.17), 0.69 (95% CI: 0.46, 1.04) and 0.60 (95% CI: 0.11, 3.36), respectively.

Insulin. The Steno-2 trial119 showed a significant decrease in insulin use in the lifestyle group after 4 years. At baseline, 6 percent and 13 percent of participants in the intervention and control groups were taking insulin. At the end of 4 years, 16 percent in the intervention group compared with 37 percent in the control group were taking insulin (RR = 0.45; 95% CI: 0.25, 0.81). However, by the end of 8 years, there was no statistically significant difference (RR = 1.05; 95% CI: 0.77, 1.43). This did not change at 13.3 years (RR = 0.89; 95% CI: 0.71, 1.11).

Menard et al.113 found no statistically significant difference between groups at the end of intervention or at the end of the 6 month followup (RR = 0.51; 95% CI: 0.10, 2.63 and RR = 0.68; 95% CI: 0.17, 2.78, respectively).

OHA plus insulin. In the Steno-2 trial,119 a statistically significant decrease of OHA plus insulin use was found in the usual care group at the end of 4 years. At baseline, none of the participants in the intervention group and only one participant in the control group were taking both types of medication. At 4 years, 38 percent of the people in the intervention group were taking both OHA and insulin, while only 5 percent in the control group were taking both medications (RR = 7.29; 95% CI: 2.69, 19.75). By the end of 8 years, there was no longer a significant difference between groups and 33 percent of participants in the intervention group and 21 percent of participants in the control group were taking both (RR = 1.59; 95% CI: 0.88, 2.88). However, by 13.3 years, the significant difference seen at 4 years in favor of usual care reappeared (RR = 1.99; 95% CI: 1.34, 2.94).

Menard et al.113 showed no significant differences between groups at both end of intervention and followup. At baseline, 35 percent and 23 percent of the participants in the intervention and control groups were taking both medications. At the end of intervention, the proportion of people taking both increased to 62 percent and 83 percent (RR = 2.16; 95% CI: 1.20, 3.89). By the end of the 6 month followup, 59 percent and 34 percent people were taking both OHA and insulin in the intervention and control group, respectively (RR = 1.72; 95% CI: 0.97, 3.07).

Antihypertensive agents. The Steno-2 trial119 showed a statistically significant increase in the lifestyle group at 4 and 8 years (RR = 1.54; 95% CI: 1.29, 1.84 and RR= 1.19; 95% CI: 1.06, 1.34, respectively). At baseline, 41 percent of the patients in both the lifestyle and control groups were taking an antihypertensive agent. At 8 years, 99 percent in the lifestyle group and 83 percent in the control group were taking this medication. However, at 13.3 years, this difference was no longer seen (RR = 0.93; 95% CI: 0.86, 1.01).

Menard et al.113 found no statistically significant difference between groups at the end of intervention or at 6 months followup (RR = 1.03; 95% CI: 0.77, 1.38 and RR = 0.91; 95% CI: 0.70, 1.18, respectively).

Lipid-lowering agents. The Steno-2 trial119 showed a statistically significant increase in use of antihypertensive agents in use of lipid-lowering agents in the lifestyle group at both 4 years and at 8 years (RR = 6.07; 95% CI: 2.72, 13.57 and RR = 3.26; 95% CI: 2.15, 4.95, respectively). At baseline, 4 percent in the intervention group and 1 percent in the control group were taking a statin, fibrate, or both. At 4 years, 48 percent in the lifestyle group compared with 8 percent in the control group were taking a lipid-lowering agent. At 8 years, 88 percent and 27 percent of the participants in the intervention and control groups respectively were taking a lipid-lowering agent. No data were reported for the 13.3 year followup.

The study by Menard et al.113 also reported a statistically significant increase in the use of lipid-lowering agents in the lifestyle group at both end of intervention and 6 month followup (RR = 1.99; 95% CI: 1.32, 2.99 and RR = 2.11; 95% CI: 1.34, 3.32, respectively). At baseline, 35 percent in the lifestyle group were taking a statin, fibrate, or both compared with 43 percent in the control group. At the end of intervention, 85 percent of the lifestyle group compared with 43 percent of the control group was taking a lipid-lowering agent. At the 6 month followup, 88 percent of the lifestyle group compared with 41 percent of the control group was taking a lipid-lowering medication.

Compliance with the intervention. The number of dropouts/withdrawals was used as a surrogate measure for compliance. Overall, there were more dropouts in the usual care groups compared with lifestyle interventions; however, this was not statistically significant (RR = 0.86; 95% CI: 0.61, 1.22, I^2^=52%).

Adverse events. Two studies reported that participants experienced minor hypoglycemic episodes113 and bleeding gastric ulcer;119 however, these adverse events were not directly attributed to the exercise, diet, or other component of the lifestyle intervention.

### Summary

Ten RCTs assessed the effectiveness of lifestyle interventions for type 2 diabetes. The following is a summary of results:

- Primary outcomes. One study, which included medication as part of the lifestyle intervention, found that the intervention decreased the number of nonfatal strokes, nonfatal myocardial infarctions, amputations, and death at 13.3 year followup. There was also a difference between groups for the progression of autonomic neuropathy in favor of the lifestyle intervention, but no difference was seen in the progression of peripheral neuropathy at all followup time points. The strength of evidence for all of these outcomes was insufficient.
- Change in body composition. Five studies reported change in weight. At the end of intervention, there was a statistically significant difference in favor of lifestyle interventions and no difference between the groups at 6 month followup. Five studies reported change in BMI (kg/m^2^). At the end of the intervention, there was a statistically significant difference in favor of the lifestyle intervention. Effect of the intervention at different postintervention timepoints was inconsistent. The strength of evidence was moderate for BMI and weight change at end of intervention. The strength of evidence was insufficient at all followup timepoints.
- Change in metabolic variables. Ten studies reported on changes in metabolic variables. For lifestyle interventions that did not include medication as part of the intervention, there was no statistically significant difference between groups for any of the metabolic variables at the end of intervention. For lifestyle interventions that included medication, the results were statistically significant in favor of lifestyle for fasting plasma glucose, HDL cholesterol, and HbA1c. The strength of evidence was low for all outcomes immediately postintervention, and insufficient at all followup timepoints.
- Systolic and diastolic blood pressure. Eight studies reported changes in systolic and diastolic blood pressure (mmHg). For lifestyle interventions that did not include medication as a component, there was no statistically significant difference between groups for either outcome at the end of intervention. For lifestyle interventions that included medication, the results were statistically significant in favor of lifestyle for diastolic, but not systolic blood pressure. Effect of the intervention at different followup timepoints was inconsistent. The strength of evidence is low for the end of intervention timepoint; it is insufficient for all followup timepoints.
- Change in physical activity. Seven studies reported changes in physical activity using different outcome measures. At the end of intervention, there was a statistically significant difference in favor of the lifestyle intervention. There was a significant difference between groups at 1 and 2 years of followup. The strength of evidence was low for the end of intervention and at 6 month followup, but insufficient at other postintervention timepoints.
- Change in dietary or nutrient intake. Four studies measured change in dietary or nutrient intake using energy intake and consumption of saturated fat. There was a significant difference in energy intake favoring the lifestyle intervention at end of intervention. There was no difference between groups at any followup timepoint. There was no significant difference between groups in consumption of saturated fats at end of intervention. However, the lifestyle intervention is favored at all followup timepoints. The strength of evidence is low for energy intake and low for consumption of saturated fat at end of intervention. It is insufficient for all other timepoints.
- Change in medications. While nine studies reported medication use at baseline, only two reported followup data. At the longest followup timepoints, either the usual care group was favored or there was no significant difference between groups. The lifestyle intervention was favored in the use of insulin at end of intervention and 4 years. At 8 and 13 year followup, there was no difference between groups.
- Compliance with intervention. Seven studies reported withdrawals by group. There was no statistically significantly difference between groups.
- Adverse events. No studies reported adverse events directly attributed to the exercise, diet, or other component of the lifestyle intervention.
- Two RCTs were considered at high risk of bias; eight were unclear. The most common source of potential bias was inadequate blinding.

### Metabolic Syndrome

#### Description of Included Studies

Four RCTs122,123,125,126 met our a priori inclusion criteria. The duration of the interventions ranged from 6 to 72 months, with followup periods ranging from 3 to 20 years. We also included three studies that had long-term interventions of at least 12 months but with no postintervention followup period.120,121,124 There were 34 associated publications.149–181 The duration of these interventions ranged from 12 to 36 months. For all seven studies, the number of participants randomized ranged from 39 to 3,234 (median = 375; IQR: 113, 437). The mean age ranged from 44 to 85 years. BMI ranged from 26.2±3.9 to 38.3±5.9.

All studies included a diet and exercise component plus at least one additional component (Table 5). These included both individual and group counseling,121–123,125,126 individual counseling,124 group counseling,120 behavior modification,120,122 a smoking cessation program,121,123 regular telephone contact,122,123 individual goal setting,125 and cooking lessons.123 The interventions were delivered by dieticians,120–125 exercise advisors,122,123 physiotherapists,124 nurse managers,122,123 nurses,125,126 physicians,122,123,126 endocrinologists,125 psychologists,122 and technicians.126 One study had medication use as an intervention component.

Table 5 Descriptions of lifestyle interventions: metabolic syndrome

Studies with postintervention followup
Author, Year | Duration of study; Duration of followup | Diet | Exercise | Counseling or other component(s) | Control group
Bo, 2007^125^ | 12 mo, 3 yr | - Followed NIH Guidelines; - Recommended daily caloric distribution; - Individualized, written recommendations from trained professionals; food pyramid; individual goals | - 150 min/wk moderate PA; - Individualized, written recommendations; individual goals | - Individual counseling: 1 session by trained professional; - Group counseling: 4 group sessions by trained professional on behavioral counseling & lifestyle tips | - Usual/standard care provided by family physician
Diabetes Prevention Program Research Group, 2002, DPP122 | 12 mo; 10 yr | - Followed Food Pyramid Guidelines; - Goal to achieve & maintain wt loss of 7% in first 24 wk; - Low fat, low calorie diet; - $100/yr for “tool kit” with cookbook, grocery vouchers; - Logbook, telephone contact, personal interview | - 150 min/wk moderate PA; - Strength training: max 75 min/wk could apply to 150 min/wk; - Clinic supervised sessions twice/wk; activity varied; - Logbook, personal interview, weighed at every session | - Individual counseling: case manager trained in nutrition, exercise or behavior modification; 16 sessions using curriculum for 1^st^ 24 wk then at least once every 2 mo; - Group counseling: case manager; quarterly for 4–8 wk courses. | - Standard diet and exercise advice
Eriksson, 1999, FDPS123 | 4 yr; 6.6 yr | - Wt loss of ≥ 5% or goal BMI of ≤ 25 kg/m2; - Emphasis on decreased SFA, increased fiber to >15g/1000 kcal; - If no wt loss in 6–12 mo, low calorie diet with group meetings was considered; - Detailed advice, printed material to illustrate messages and serve as reminders; - Logbook, telephone, progress reports, wt measured/3 mo | - >30 min/d moderate PA; - Nutritionist counseled on PA at visits, reinforced by physician annually; offered supervised progressive resistance training twice/wk; - Voluntary group walking and hiking; - Telephone contact, progress reports | - Individual counseling: nutritionist; 7 sessions for 1^st^ yr then every 3 mo; - Group counseling: voluntary group sessions with a nutritionist; included expert lectures, low fat cooking lessons, visits to supermarkets; - Encouraged to quit smoking | - Attention control; - Written and oral information on diet and exercise; - Completed food diaries prior to annual visits; - Advised to decrease energy intake to decrease BMI below 25 kg/m2 with <30% daily energy from fat; - Advised to decrease alcohol and smoking as appropriate; - General information on benefits of recreational exercise; - Annual visits
Pan, 1997, Da Qing126 | 6 yr; 14 yr | - Those with BMI ≥ 25 kg/m^2^ to reduce caloric intake to lose wt at rate of 0.5–1.0 kg/mo to goal BMI of 23 kg/m^2^; - Those with BMI < 25 kg/m^2^ to eat more vegetables, limit alcohol, reduce simple sugars; - List of commonly used foods and substitution list provided | - Increased leisure PA by at least 1 unit/d or 2 units/d if < 50 yr | - Individual counseling by physician; individual counseling on daily food intake; - Individual goal setting for diet and exercise; - Group counseling: all met in small groups (decreasing frequency over time) | - Attention control; - Information about diabetes and IGT provided; - Given information brochures with general instructions for diet and/or increased leisure PA
Studies with no postintervention followup
Mensink, 2003, SLIM Trial121 | 3 yr; 0 | - Followed Dutch Nutrition Council guidelines; - Emphasis on decreasing SFA intake; - Wt loss of 5–7%; - Log book, 3 d food diary/3 mo; - Reduced alcohol intake | - Followed ACSM recommendation: 30 min moderate PA/d, 5 d/wk; - Encouraged to attend group exercise sessions; - Log book, attendance, asked to participate in program with HR monitor 3 x/yr, 3 d diary/3 mo | - Individual counseling: dietician every 3 mo; - Group counseling: dietician at 9, 21, 33 mo; - Encouraged to quit smoking | - Attention control; - Oral and written information on healthy diet, wt loss, and increasing PA
Oldroyd, 2001^124^ | 2 yr; 0 | - Followed British Diabetic Association guidelines; - Encouraged to decrease fat and sugar and increase F&V and fiber intake; - Overweight subjects were encouraged to decrease BMI to < 25 kg/m^2^; - Educational material, personal interview | - Graded PA plan designed to achieve 20–30 min aerobic activity 2–3 x/wk; - Information on exercise facilities provided; City Card offered (up to 80% discount on use of public leisure facilities) | - Individual counseling: dietitian and physiotherapist; 12 review appointments over 24 mo (gradually decreased frequency of appointments over time) | - Usual/standard care by primary care physician; - Asked to live normal day-to-day life during the study
Pinkston, 2006^120^ | 12 mo; 0 | - Followed LIFESTEPSr: your personal plan for weight management, 3^rd^ edition, 1998, Dairy Council of Utah, Nevada; - Encouraged to decrease calories by at least 500 kcal/d; - Goal wt loss 1 lb/wk; - Fat intake was 30% of total daily calories; - Meal demonstrations of modified traditional foods; - Weekly food diary | - Goal to increase PA to 5 x/wk for 30 min for total of ≥ 150 min/wk; - Encouraged to use walking as primary form of PA; - Suggestions provided (e.g.: using stairs, taking short walks); - Exercise contracts used to promote PA; - Incentives provided for motivation | - Group counseling: bilingual dietician; 24 weekly classes for 1 hr, then gradual tapering of classes; - Included problem-solving and role-playing of behavioral change skills (e.g.: identifying difficult eating situations, setting exercise objectives); - Instructed to take 120 mg of orlistat 3 times/d with meals, 1 vitamin/mineral capsule daily | - Wait-list control

BMI = body mass index; CHO =carbohydrate; d = day(s); DPP = Diabetes Prevention Program; F&V = fruits and vegetables; FDPS = Finnish Diabetes Prevention Study; hr = hour(s); kcal = kilocalories; lb = pound(s); max = maximum; meds = medications; min = minute(s); mo = month(s); NIH = National Institutes of Health; PA = physical activity; SLIM = Study on Lifestyle Intervention and Impaired Glucose Tolerance Maastricht; SFA = saturated fatty acids; wk = week(s); wt = weight; × = times

#### Methodological Quality

The methodological quality of the RCTs is summarized in Table 6. Three studies120–122 were assessed as having a high risk of bias and four123–126 an unclear risk of bias. All seven studies were RCTs, and only two120,126 did not describe the method by which participants were randomized to groups. Allocation was concealed in only two studies.123,125 All but one study126 were at high or unclear risk of bias for lack of blinding for subjective or self-reported outcomes (e.g., number of hours of exercise per week). One study122 stated that the allocation to metformin or placebo was double blinded; however, we did not extrapolate this double blinding to the diet and exercise components of the intervention. Three studies121–123 were at unclear risk of bias for incomplete outcome data; the remaining studies120,124–126 had low risk of bias for this domain. There was no evidence of selective outcome reporting. Two studies120,122 received funding from industry. Three studies received funding from foundations,121–123 one from the World Bank,126 and three from government.120,122,123 Two studies124,125 did not report funding.

Table 6 Risk of bias assessment for studies of metabolic syndrome

Author Year | Sequence generation | Allocation concealment | Blinding: Objective outcomes | Blinding: Self-reported outcomes | Incomplete outcome data | Selective outcome reporting | Other sources: Baseline imbalance | Other sources: Funding | Overall risk of bias
Bo 2007^125^ | Low | Low | Low | Unclear | Low | Low | Low | Low | Unclear
DPP Research Group 2002^122^ | Low | Unclear | Low | Unclear | Unclear | Low | Low | High | High
Eriksson 1999^123^ | Low | Low | Low | Unclear | Unclear | Low | Low | Low | Unclear
Mensink 2003^121^ | Low | Unclear | Low | High | Unclear | Low | Low | Low | High
Oldroyd 2001^124^ | Low | Unclear | Low | Unclear | Low | Low | Low | Low | Unclear
Pan 1997^126^ | Unclear | Unclear | Low | Low | Low | Low | Low | Low | Unclear
Pinkston 2006^120^ | Unclear | Unclear | Low | High | Low | Low | Unclear | High | High

High = high risk of bias; Low = low risk of bias; Unclear = unclear risk of bias

#### Results

Primary Outcomes. Our primary outcomes were CVD complications, and development of type 2 diabetes. Four studies122,123,125,126 reported data for at least one of these outcomes. No studies reported nonfatal myocardial infarction or nonfatal stroke.

Cardiovascular disease complications. Two studies123,126 reported CVD events. The Finnish Diabetes Prevention Study (FDPS)123 by Eriksson et al. reported that at 10 years postintervention there was no statistically significant difference between the lifestyle and usual care groups (RR = 1.02; 95% CI: 0.73, 1.42). There were 57/257 (22 percent) CVD events in the intervention group compared with 54/248 (22 percent) in the control group. The Da Qing Diabetes Prevention Trial126 reported any first CVD event at 6 and 20 years of followup. There were no statistically significant differences between the groups at either timepoint (HR = 0.96; 95% CI: 0.76–1.44 and HR = 0.98; 95% CI: 0.71–1.37, respectively).

Development of type 2 diabetes. Four studies122,123,125,126 reported the development of type 2 diabetes. Bo et al.125 found a significant difference in favor of the lifestyle intervention at both end of intervention (RR = 0.25; 95% CI: 0.07, 0.85) and at the 4 year followup (RR = 0.44; 95% CI: 0.21, 0.94). There were 3/169 (2 percent) individuals who developed type 2 diabetes in the intervention group compared with 12/166 (7 percent) in the usual care group at the end of intervention; while at 4 years, 9/169 (5.4 percent) individuals in the intervention group and 20/166 (10.2 percent) in the control group developed diabetes. The Da Qing study126 also reported a significant difference in favor of the lifestyle intervention at both 6 and 20 years (HR = 0.49; 95% CI: 0.33, 0.73 and HR = 0.57; 95% CI: 0.41, 0.81, respectively). The hazard ratios combined several intervention groups, therefore the results for our primary outcomes included a lifestyle intervention with both diet and exercise components, a diet only intervention, and an exercise only intervention. The FDPS by Eriksson et al.123 showed a significant difference in favor of lifestyle intervention at both end of intervention and 6 years (10 year data were not reported). There were 5/265 (2 percent) in the intervention group that developed type 2 diabetes compared with 16/257 (6 percent) in the usual care group. At 6 years, this rose to 27/265 (10 percent) and 59/257 (23 percent), respectively. The Diabetes Prevention Program (DPP) by Knowler et al.122 also found a significant difference between the intervention and usual care groups at both 4 years (210/1,079, 19 percent and 375/1,082, 35 percent, respectively) and 10 years (465/1,079, 43 percent and 580/1,082, 54 percent).

Figure 16 Effect of lifestyle interventions vs. control on development of diabetes: patients with metabolic syndrome

Figure 16 displays a forest plot of studies reporting a risk ratio of development of diabetes, lifestyle interventions vs. control in patients with metabolic syndrome. This figure is described further in the Section entitled “Development of type 2 diabetes” as follows: “Four studies reported the development of type 2 diabetes. Bo et al. found a significant difference in favor of the lifestyle intervention at both end of intervention (RR = 0.25; 95% CI: 0.07, 0.85) and at the 4 year followup (RR = 0.44; 95% CI: 0.21, 0.94). There were 3/169 (2 percent) individuals who developed type 2 diabetes in the intervention group compared with 12/166 (7 percent) in the usual care group at the end of intervention; while at 4 years, 9/169 (5.4 percent) individuals in the intervention group and 20/166 (10.2 percent) in the control group developed diabetes. The Da Qing study also reported a significant difference in favor of the lifestyle intervention at both 6 and 20 years (HR = 0.49; 95% CI: 0.33, 0.73 and HR = 0.57; 95% CI: 0.41, 0.81, respectively). The hazard ratios combined several intervention groups, therefore the results for our primary outcomes included a lifestyle intervention with both diet and exercise components, a diet only intervention, and an exercise only intervention. The FDPS by Eriksson et al. showed a significant difference in favor of lifestyle intervention at both end of intervention and 6 years (10 year data were not reported). There were 5/265 (2 percent) in the intervention group that developed type 2 diabetes compared with 16/257 (6 percent) in the usual care group. At 6 years, this rose to 27/265 (10 percent) and 59/257 (23 percent), respectively. The Diabetes Prevention Program (DPP) by Knowler et al. also found a significant difference between the intervention and usual care groups at both 4 years (210/1,079, 19 percent and 375/1,082, 35 percent, respectively) and 10 years (465/1,079, 43 percent and 580/1,082, 54 percent).”

Death. Two studies123,126 reported the number of deaths. The FDPS123 reported no difference between the groups at 10 years (RR = 0.58; 95% CI: 0.21, 1.57). There were 6/257 deaths in the lifestyle group and 10/248 in the usual care group. The Da Qing study126 found no difference between groups for CVD mortality at 20 years (HR = 0.83; 95% CI: 0.48, 1.40). There were no deaths in either group at 6 years. There were no differences for all-cause mortality at either timepoint (HR = 1.33; 95% CI: 0.45, 3.92 and HR = 0.96; 95% CI: 0.65, 1.41, respectively).

Secondary Outcomes. Change in body composition. There were 6 studies120–122,124–126 that reported weight (lbs) at the end of intervention (Figure 17). The pooled MD was −7.80 (95% CI: −11.92, −3.67, I^2^=78%). At 4 years postintervention, Bo et al.125 reported a statistically significant difference between groups in favor of the lifestyle intervention (MD = −5.56; 95% CI: −7.92, −3.20). At 4 years postintervention the DPP Study by Knowler et al.122 also reported a statistically significant difference between groups in favor of the lifestyle intervention (MD = −7.68, 95% CI: −13.27, −2.09). At 10 years, the difference between groups had disappeared. We conducted a post hoc sensitivity analysis to assess the impact of medication use on changes in body composition in the study by Pinkston et al.120 and found no statistically significant differences.

Figure 17 Effect of lifestyle interventions vs. control on weight change (lbs): patients with metabolic syndrome

Figure 17 displays a forest plot of studies reporting a mean difference of weight change (lbs), lifestyle interventions vs. control in patients with metabolic syndrome. This figure is described in the Section entitled “Change in body composition” as follows: “There were 6 studies that reported weight (lbs) at the end of intervention. The pooled MD was −7.80 (95% CI: −11.92, −3.67, I2=78%). At 4 years postintervention, Bo et al. reported a statistically significant difference between groups in favor of the lifestyle intervention (MD = −5.56; 95% CI: −7.92, −3.20). At 4 years postintervention the DPP Study by Knowler et al. also reported a statistically significant difference between groups in favor of the lifestyle intervention (MD = −7.68, 95% CI: −13.27, −2.09). At 10 years, the difference between groups had disappeared. We conducted a post hoc sensitivity analysis to assess the impact of medication use on changes in body composition in the study by Pinkston et al. and found no statistically signficant differences.”

The FDPS by Eriksson et al.123 reported whether participants achieved the goal of losing five percent or more of their body weight. The difference between the lifestyle and control groups was statistically significant in favor of the lifestyle intervention (MD = 3.35; 95% CI: 2.37, 4.74).

BMI (kg/m^2^) was reported in four studies120,121,123,125 (Figure 18). At the end of the intervention, the pooled MD was statistically significant in favor of the lifestyle group (MD = −0.95; 95% CI: −1.49, −0.41; I^2^ = 46%). At 4 years, Bo et al.125 reported a statistically significant difference that favored the lifestyle intervention (MD = −0.92; 95% CI: −1.32, −0.53).

Figure 18 Effect of lifestyle interventions vs. control on BMI (kg/m^2^): patients with metabolic syndrome

Figure 18 displays a forest plot of studies reporting a mean difference of BMI (kg/m2), lifestyle interventions vs. control in patients with metabolic syndrome. This figure is described further in the Section entitled “Change in body composition” as follows: “BMI (kg/m2) was reported in four studies. At the end of the intervention, the pooled MD was statistically significant in favor of the lifestyle group (MD = −0.95; 95% CI: −1.49, −0.41, I2 = 46%). At 4 years, Bo et al. reported a statistically significant difference that favored the lifestyle intervention (MD = −0.92; 95% CI: −1.32, −0.53).”

Waist circumference was another outcome that measured change in body composition and was reported in five studies120,121,123–125 (Figure 19). The pooled MD −3.73 (95% CI: −4.87, −2.59, I^2^ = 11%). At 4 years, the difference had decreased, however, it was still statistically significant in favor of the lifestyle intervention (MD = −1.86, 95% CI: −3.49, −0.22).

Figure 19 Effect of lifestyle interventions vs. control on change in waist circumference (cm): patients with metabolic syndrome

Figure 19 displays a forest plot of studies reporting a mean difference of waist circumference (cm), lifestyle interventions vs. control in patients with metabolic syndrome. This figure is described further in the Section entitled “Change in body composition” as follows: “Waist circumference was another outcome that measured change in body composition and was reported in five studies. The pooled MD −3.73 (95% CI: −4.87, −2.59, I2 = 11%). At 4 years, the difference had decreased, however, it was still statistically significant in favor of the lifestyle intervention (MD = −1.86, 95% CI: −3.49, −0.22).”

Change in metabolic variables. Seven studies reported on changes in different metabolic variables, including fasting plasma glucose121–125 (Figure 20), triglycerides120,121,123,125 (Figure 21), total cholesterol120,121,123–125 (Figure 22), HDL120,121,123,125 and LDL cholesterol120,121,124 (Figure 23, Figure 24), and HbA1c110–119 (Figure 25). In general, lifestyle interventions appear to improve metabolic variables more than usual care, although the differences were not always statistically significant. The changes in metabolic variables were sustained at 4 years of followup. However, at 10 years of followup, the DPP study reported that usual care was more effective in lowering fasting plasma glucose compared with the lifestyle intervention (RR = 0.10; 95% CI: 0.03, 0.18). At 10 years, the lifestyle intervention was more effective than usual care in controlling HbA1c (RR = −0.05; 95% CI: −0.09, −0.02).

Figure 20 Effect of lifestyle interventions vs. control on fasting plasma glucose (mmol/l): patients with metabolic syndrome

Figure 20 displays a forest plot of studies reporting a mean difference of fasting plasma glucose (mmol/l), lifestyle interventions vs. control in patients with metabolic syndrome. Five studies reported this outcome. Though a positive difference was seen at the end of intervention (MD = −0.29; 95%CI: −0.35, −0.23; I2 = 12%) as well as followup at 4 years (MD = −0.35; 95%CI: −0.41, −0.29), a significant difference favoring the control group was seen at 10 years followup (MD = 0.10; 95%CI: 0.03, 0.18).

Figure 21 Effect of lifestyle interventions vs. control on triglycerides (mmol/l): patients with metabolic syndrome

Figure 21 displays a forest plot of studies reporting a mean difference of triglycerides (mmol/l), lifestyle interventions vs. control in patients with metabolic syndrome. Four studies reported this outcome. No difference was seen between groups at any of the timepoints.

Figure 22 Effect of lifestyle interventions vs. control on total cholesterol (mmol/l): patients with metabolic syndrome

Figure 22 displays a forest plot of studies reporting a mean difference of total cholesterol (mmol/l), lifestyle interventions vs. control in patients with metabolic syndrome. Five studies reported total cholesterol. No difference was seen between groups.

Figure 23 Effect of lifestyle interventions vs. control on HDL cholesterol (mmol/l): patients with metabolic syndrome

Figure 23 displays a forest plot of studies reporting a mean difference of HDL cholesterol (mmol/l), lifestyle interventions vs. control in patients with metabolic syndrome. Four studies reported HDL cholesterol. A favorable difference was seen at the end of intervention (MD = 0.08; 95%CI: 0.05, 0.10; I2 = 0%); however, there was no difference between groups at 3 years of followup (MD = 0.05; 95%CI: 0.00, 0.10).

Figure 24 Effect of lifestyle interventions vs. control on LDL cholesterol (mg/dl): patients with metabolic syndrome

Figure 24 displays a forest plot of studies reporting a mean difference of LDL cholesterol (mg/dl), lifestyle interventions vs. control in patients with metabolic syndrome. Three studies reported this outcome. No difference was seen between groups.

Figure 25 Effect of lifestyle interventions vs. control on HbA1c (%): patients with metabolic syndrome

Figure 25 displays a forest plot of studies reporting a mean difference of HbA1c (%), lifestyle interventions vs. control in patients with metabolic syndrome. Two studies reported HbA1c. Though no difference was seen at the end of intervention (MD = −0.10; 95%CI: −0.28, 0.08; I2 = 81%), differences between groups were seen at the 4 year followup (MD = −0.15; 95%CI: −0.20, −0.10) and 10 year followup (MD = −0.05; 95%CI: −0.09, −0.02).

Systolic and diastolic blood pressure. Changes in systolic and diastolic blood pressure (mmHg) were reported in five studies.120–123,125 There was a statistically significant difference between groups for both systolic blood pressure (MD = −3.17; 95% CI: −5.02, −1.33; I^2^ = 27%) and diastolic blood pressure (MD = −2.70; 95% CI: −3.21, −2.18; I^2^ = 0%) at the end of intervention (Figure 26 and Figure 27). At the followup timepoint, there was still a statistically significant difference seen for both systolic (MD = −4.41; 95% CI: −8.47, −0.35) and diastolic (MD = −1.88; 95% CI: −2.65, −1.12) blood pressure.

Figure 26 Effect of lifestyle interventions vs. control on systolic blood pressure: patients with metabolic syndrome

Figure 26 displays a forest plot of studies reporting a mean difference of systolic blood pressure (mmHg), lifestyle interventions vs. control in patients with metabolic syndrome. This figure is described further in the Section entitled “Systolic and diastolic blood pressure” as follows: “Changes in systolic and diastolic blood pressures (mmHg) were reported in five studies. Two studies showed a difference at the end of intervention for systolic blood pressure and four studies had a difference between groups for diastolic blood pressure. However, there was a significant difference between groups overall for both systolic blood pressure (MD = −3.17; 95% CI: −5.02, −1.33; I2 = 27%) and diastolic blood pressure (MD = −2.70; 95% CI: −3.21, −2.18; I2 = 0%). At the followup timepoint, there was still a statistically significant difference seen for both systolic (MD = −4.41; 95% CI: −8.47, −0.35) and diastolic (MD = −1.88; 95% CI: −2.65, −1.12) blood pressure.”

Figure 27 Effect of lifestyle interventions vs. control on diastolic blood pressure: patients with metabolic syndrome

Figure 27 displays a forest plot of studies reporting a mean difference of diastolic blood pressure (mmHg), lifestyle interventions vs. control in patients with metabolic syndrome. This figure is described further in the Section entitled “Systolic and diastolic blood pressure” as follows: “Changes in systolic and diastolic blood pressures (mmHg) were reported in five studies. Two studies showed a difference at the end of intervention for systolic blood pressure and four studies had a difference between groups for diastolic blood pressure. However, there was a significant difference between groups overall for both systolic blood pressure (MD = −3.17; 95% CI: −5.02, −1.33; I2 = 27%) and diastolic blood pressure (MD = −2.70; 95% CI: −3.21, −2.18; I2 = 0%). At the followup timepoint, there was still a statistically significant difference seen for both systolic (MD = −4.41; 95% CI: −8.47, −0.35) and diastolic (MD = −1.88; 95% CI: −2.65, −1.12) blood pressure.”

Change in physical activity. Four studies122,124–126 reported on the change in general exercise (Figure 28). At the end of the intervention, all showed a statistically significant increase in exercise that favored the lifestyle intervention (SMD = 0.40; 95% CI: 0.20, 0.59, I^2^ = 66%). At 4 years postintervention, the DPP Research Group122 reported a statistically significant difference between the groups in favor of the lifestyle group (SMD = 0.23; 95% CI: 0.10, 0.35).

Figure 28 Effect of lifestyle interventions vs. control on change in physical activity: patients with metabolic syndrome

Figure 28 displays a forest plot of studies reporting a standardized mean difference of change in physical activity, lifestyle interventions vs. control in patients with metabolic syndrome. This figure is described further in the Section entitled “Change in physical activity” as follows: “Four studies reported on the change in general exercise. At the end of the intervention, all showed a statistically significant increase in exercise that favored the lifestyle intervention (SMD = 0.40; 95% CI: 0.20, 0.59, I2 = 66%). At 42 months postintervention, the DPP Research Group reported a statistically significant difference between the groups in favor of the lifestyle group (SMD = 0.23; 95% CI: 0.10, 0.35).”

Change in dietary intake. Four studies121,122,125,126 measured change in energy intake (Figure 29) and reported that participants in the lifestyle groups had a significantly lower energy intake at the end of the intervention compared with the usual care group (SMD = −0.23; 95% CI: −0.31, −0.16, I^2^ = 0%). All three studies that measured fiber intake reported that the lifestyle group had a higher fiber intake than the usual care group (SMD = 0.39; 95% CI: 0.21, 0.57, I^2^ = 0%) (data not shown). The FDPS123 by Eriksson et al. reported whether participants reached their goal of consuming at least 15 grams of fiber per 1000 kcal and found that significantly more participants in the lifestyle group achieved this goal compared with the usual care group (RR = 2.06; 95% CI: 1.40, 3.05).

Figure 29 Effect of lifestyle interventions vs. control on change in energy intake: patients with metabolic syndrome

Figure 29 displays a forest plot of studies reporting a standardized mean difference of change in energy intake, lifestyle interventions vs. control in patients with metabolic syndrome. This figure is described further in the Section entitled “Change in dietary intake” as follows: “Four studies measured change in energy intake and reported that participants in the lifestyle groups had a significantly lower energy intake at the end of the intervention compared with the usual care group (SMD = −0.23; 95% CI: −0.31, −0.16, I2 = 0%).”

Four studies121,124–126 assessed fat intake (Figure 30). The pooled difference was not statistically significant (SMD = −0.36; 95% CI: −0.74, 0.02, I^2^ = 82%). However, two studies121,125 reported saturated fat intake and found a statistically significant difference between the lifestyle and usual care group (SMD=−0.53; 95% CI: −0.73, −0.34, I^2^ = 0%).

Figure 30 Effect of lifestyle interventions vs. control on change in fat intake: patients with metabolic syndrome

Figure 30 displays a forest plot of studies reporting a standardized mean difference of change in fat intake, lifestyle interventions vs. control in patients with metabolic syndrome. This figure is described further in the Section entitled “Change in dietary intake” as follows: “Four studies assessed fat intake. The pooled difference was not statistically significant (SMD = −0.36; 95% CI: −0.74, 0.02, I2 = 82%). However, two studies reported saturated fat intake and found a statistically significant difference between the lifestyle and usual care group (SMD=−0.53; 95%CI: −0.73, −0.34, I2 = 0%).”

In the FDPS,123 the increase in vegetable consumption was significantly greater in the lifestyle intervention group at the end of intervention (RR = 1.16; 95% CI: 1.03, 1.32).

Change in medications. One study122 reported medication use. All groups increased their use of antidiabetic medication over 10 years but the lifestyle intervention group had a smaller increase in use compared with usual care. The lifestyle group also used fewer antihypertensive drugs compared with usual care, though this was not statistically significant. The lifestyle intervention group used significantly fewer lipid-lowering drugs than the usual care group, with a mean of 18.4 percent versus 22.7 percent, respectively (p = 0.02).

Compliance with the intervention. Compliance was measured by the number of dropouts/withdrawals. The FDPS123 was the only study that showed a statistically significant difference in favor of the lifestyle group (RR = 0.61; 95% CI: 0.41, 0.90). Five studies121,122,124–126 found no difference between groups. One study120 did not report withdrawal data. Overall, there was no statistically significant difference in dropout rates (RR = 0.92; 95% CI: 0.76, 1.11).

Adverse events. Two studies reported the following adverse events: fatty stool and related complications120 and gastrointestinal symptoms.122 The adverse events were not directly attributed to the exercise, diet, or other component of the lifestyle intervention.

#### Summary

Seven RCTs assessed the effectiveness of lifestyle interventions for metabolic syndrome. The following is a summary of results:

- Primary outcomes. Four studies assessed the primary outcomes of CVD complications, development of type 2 diabetes, and death. There were no significant differences between the groups except for the development of type 2 diabetes. Two long-term studies found that lifestyle interventions significantly decreased the risk of developing type 2 diabetes. The strength of evidence is moderate for development of type 2 diabetes at end of intervention and for followup timepoints. The strength of evidence is insufficient for CVD events and death.
- Change in body composition. Six studies reported weight (lbs) at the end of intervention. At 4 years postintervention, two studies reported a statistically significant difference between groups in favor of the lifestyle intervention. At 10 years, there was no longer a difference between groups. Four studies reported change in BMI (kg/m^2^). At both end of intervention and 4 years followup, there was a statistically significant difference between groups favoring the lifestyle intervention. Waist circumference was measured in five studies. The lifestyle group was favored at end of intervention and the 4 year followup. The strength of evidence is moderate for BMI, moderate for weight change, and moderate for waist circumference at end of intervention. The strength of evidence is low in weight change at 4 year followup. It is insufficient for BMI and waist circumference at followup.
- Change in metabolic variables. Six studies reported on changes in different metabolic variables. For fasting plasma glucose, the lifestyle group was significantly favored at end of intervention and at 4 year followup. At 10 years, there was a significant difference between groups favoring the usual care group. For HbA1C, the lifestyle group was significantly favored at both 4 and 10 year followup. For all other metabolic variables, there was no significant difference between groups at the followup timepoints. The strength of evidence is moderate for fasting plasma glucose and HDL cholesterol at end of intervention. It is low for LDL cholesterol, total cholesterol and triglycerides at end of intervention and is insufficient for HbA1c and impaired glucose at end of intervention. The strength of evidence is insufficient for all outcomes at all followup timepoints.
- Systolic and diastolic blood pressure. Five studies reported change in systolic and diastolic blood pressure (mmHg). There was a significant difference between groups for both systolic and diastolic blood pressure at the end of intervention. At the followup timepoint, there was still a difference seen for both systolic and diastolic blood pressure. The strength of evidence is moderate for end of intervention for both outcomes and low for 4 year followup.
- Change in physical activity. Four studies reported on the change in general exercise. At end of intervention and at 4 year followup, the lifestyle group was significantly favored. The strength of evidence is moderate at end of intervention and insufficient at 4 year followup.
- Change in dietary or nutrient intake. Four studies measured change in energy intake. The lifestyle group had a significantly lower energy intake at the end of the intervention compared with the usual care group. The lifestyle group also had significantly lower consumption of saturated fat compared with the usual care group. The strength of evidence is moderate for energy intake and low for saturated fat intake at end of intervention. There were no followup data for either of these outcomes.
- Change in medications. None of the studies reported use of diabetic medication.
- Compliance with intervention. Compliance was measured by the number of dropouts/withdrawals. One study that showed a statistically significant difference in favor of the lifestyle group while five studies found no difference between groups.
- Adverse events. No studies reported adverse events directly attributed to the exercise, diet, or other component of the lifestyle intervention.
- Three RCTs were considered to be at high risk of bias; four were unclear. The most common sources of potential bias were unclear concealment of allocation, inadequate blinding, and incomplete outcome data. Two studies received funding from industry.

Table 4 Description of studies and baseline characteristics of participants: metabolic syndrome

Studies with postintervention followup
Author, Year, Study name | Randomized (N); Withdrawals (N) | Age (mean ± SD); Males: N (%);Ethnicity | Socioeconomic status (%≤$20,000/yr income); Education (%≤ high school); Smokers (%) | Weight (kg); BMI (km/m^2^); Waist circumference (cm) | HbA1c (%); Plasma Fasting Glucose (mmol/l); Insulin resistance (HOMA-IR); Blood pressure (mmHg) | Number of medications; Type
Bo, 2007^125^ | I: 187;18 C: 188;22 | I: 55.7±5.7; 77 (41.4); 100 White C: 55.7±5.6; 79 (42.2); 100 White | I: NR; 92.9; 21.9 C: NR; 97.0; 21.7 | I: 81.7±14.9; 29.7±4.1; 99.6±11.6 C: 81.3±13.5; 29.8±4.6; 99.8±10.6 | I: NR; 5.8±0.8; 0.81±1.11; 142.6±14.1/88.2± 9.8 C: NR; 5.8±0.7; 0.84±1.33; 141.5±15.2/87.8± 9.5 | I: NR C: NR
DPP Research Group, 2002, DPP122 | I:1079;20 C:1082;16 Grp3: 1073; 16 | I: 50.6+11.3; 345 (32.0); 53.8 White, 18.8 Black, 27.4 Other C: 50.3+10.4; 335.0(31.0); 54.2 White, 20.3 Black, 25.5 Other Grp3: 50.9+10.3; 363 (33.8); 56.1 White, 20.6 Black, 23.3 Other | I: NR; NR; NR C: NR; NR; NR Grp3: NR; NR; NR Total ≤high school= 25.8 | I: 94.1±20.8; 33.9±6.8; 105.1±14.8 C: 94.3±20.2; 34.2±6.7; 105.2±14.3 Grp3: 94.3±19.9; 33.9±6.6; 104.9±14.4 | I: 5.9±0.5;106.3±8.1 (mg/dl); 7±4.3; 123.7+14.8/78.6+9.2 C: 5.91±0.5; 106.7±8.4 (mg/dl); 7.1±4.2; 123.5+14.4/78.0+9.2 Grp3: 5.9±0.5; 106.5±8.5 (mg/dl); 7.2±4.1; 124.0+14.9/78.2+9.5 | I: Antidiabetic drugs: 0 C: Antidiabetic drugs: 0 Grp3: Antidiabetic drugs: 0
Eriksson, 1999, FDPS123 | I: 265; 34 C: 257; 54 | I: 55.0±7.0; 91.0 (34.4);100 White C: 55.0±7.0; 81.0 (31.5);100 White | I: NR; 67.0; 7.0 C: NR; 67.0; 7.3 | I: 86.7±14.0; 31.4±4.5; 102.0±11.0 C: 85.5±14.4; 31.1±4.5; 100.5±10.9 | I: 5.7±0.6; 6.1±0.08; NR; 140.0±18/86±9 C: 5.6±0.6; 6.2±0.7; NR; 136±17/86±10 | I: NR C: NR
Pan, 1997, Da Qing Study126 | I: 438; 133 C: 138; 43 | I: 44.4±9.2; 70.0 (55.6); 100 Chinese C: 46.5±9.3; 73 (54.9); 100 Chinese | I: NR; NR; NR C: NR; NR; NR | I: NR; 26.3±3.9; NR C: NR; 26.2±3.9; NR | I: NR; 5.67±0.8; 1.71±0.08; all 3 interventions combined mean(SE): 132.2±1.1/87.2±0.7 C: NR; 5.52±0.82; 1.72±0.07; 134.3±2/88.5±1.5 | I: NR C: NR
Studies with no postintervention followup
Mensink, 2003, SLIM Trial121 | I: 74; 22 C: 73; 19 | I: 54.2±5; 8; 28 (53.8); 100 White C:58.4±6.8; 30 (55.6); 100 White | I: NR; NR; NR C: NR; NR; NR | I: 87.5±13.7; 29.6±3.8; 103.2±10.6 C: 83.0±11.7; 29.2±3.3; 102.4±9.2 | I: 5.6±0.5; 6.0±0.87; 4.82±2.04(HOMA); 142±16/90±9 C: 5.8±0.5; 5.9±0.7; 4.55±2.05(HOMA); 145±14/88±7 | I: NR C: NR
Oldroyd, 2001^124^ | I: 39; 4 C: 39; 7 | I: 58.2 (range 41–75); 17.0 (46.0);100 White C: 57.5 (range 41–73); 22.0 (69.0); 100 White | I: NR; NR; NR C: NR; NR; NR | I: 83.3±16.1; 30.4±5.6; 97.9±11.1 C: 85.5±14.2; 29.9±4.9; 99.6±11.3 | I: 5.8±0.7; 6.0±0.9; 3.6±1.9; 137.2±19.9/77±12.6 C: 5.9±0.5; 6.2±0.9; 3.8±2.3(HOMA); 132.8±16.4/75.5±9.8 | I: NR C: NR
Pinkston, 2006^120^ | I: 21; NR C: 18; NR | I: 44.9±9.2; 0 (0); 100 Hispanic C:45.8±8.2;0 (0); 100 Hispanic | I: NR; 19 (<high school); NR C: NR; 11.1 (<high school); NR | I: 95.9±8.3; 37.9±5.1; 113.3±13.8 C: 97.6±21.2; 38.3±5.9; 111.8±10.3 | I: NR; NR; NR; 126.4±17.7/80.3±11 C: NR; NR; NR; 124.3±14.1/80.1±10.4 | I: NR C: NR

DPP = Diabetes Prevention Program; FDPS = Finnish Diabetes Prevention Study; NR = not reported; SLIM = Study on Lifestyle Intervention and Impaired Glucose Tolerance Maastricht

### Breast and Prostate Cancer

#### Description of Included Studies

Three RCTs127–129 met our inclusion criteria. There were 6 associated publications.182–187 One trial129 included patients with breast and prostate cancer but did not separate the data by type of cancer; therefore, this section presents the results for both types of cancer. We describe the three studies separately (Tables 7 and 8).

Table 7 Description of studies and baseline characteristics of participants: breast and prostate cancer

Author, Year, Study name | Randomized (N); Withdrawals (N) | Age (mean ± SD); Ethnicity | Socioeconomic status; Education (%≤ high school); Smokers: (%) | Weight (kg); BMI (km/m^2^); Waist circumference (cm) | Type of prostate cancer; Time since diagnosis (yrs); Time since treatment (yrs); Mean Gleason score (sum); PSA levels (ng/ml) | Type of breast cancer; Time since diagnosis (yrs); Time since treatment (yrs)
Demark-Wahnefried, 2006, Project LEAD129 | I: 89; 12 C: 93; 10 | I: 71.5±4.4; 82.0 White, 14.6 Black, 3.4 Other C: 71.9±5.6; 82.8 White, 15.0 Black, 2.2 Other | I: 10.1 earn <$12,000 per year; 29.2; 13.5 C: 8.6 earn <$12,000 per year; 36.6; 5.4 | I: NR; 27.7±5.3; NR C:NR; 28.3±5.3; NR Total: 71% had BMI≥25.0 | I: Locoregional; ≤ 1.5 yrs; NR; NR; NR C: Locoregional; ≤ 1.5 yrs; NR; NR; NR | I: Locoregional; ≤ 1.5 yrs; NR C: Locoregional; ≤ 1.5 yrs; NR
Ornish, 2005, PCL Trial128 | I: 44; 4 C: 49; 7 | I: 64.8±7.1; 84.1 White, 6.8 Black, 9.1 Other C:66.5±7.6; 96 White, 2 Black, 2 Other | I: NR; 6; NR C: NR; 4; NR | I: 80.0±13.6 26.0±4.2 NR C: 80.0±11.3 25.9±4.2 NR | I: Biopsy with Gleason score < 7, serum PSA 4–10 ng/ml and stages T1 and T2 disease; NR; have refused conventional tx; 5.7±0.5; 6.32±1.72 C: Biopsy with Gleason score < 7, serum PSA 4–10 ng/ml and stages T1 and T2 disease; NR; have refused conventional tx; 5.7±0.7; 6.28±1.66 | NA
Morey, 2009, RENEW (Breast)127 | I: 119 C: 131 Total withdrawals: 83 | I: 71.84±5.00; 89.0; White, 10.92 Other C: 72.20±4.77; 86.26 White, 13.74 Other | I: NR; 55.46 any college education; 3.36 C: NR; 54.96 any college education; 5.34 | I: 78.28±9.16; 28.97±2.97; NR C: 78.88±10.57; 29.40±3.90; NR | NA | I: In situ, localized, regional; ≥5 years; NR C: In situ, localized, regional; ≥5 years; NR
Morey, 2009, RENEW (Prostate)127 | I: 111 C: 114 Total withdrawals: 83 | I: 73.98±1.72; 90.99 White, 9.01 Other C: 73.68±4.96; 91.23 White, 8.77 Other | I: NR; 73.87 any college education; 5.51 C: NR; 72.81 any college education; 8.77 | I: 94.33±12.74; 29.20±3.53; NR C: 90.51±10.86; 28.39±3.04; NR | I: In situ, localized, regional; ≥5 years; NR; NR; NR C: In situ, localized, regional; ≥5 years; NR; NR; NR | NA

BMI = body mass index; Br = breast cancer; mo = month(s); LEAD = Leading the Way in Exercise and Diet; NR = not reported; PCL = Prostate Cancer Lifestyle; RENEW = Reach Out to Enhance Wellness; tx = treatment

Table 8 Description of lifestyle intervention for breast and prostate cancer studies

Author, Year, Study name | Duration of intervention; followup | Diet | Exercise | Counseling or other component(s) | Control group
Demark-Wahnefried, 2006, Project LEAD129 | 6 mo; 6 mo | - Followed US National Guidelines; - Home-based diet program: increased diet diversity, F&Vs, whole grains; decreased total fat, SFA, cholesterol; adequate iron and calcium; - Workbook, telephone contact, tailored mailed materials | - Home-based exercise program: specific exercises tailored to functional limitations; - Recommendation of ≥30 min of moderate PA on 5 or more days; - Pedometer, logbook, workbook, telephone contact, tailored mailed materials | - Individual counseling: 12 telephone calls for 6 mo; dietician first 3 mo, exercise physiologist for next 3 mo to improve PA; - Counselors helped to achieve behavioral goals | - Attention control; - Health promotion materials (not tailored and unrelated to diet and exercise); - Bi-monthly telephone counseling for 6 mo on general health topics
Ornish, 2005, PCL Trial128 | 12 mo; 12 mo | - Followed vegan diet; predominately F&V, whole grains, legumes and soy products, low in simple CHO with approx 10% of calories from fat; supplemented with fish oil, vitamin E, selenium and vitamin C; - Met with dietitian and chef to learn food preparation techniques; - Telephone contact, mailings | - Moderate aerobic PA; walking 30 min 6 d/wk; - Telephone contact, mailings | - Individual counseling: RD for nutrition education; nurse case manager for telephone contact weekly for first 3 mo, 1/mo after; - Group-based counseling: 1-hr weekly support group; - Stress management: yoga based stretching, breathing, meditation, imagery and progressive relaxation; 60 min daily | - Usual/standard care by primary care physician
Morey, 2009, RENEW127 | 12 mo; 0 | - Followed U.S. National Guidelines; - Home-based diet program: increased F&Vs, <10% of calories from SFA; - Personalized record logs, automated telephone prompts, quarterly progress reports | - Home-based exercise program: aerobic goal of 30 min/d, 15 min strength exercises every other d; - Pedometer, Therabands, exercise poster, personalized record logs, telephone prompts, progress reports 4/yr | - Individual counseling: counselor, 15 sessions via telephone for 15–30 min including behavioral modification and goal setting | - Wait-list control

approx = approximately; CHO =carbohydrate; d = day(s); F&V = fruits and vegetables; LEAD = Leading the Way in Exercise and Diet; min = minute(s); mo = month(s); PA = physical activity; PCL = Prostate Cancer Lifestyle; RD = registered dietitian; RENEW = Reach Out to Enhance Wellness; SFA = saturated fatty acids; wk = week(s)

Project Leading the Way in Education Against Disease (Project LEAD)129 by Demark-Wahnefried et al. tested whether a personally tailored telephone counseling program is effective in improving diet and physical activity behavior among early stage breast and prostate cancer patients. There were 104 breast and 78 prostate cancer survivors randomized to either a lifestyle intervention that included a home-based diet and exercise program of telephone counseling and mailed materials or to an active control group that received a mailed workbook and telephone counseling on other health-related areas. The mean age was 71.7±5.0 years. The duration of the intervention was 6 months with a 6 month postintervention followup. The intervention was delivered by a dietician and exercise physiologist.

In the trial by Ornish et al.,128 93 men diagnosed with prostate cancer and who had chosen not to undergo any conventional treatment were randomized to either a comprehensive lifestyle change intervention or usual care. Participants in the lifestyle group followed a vegan diet, were asked to do moderate aerobic exercise, learned stress management techniques, and participated in a 1 hour per week support group. Their nutrition education and counseling was provided by a registered dietitian; participants were contacted by phone by a nurse case manager. The control group followed their physicians’ advice regarding lifestyle changes. The mean age was 65.7±7.4 years. The duration of the intervention was 1 year with no postintervention followup.

The Reach out to ENhancE Wellness in Older Cancer Survivors (RENEW) study by Morey et al.127 included overweight participants who were long-term survivors (≥5 years) of breast, prostate, and colorectal cancer. For the purposes of this review, we report only the data for breast and prostate cancer patients (data provided by the authors of the study). There were 250 breast cancer and 225 prostate cancer patients. For 12 months, the intervention group participated in a home-based program based on social cognitive theory and transtheoretical models. They received personally tailored workbooks, quarterly newsletters, telephone counseling, and automated prompts. The intervention was delivered by health counselors. No details were provided on the type of training these individuals had. The control group comprised patients on a wait list; they received the same lifestyle intervention at the end of the study. The mean age was 73.1±5.0 years. The duration of the intervention was 1 year with a planned 1 year followup; however, only immediate postintervention followup data have been reported.

#### Methodological Quality

The methodological quality of the three RCTs is summarized in Table 9. One trial128 was assessed at high risk of bias; for two, the risk of bias was unclear.127,129 All three stated that they were RCTs; one128 did not describe the sequence generation. One stated that there was concealment of allocation.127 For the blinding domain, one study128 was assessed as having a high risk of bias associated with self-reported outcomes such as changes in diet and physical activity; two studies were rated as unclear.127,129 The studies were at low risk of bias for the remaining components (selective outcome reporting, baseline imbalances or the funding source). Funding was provided by government and foundations.

Table 9 Risk of bias assessment for studies of breast or prostate cancer

Author Year | Sequence generation | Allocation concealment | Blinding: Objective outcomes | Blinding: Self-reported outcomes | Incomplete outcome data | Selective outcome reporting | Other sources: Baseline imbalance | Other sources: Funding | Overall risk of bias
Demark-Wahnefried 2006^129^ | Low | Unclear | Low | Unclear | Low | Low | Low | Low | Unclear
Morey 2009^127^ | Low | Low | Low | Unclear | Low | Low | Low | Low | Unclear
Ornish 2005^128^ | Unclear | Unclear | Low | High | Unclear | Low | Low | Low | High

High = high risk of bias; Low = low risk of bias; Unclear = unclear risk of bias

#### Results

Primary outcome. Our primary outcome was the recurrence of cancer, or for patients with prostate cancer undergoing watchful waiting, a change in PSA levels that required active treatment.

Recurrence of cancer. Ornish et al.128 reported that at the end of the 12 month intervention serum PSA levels had decreased in the lifestyle intervention group (6.23±1.7 to 5.98±1.7) and had increased in the control group (6.36±1.7 to 6.74±2.1). The difference between the groups was statistically significant in favor of the lifestyle intervention group (MD = −0.63; 95% CI: −1.41, −0.12). Among the control group, six participants underwent conventional therapy, four due to an increase in PSA and two due to progression of prostate cancer. None of the lifestyle group underwent conventional therapy during the study. Demark-Wahnefried et al.129 and Morey et al.127 did not report data for this outcome.

Secondary outcomes. Change in body composition. Two studies127,128 reported weight change (lbs) at end of intervention (Figure 31). For prostate cancer, the pooled estimate reported a statistically significant difference in favor of the lifestyle intervention (MD = −7.55; 95% CI: −13.05, −2.05, I^2^=44%). For breast cancer, there was no difference between groups (MD= −3.90; 95% CI: −10.32, 2.52)

Figure 31 Effect of lifestyle interventions vs. control on weight change (lbs): breast or prostate cancer

“Figure 31 displays a forest plot of studies reporting a mean difference of weight change (lbs), lifestyle interventions vs. control in patients with breast or prostate cancer. This figure is described further in the Section entitled ““Change in body composition”“ as follows: ““Two studies reported weight change (lbs) at end of intervention. For prostate cancer, the pooled estimate reported a statistically significant difference in favor of the lifestyle intervention (MD = −7.55; 95% CI: −13.05, −2.05, I2=44%). For breast cancer, there was no difference between groups (MD= −3.90; 95% CI: −10.32, 2.52).”““

Two studies reported BMI127,129 at end of intervention and found no statistically significant difference between groups (Figure 32). One study by Demark-Wahnefried129 showed no significant difference between groups at 6 month followup (data not presented).

Figure 32 Effect of lifestyle interventions vs. control on change in BMI: breast or prostate cancer

Figure 32 displays a forest plot of studies reporting a mean difference of change in BMI (kg/m2), lifestyle interventions vs. control in patients with breast or prostate cancer. This figure is described futher in the Section entitled “Change in body composition” as follows: “Two studies reported BMI and found no statistically significant difference between groups. One study by Demark-Wahnefried showed no significant difference between groups at 6 month followup (data not presented).”

Change in metabolic variables. Ornish et al.128 was the only study that reported metabolic outcomes. They reported total cholesterol (MD = −34.00; 95% CI: −47.69, −20.31), LDL cholesterol (MD = −28.60; 95% CI: −40.23, −16.97), HDL cholesterol (MD = −6.40; 95% CI: −9.50, −3.30), and triglycerides (MD = −9.00; 95% CI: −38.06, 20.06). A statistically significant difference in favor of the lifestyle intervention was seen in all except triglycerides.

Change in physical activity. Two studies looked at changes in exercise level.128,129 The difference between groups in changes from baseline to the end of the intervention was statistically significant favoring the lifestyle group (SMD = 0.43; 95% CI: 0.13, 0.72, I^2^ = 28%).

Demark-Wahnefried et al. assessed energy expenditure. There was a statistically significant increase in energy expenditure in favor of the lifestyle intervention at the end of intervention (SMD = 511.11; 95% CI: 20.56, 1001.44). This difference disappeared at the 6 month followup (SMD = −245.0; 95% CI: −813.14, 323.14).

The RENEW study127 looked at moderate minutes of endurance and strength exercise. The pooled results for both breast and prostate cancer patients for moderate minutes of endurance was statistically significant in favor of the lifestyle intervention (MD = 15.04; 95% CI: 0.09, 29.99; I^2^ = 0%). The pooled results for both breast and prostate cancer patients for moderate minutes of strength exercise was also statistically significant in favor of the lifestyle intervention (MD = 21.91; 95% CI: 13.30, 30.51, I^2^ = 26%).

The RENEW study127 also looked at sessions per week of both endurance and strength exercises and reported a significant difference in the breast cancer participants only for both endurance and strength exercises in favor of the lifestyle intervention (MD = 1.17; 95% CI: 0.38, 1.96 for endurance and MD = 1.67; 95% CI: 1.18, 2.16 for strength). There was no significant difference seen in the prostate cancer participants for either types of exercise. The pooled mean difference for sessions per week of endurance exercises for both breast and prostate cancer patients was statistically significant (MD = 0.98; 95% CI: 0.38, 1.59, I^2^ = 0%). For sessions per week of strength exercises, the pooled results favored the lifestyle intervention. However, the results were not statistically significant (MD = 1.06; 95% CI: −0.17, 2.29, I^2^ = 89%).

Change in dietary or nutrient intake. All three studies127–129 assessed calories from fat (Figure 33). For breast cancer patients in the RENEW study,127 there was a statistically significant decrease in calories from fat (MD = −1.76; 95% CI: −2.57, −0.95). In prostate cancer patients, there was a statistically significant decrease in calories from fat only in the study by Ornish et al.128 (MD = −16.80; 95% CI: −20.29, −13.31). This was not seen in the prostate cancer participants in the RENEW study (MD = −0.74; 95% CI: −1.53, 0.05). There was no significant difference seen in the study by Demark-Wahnefried et al.129 at the end of intervention or at the 6 month followup.

Figure 33 Effect of lifestyle interventions vs. control on fat consumption (calories): patients with breast or prostate cancer

Figure 33 displays a forest plot of studies reporting a mean difference of fat consumption (calories), lifestyle interventions vs. control in patients with breast or prostate cancer. This figure is described further in the Section entitled “Change in dietary or nutrient intake” as follows: “All three studies assessed calories from fat. For breast cancer patients in the RENEW study, there was a statistically significant decrease in calories from fat (MD = −1.76; 95% CI: −2.57, −0.95). In prostate cancer patients, there was a statistically significant decrease in calories from fat only in the study by Ornish et al. (MD = −16.80; 95% CI: −20.29, −13.31). This was not seen in the prostate cancer participants in the RENEW study (MD = −0.74; 95% CI: −1.53, 0.05). There was no significant difference seen in the study by Demark-Wahnefried et al. at the end of intervention or at the 6 month followup.”

Two studies127,129 reported intake of fruits and vegetables. Both breast and prostate cancer participants in the RENEW study, the lifestyle group significantly increased their intake of fruits and vegetables. The MD was 1.08 (95% CI: 0.50, 1.66) for the breast cancer participants and 1.40 (95% CI: 0.75, 2.05) for the prostate cancer participants. There was no statistical difference seen in the study by Demark-Wahnefried et al.129 at the end of intervention or at the 6 month followup. The overall pooled MD of 0.95 (95% CI: 0.39, 1.52; I^2^ = 61%) shows a statistically significant increase of fruits and vegetables favoring the lifestyle intervention.

Demark-Wahnefried et al.129 also reported a Diet Quality Index. There was a statistically significant difference in favor of the lifestyle intervention at the end of intervention. The MD was 5.10 (95% CI: 1.04, 9.16). This difference was not seen at the 6 month followup (MD = 0.80; 95% CI: −3.20, 4.80).

Compliance with the intervention. Compliance was measured by withdrawals/dropouts from the studies. There was no statistical difference seen in the studies by Ornish et al.128 and Demark-Wahnefried et al.129 The pooled MD was 1.01 (95% CI: 0.53, 1.94; I^2^ = 0%). The RENEW study did not report withdrawals separated by group.

Adverse events. The RENEW study reported five adverse events.127 One participant had increased blood pressure with exercise and four experienced hip pain during exercise, a pulled hamstring, a fall during hiking, or calf pain and stiffness using the exercise bands. The study stated that there was no difference between the intervention and control groups regarding the number of adverse events.

#### Summary

Three RCTs127–129 assessed the effectiveness of lifestyle interventions for breast and prostate cancer. The following is a summary of results:

- Primary outcomes. One study assessed our primary outcome of PSA levels in prostate cancer participants. There was a significant decrease in levels for lifestyle intervention participants. The strength of evidence for this outcome is insufficient.
- Change in body composition. Two studies reported change in weight (lbs) at end of intervention. There was no difference between groups for breast cancer patients but a statistically significant difference favoring the lifestyle group for prostate cancer patients. Two studies reported change in BMI (kg/m^2^) and showed no statistically significant difference between groups for breast, prostate, and mixed cancer populations. The strength of evidence for change in BMI or weight is insufficient.
- Change in metabolic variables. One study reported metabolic outcomes. A statistically significant difference in favor of the lifestyle intervention was seen for total cholesterol, and HDL and LDL cholesterol. The strength of evidence is insufficient.
- Change in physical activity. Two studies looked at changes in exercise level. The difference between groups at end of intervention was statistically significant favoring the lifestyle group. One study reported a statistically significant increase in energy expenditure in favor of the lifestyle intervention at the end of intervention; this difference was no longer present at 6 month followup. One study looked at moderate minutes of endurance and found no statistically significant difference between the groups for both breast and prostate cancer patients. The strength of evidence is insufficient for all outcomes.
- Change in dietary or nutrient intake. All three studies127–129,153,154,52,51,53,154,52,51,53,154,52,6,127–129,48,140,152,127–129 assessed calories from fat. In two studies there was a statistically significant decrease in calories from fat in breast cancer and prostate cancer patients. One study showed no difference between groups in the mixed breast and prostate cancer populations at end of intervention and 6 month followup.
- Compliance with intervention. Two studies showed no statistically significant difference between groups. One study did not report withdrawals separated by group.
- Adverse events. One study stated that there was no difference between the intervention and control groups regarding the number of adverse events.
- One trial was assessed as high risk of bias; two were unclear. The most common sources of potential bias were inadequate allocation concealment and inadequate blinding.

## Key Question 2 What is the generalizability of the evidence to the Medicare population (> 65 years)?

Type 2 diabetes. The trials included a wide range of patients including varying comorbidities and nationalities. The mean ages from the 10 trials ranged from 53 to 62 years and included participants up to 75 years old. The majority of these addressed our secondary outcomes, thus we believe that the results for our secondary outcomes should be generalizable to individuals aged 65 years or older. Two trials excluded patients over the age of 65 years,117,119 including the only study119 that provided data for our primary outcomes. Therefore, we are uncertain whether the results for our primary outcomes (progression of diabetes, progression to micro- or macrovascular complications) are generalizable to the Medicare population.

Metabolic syndrome. The mean ages from the seven trials ranged from 44 to 58 years and included participants up to 85 years of age. Two trials excluded patients over the age of 65 years,123,125 including studies that provided data for our primary outcomes. Therefore, we are uncertain whether the results for our primary outcomes (progression to diabetes or cardiovascular events) are generalizable to the Medicare population. For our secondary outcomes, we believe that the results should be generalizable to individuals aged 65 years or older.

Breast and prostate cancer. The mean age of participants in the three trials ranged from 65 to 75 years. Therefore, the results from these studies should be generalizable to the Medicare population.

## Key Question 3 What is the evidence on whether specific components of the interventions, composition of the team, and/or patient characteristics contribute to better outcomes?

We were unable to address this question due to insufficient data.