# Methods

This chapter describes the prospectively designed protocol that the University of Alberta Evidence-based Practice Center used to synthesize the evidence on lifestyle interventions for type 2 diabetes, metabolic syndrome, breast cancer, and prostate cancer. We outline the literature search strategy, the selection process for identifying relevant articles, the process for extracting data from eligible studies, the methods for assessing the methodological quality of individual studies and for rating the overall body of evidence, and our approach to data analysis and synthesis.

## Literature Search

The Research Librarians, in collaboration with the research team, developed search strategies designed to identify evidence relevant to each key question. Our search for published literature included structured searches in standard bibliographic databases. We systematically searched the following resources: MEDLINE® (1950 – 2010), Embase (1980–2010), Cochrane Controlled Trials Register (CENTRAL) (1980 – 2010), CINAHL® (1982 – 2010), and SCOPUS (1980 – 2010). The original searches were performed between March 3^rd^ and March 23^rd^, 2010. Search terms were identified by reviewing search strategies of systematic reviews on similar topics and by looking at how potentially relevant studies were indexed in various databases. A combination of subject headings and text words was adapted for each electronic resource covering the four diseases/conditions and lifestyle interventions (diabet* type II or noninsulin depend$ OR MODY or NIDDM OR T2DM) OR (metabolic syndrome x or prediabet* or insulin resistance) OR (prostat* and (neoplasm* or cancer* or carcinoma or tum?or* or malignan*)) OR (breast* and (neoplasm* or cancer* or carcinoma or tum?or* or malignan*)) AND (exercise* or fitness* or exertion or activit* or endurance*) AND (lifestyle or stress or mental health or cognitive therap* or psychotherap* or health promotion or health education or behavior?r therap* or quality of life or mend-body therap* or breathing exercise* or laughter therap* or therapeutic touch* or tai chi or aromatherap* or hypnosis or meditation) AND (diet* or weight loss* or nutrition* or calori* and (intake or restriction or reduction or deficit or diet or intervention or change or program)) or fat intake or fiber intake). A RCT filter was applied to limit the searches to controlled trials. Searches were also limited to English language and a date restriction of 1980 – present was applied. See Appendix A for exact search strategies.

## Study Selection

The review included RCTs published between 1980 and 2010. The population was adults (≥ 18 years) who were survivors of breast cancer (diagnosed and successfully treated), survivors of prostate cancer (diagnosed and successfully treated or diagnosed and in a watchful waiting category), with type 2 diabetes (diagnosed by a physician), or metabolic syndrome (operationally defined as including metabolic syndrome, insulin resistance, pre-diabetes, impaired glucose tolerance, syndrome X, dysmetabolic syndrome X, and Reaven syndrome).

The lifestyle intervention had to include an exercise component, a diet component, and at least one other component (e.g., counseling, smoking cessation, stress reduction, group therapy, behavior modification). The comparison could be usual care, the diet and/or exercise components alone, or wait list. Our a priori criteria stated that the intervention must be at least 3 months with a postintervention followup period of at least 6 months. We made a post hoc modification to include RCTs in which the duration of the lifestyle intervention was at least 1 year but without a 6 month postintervention followup. We believe that such studies provide relevant information about the impact of long-term interventions.

The primary outcomes were recurrence of breast or prostate cancer, progression of type 2 diabetes to additional medication or insulin or progression to cardiovascular problems, hypertension or neuropathies, or progression of metabolic syndrome to diabetes, heart disease or stroke. The secondary outcomes were increase in physical activity, change in dietary or nutrient intake, change in body composition, change in metabolic variables, change in total number of medications taken or change in medication dose, and compliance to treatment allocation.

Article screening was conducted in two phases. In the first phase, two reviewers independently screened the titles, keywords, and abstracts (when available) to determine if an article met broad screening criteria for study design and population. Each article was rated as “include,” “exclude,” or “unclear”. The full text of articles classified as “include” or “unclear” by at least one of the reviewers was retrieved for detailed review. Two reviewers independently assessed each study using a detailed standard inclusion/exclusion form (Appendix B). Disagreements were resolved by consensus or third-party adjudication.

## Methodological Quality

The Cochrane Collaboration Risk of Bias (RoB) tool was used to assess the internal validity of the RCTs.108 The tool examines six domains (sequence generation, concealment of allocation, blinding, incomplete outcome data, selective outcome reporting, and “other” sources of bias). Each separate domain is rated “high”, “low”, or “unclear”. Blinding and incomplete outcome data were assessed separately for subjective outcomes (e.g., self-reported diet or exercise information) and objective clinical outcomes (e.g., weight gain, blood pressure). “Other” sources of bias included funding source, stopping early for benefit, and comparability of groups at baseline. The overall assessment was based on the responses to individual domains. If one or more individual domains were assessed as having a high risk of bias, the overall score was rated as high risk of bias. The overall risk of bias was considered low only if all components were rated as having a low risk of bias. The risk of bias for all other studies was rated as unclear.

Decision rules regarding application of the ROB tool were developed a priori and a sample of studies was used to pilot the RoB tool. Two reviewers independently assessed the methodological quality of included studies. Disagreements were resolved through consensus or third party adjudication. We contacted authors of included studies to collect missing information.

## Data Extraction

Using a standardized form (Appendix B), one reviewer extracted data into an Excel® database. The data were verified for accuracy and completeness by a second reviewer. Disagreements were resolved through discussion or third party adjudication.

The following data were extracted: author identification, year of publication, source of study funding, study design characteristics and methodological quality criteria, study population (including study inclusion and exclusion criteria, duration of intervention, patient baseline characteristics (i.e., age, sex, race, weight, BMI, waist circumference, blood pressure), detailed description of the intervention and comparison, results for the outcomes of interest, and adverse events.

## Data Analysis

The following assumptions were made and imputations performed to transform reported data into the form required for analysis. Graphical data were extracted using the measurement tool of Adobe Acrobat 9 Pro (Adobe Systems Inc., California, U.S.). Evidence tables and qualitative descriptions of results are presented for all included studies.

Quantitative results were meta-analyzed in Review Manager Version 5.0 (The Cochrane Collaboration, Copenhagen, Denmark). For continuous variables where the outcome measures were on the same scale (e.g., BMI) or could be easily converted to the same scale (e.g., pounds to kilograms), the mean difference (MD) was calculated. When the same outcome was measured using different scales (e.g., physical activity), the standardized mean difference (SMD) was used. Relative risks (RR) were computed to estimate between-group differences in studies that reported dichotomous outcomes (e.g., death). If no events were reported in one treatment arm, a correction factor of 0.5 was added to each cell of the two by two table in order to obtain estimates of the risk ratio. When no events were reported in both of the treatment arms, the RR was undefined and was denoted as “not calculated (NC)” in the results tables. All results are reported with 95% CI. When data were missing, imputations had to be carried out. Missing means were approximated by medians. Missing standard deviations were computed from standard errors, confidence intervals, or p-values. If none of these were available they were estimated from ranges or inter-quartile ranges, or imputed from other similar studies with the same outcome. If a trial had three or more arms of which two or more could be classified as a “treatment”, we included the study in a meta-analysis twice, splitting the control group to prevent a unit of analysis error.

All meta-analyses used a random effects model. Statistical heterogeneity was quantified using the I-squared (I^2^) statistic. When the I^2^ was greater than 75 percent, we conducted sensitivity analyses to explore sources of heterogeneity including study population (age, sex, risk factors), components of the lifestyle intervention, and study quality. Potential publication bias was explored graphically through funnel plots for comparisons for which there were at least 10 studies.

## Grading the Body of Evidence

We used the EPC GRADE approach109 to assess the strength of the evidence for all our primary outcomes and the following secondary outcomes: change in body composition, metabolic variables, systolic and diastolic blood pressure, physical activity, and dietary or nutrient intake. The following four major domains were examined for each outcome: risk of bias (the degree to which outcomes have a likelihood of adequate protection against bias; rated as low, medium, or high risk of bias), consistency (the degree to which reported effect sizes appear to have the same effect direction; rated as no inconsistency, inconsistency present, unknown, or not applicable), directness (whether the evidence directly links health outcomes to interventions; rated as direct or indirect), and precision (degree of certainty related to an outcome’s effect estimate; rated as precise or imprecise). Each outcome for each comparison of interest was given one of the following grades based on the ratings for the individual domains: high (further research is very unlikely to change our confidence in the estimate of effect), moderate (further research may change our confidence in the estimate of effect and may change the estimate), low (further research is likely to change the confidence in the estimate of effect and is likely to change the estimate), or insufficient (evidence either is unavailable or does not permit estimation of an effect). The body of evidence was graded by one reviewer.