# Appendixes

Appendix A Search Strategies

Appendix B Sample Forms

Appendix C List of Companion Publications

Appendix D Excluded Studies

Appendix E GRADE Tables