# GRADE Tables

Grading the body of evidence: type 2 diabetes

Outcome | # RCTs; # subjects | Risk of bias | Consistency | Directness | Precision | Strength of evidence
Primary outcomes
All-cause mortality (13 yr followup) | 1; 93 | Unclear | Unknown (single study) | Direct | Precise (RR_meds_ = 0.60; 95% CI: 0.4, 0.9) | Low
Cumulative incidence of CVD events (13 yr followup) | 1; 93 | Unclear | Unknown (single study) | Direct | Precise (RR_meds_ = 0.49; 95% CI: 0.34, 0.71) | Low
Autonomic neuropathy progression (13 yr followup) | 1; 93 | Unclear | Unknown (single study) | Direct | Precise (RR_meds_ = 0.75; 95% CI: 0.57, 0.99) | Low
Development of nephropathy (13 yr followup) | 1; 93 | Unclear | Unknown (single study) | Direct | Precise (RR_meds_ = 0.54; 95% CI: 035, 0.85) | Low
Development of retinopathy (13 yr followup) | 1; 93 | Unclear | Unknown (single study) | Direct | Precise (RR_meds_ = 0.76; 95% CI: 0.58, 0.99) | Low
Peripheral neuropathy progression (13 yr followup) | 1; 93 | Unclear | Unknown (single study) | Direct | Imprecise (RR_meds_ = 0.96; 95% CI: 0.73, 1.26) | Low
Change in body composition
BMI (EoI) | 4; 544 | Unclear | Consistent | Indirect | Precise (MD_all_ = −0.48; 95% CI: −0.92, −0.05) | Moderate
BMI (6 mo postintervention) | 1; 61 | Unclear | Unknown (single study) | Indirect | Imprecise (MD_meds_ = 1.0; 95%CI: −1.84, 3.84) | Insufficient
BMI (13 yr followup) | 1; 93 | Unclear | Unknown (single study) | Indirect | Imprecise (MD_meds_ = −1.1; 95% CI: −3.14, 0.94) | Insufficient
Weight change (EoI) | 5; 5,726 | Unclear | Consistent | Indirect | Precise (MD_no meds_ = −1.53; 95% CI: −2.09, −0.97; MD_meds_ = −15.4; 95% CI: − 16.1, −14.5) | Moderate
Weight change (6 mo postintervention) | 1; 171 | Unclear | Unknown (single study) | Indirect | Imprecise (MD_meds_ = 1.14; 95% CI: −5.39, 7.67) | Insufficient
Weight change (4 yr followup) | 1; 4,815 | Unclear | Unknown (single study) | Indirect | Precise (MD_meds_ = −11.62; 95% CI: −12.37, −10.87) | Insufficient
Metabolic variables
Fasting plasma glucose (EoI) | 3; 5,106 | Unclear | Inconsistent | Indirect | Imprecise (MD_no meds_ = − 0.33; 95% CI: −0.83, 1.49; MD_meds_ = −1.02; 95% CI: −1.85, −0.19) | Low
Fasting plasma glucose (6 mo postintervention) | 1; 61 | Unclear | Unknown (single study) | Indirect | Imprecise (MD_meds_ = −1.0; 95% CI: −2.61, 0.61) | Insufficient
Fasting plasma glucose (13 yr followup) | 1; 93 | Unclear | Unknown (single study) | Indirect | Imprecise (MD_meds_ = −0.16; 95% CI: −1.47, 1.15) | Insufficient
HbA1c (EoI) | 10; 6,411 | Unclear | Inconsistent | Indirect | Imprecise (MD_no meds_ = − 0.09; 95% CI: −0.58, 0.75; MD_meds_ = 0.77; 95% CI: −1.18, −0.36) | Low
HbA1c (6 mo postintervention) | 2; 232 | Unclear | Inconsistent | Indirect | Imprecise (MD_all_ = 0.09; 95% CI: −0.58, 0.75) | Insufficient
HbA1c (13 yr followup) | 1; 130 | Unclear | Unknown (single study) | Indirect | Imprecise (MD_meds_ = −0.70; 95% CI: −1.41, 0.01) | Insufficient
HDL cholesterol (EoI) | 6; 5,923 | Unclear | Inconsistent | Indirect | Imprecise (MD_no meds_ = − 0.01; −0.04, 0.05; MD_meds_ = 0.05; 95% CI: 0.03, 0.07) | Low
HDL cholesterol (6 mo postintervention) | 1; 171 | Unclear | Unknown (single study) | Indirect | Imprecise (MD_no meds_ = − 0.04; 95% CI: −0.16, 0.09) | Insufficient
HDL cholesterol (13 yr followup) | 1; 93 | Unclear | Unknown (single study) | Indirect | Imprecise (MD_meds_ = 0.08; 95% CI: −0.07, 0.22) | Insufficient
LDL cholesterol (EoI) | 5; 5,735 | Unclear | Inconsistent | Indirect | Imprecise (MD_no meds_ = − 0.09; 95% CI: −0.26, 0.08; MD_meds_ = −0.27; 95% CI: −0.92, 0.37) | Low
LDL cholesterol (6 mo postintervention) | 1; 61 | Unclear | Unknown (single study) | Indirect | Precise (MD_meds_ = −0.59; 95% CI: −1.07, −0.11) | Insufficient
LDL cholesterol (13 yr followup) | 1; 93 | Unclear | Unknown (single study) | Indirect | Imprecise (MD_meds_ = −0.05; 95% CI: −0.4, 0.3) | Insufficient
Total cholesterol (EoI) | 5; 964 | Unclear | Inconsistent | Indirect | Imprecise (MD_all_ −0.13; 95% CI: −0.27, 0.01), | Low
Total cholesterol (6 mo postintervention) | 1; 170 | Unclear | Unknown (single study) | Indirect | Imprecise (MD_no meds_ = 0.01; 95% CI: −0.35, 0.36) | Insufficient
Total cholesterol (13 yr followup) | 1; 93 | Unclear | Unknown (single study) | Indirect | Imprecise (MD_meds_ = 0.38; 95% CI: −0.06, 0.82) | Insufficient
Triglycerides (EoI) | 5; 5,583 | Unclear | Consistent | Indirect | Imprecise (MD_all_ = −0.17; 95% CI: −0.23, −0.12) | Low
Triglycerides (6 mo postintervention) | 1; 61 | Unclear | Unknown (single study) | Indirect | Imprecise (MD_meds_ = −0.18; 95% CI: −1.47, 1.11) | Insufficient
Triglycerides (13 yr followup) | 1; 93 | Unclear | Unknown (single study) | Indirect | Imprecise (MD_meds_ = −0.03; 95% CI: −0.67, 0.61) | Insufficient
Blood pressure
Diastolic BP (EoI) | 6; 5,905 | Unclear | Inconsistent | Indirect | Imprecise (MD_no meds_ = 0.32; 95% CI: −1.43, 20.7; MD_meds_ = −1.2; 95% CI: −1.75, 0.65) | Low
Diastolic BP (6 mo postintervention) | 1; 61 | Unclear | Unknown (single study) | Indirect | Imprecise (MD_meds_ = 0; 95% CI: −5.07, 5.07) | Insufficient
Diastolic BP (13 yr followup) | 1; 93 | Unclear | Unknown (single study) | Indirect | Imprecise (MD_meds_ = 2.0; 95% CI: −1.90, 5.90) | Insufficient
Systolic BP (EoI) | 6; 5,905 | Unclear | Inconsistent | Indirect | Imprecise (MD_no meds_ = − 1.89; 95% CI: −0.57, 4.35; MD_meds_ −6.89; 95% CI: −14.42, 0.64) | Low
Systolic BP (6 mo postintervention) | 1; 61 | Unclear | Unknown (single study) | Indirect | Imprecise (MD_meds_= −3.0; 95% CI: −12.4, 6.4) | Insufficient
Systolic BP (13 yr followup) | 1; 93 | Unclear | Unknown (single study) | | Imprecise (MD_meds_ = −3.0; 95% CI: −9.79, 3.79) | Insufficient
Change in physical activity
Exercise (EoI) | 5; 973 | Unclear | Consistent | Indirect | Precise (SMD_all_ = 0.45; 95% CI: 0.2, 0.71) | Low
Exercise (6 mo postintervention) | 3; 469 | Unclear | Consistent | Indirect | Precise (SMD_all_ = 0.5; 95% CI: 0.1, 0.89) | Low
Exercise (1 yr followup) | 1; 2556 | Unclear | Unknown (single study) | Indirect | Precise (SMD_meds_ = 0.53; 95% CI: 0.44, 0.61) | Insufficient
Exercise (2 yr followup) postintervention) | 1; 245 | Unclear | Unknown (single study) | Indirect | Precise (SMD_no meds_ = 0.41; 95% CI: 0.16, 0.67) | Insufficient
Exercise (8 yr followup) | 1; 130 | Unclear | Unknown (single study) | Indirect | Imprecise (SMD_meds_ = 0.11; 95% CI: −0.24, 0.45) | Insufficient
Change in dietary or nutrient intake
Energy intake (EoI) | 4; 728 | Unclear | Inconsistent | Indirect | Imprecise (SMD_all_ = −0.17; 95% CI: −0.33, −0.01) | Low
Energy intake (6 mo postintervention) | 1; 61 | Unclear | Unknown (single study) | Indirect | Imprecise (SMD_meds_ = − 0.12; 95% CI: −0.59, 0.36) | Insufficient
Energy intake (8 yr followup) | 1; 130 | Unclear | Unknown (single study) | Indirect | Imprecise (SMD_meds_ = 0; 95% CI: −0.35, 0.34) | Insufficient
SFA intake (EoI) | 4; 663 | Unclear | Consistent | Indirect | Imprecise (SMD_all_ = −0.31; 95% CI: −0.68, 0.07) | Low
SFA intake (6 mo postintervention | 2; 298 | Unclear | Consistent | Indirect | Imprecise (SMD_all_ = −0.45 95% CI: −0.79, −0.10) | Insufficient
SFA intake (8 yr followup) | 1; 130 | Unclear | Unknown (single study) | Indirect | Precise (SMD_meds_ = −0.68; 95% CI: −1.03, −0.32) | Insufficient

Grading the body of evidence: metabolic syndrome

Outcome | # RCTs; # subjects | Risk of bias | Consistency | Directness | Precision | Strength of evidence
Primary outcomes
CVD events (Followup: 6–10 yr) | 2; 1,035 | Unclear | Consistent | Direct | Imprecise (RR = 1.02; 95% CI: 0.73, 1.42) Imprecise (HR = 0.96; 95% CI: 0.76–1.44) | Insufficient
CVD events (Followup: 20 yr) | 1; 400 | Unclear | Unknown (single study) | Direct | Imprecise (HR = 0.98; 95% CI: 0.71–1.37) | Insufficient
Development of type 2 diabetes (EoI: duration 1–6 yr) | 3; 1,371 | Unclear | Consistent | Direct | Precise (RR = 0.44; 95% CI: 0.2, 0.93) | Moderate
Development of type 2 diabetes (Followup: 4–10 yr) | 3; 2,611 | Unclear | Consistent | Direct | Precise (RR_4 yr_ = 0.56; 95% CI: 0.48, 0.64; RR_6 yr_ = 0.44; 95% CI: 0.29, 0.68) | Moderate
Death (Followup: 10–20 yr) | 2; 905 | Unclear | Consistent | Direct | Imprecise (RR_10 yr_ = 0.58; 95% CI: 0.21, 1.57; HR_20 yr_ = 0.83; 95% CI: 0.48, 1.40) | Insufficient
Change in body composition
BMI (EoI) | 4; 914 | Unclear | Consistent | Indirect | Precise (MD = −0.95; 95% CI: −1.49, −0.41) | Moderate
BMI (4 yr followup) | 1; 335 | Unclear | Unknown (single study) | Indirect | Precise (MD = −0.92; 95% CI: −1.32, −0.53) | Insufficient
Waist circumference (EoI) | 5; 968 | Unclear | Consistent | Indirect | Precise (MD = −3.73; 95% CI: −4.87, −2.59) | Moderate
Waist circumference (4 yr followup) | 1; 335 | Unclear | Unknown (single study) | Indirect | Precise (MD = −1.86; 95% CI: −3.49, −0.22) | Insufficient
Weight change (EoI) | 6; 3,106 | Unclear | Consistent | Indirect | Precise (MD = −7.8; 95% CI: −11.92, −3.67) | Moderate
Weight change (4 yr followup) | 2: 1,341 | Unclear | Consistent | Indirect | Precise (MD= −5.88; 95% CI: − 8.05, −3.71) | Low
Weight change (10 yr followup) | 1; 1,842 | Unclear | Unknown (single study) | Indirect | Imprecise (MD = −0.94; 95% CI: −5.07, 3.19) | Insufficient
Change in metabolic variables
Fasting plasma glucose (EoI) | 5; 2,971 | Unclear | Inconsistent | Indirect | Precise (MD = −0.29; 95% CI: −0.35, −0.23) | Moderate
Fasting plasma glucose (10 yr followup) | 1; 1,842 | High | Unknown (single study) | Indirect | Precise (MD = 0.10; 95% CI: 0.03, 0.18) | Insufficient
HbA1c (EoI) | 2; 2,148 | High | Inconsistent | Indirect | Imprecise (MD = −0.10; 95% CI: −0.28, 0.08) | Insufficient
HbA1c (10 yr followup) | 1; 1,842 | High | Unknown (single study) | Indirect | Precise (MD = −0.05; 95% CI: −0.09, −0.02) | Insufficient
HDL cholesterol (EoI) | 4; 914 | Unclear (50% high, 50% unclear) | Consistent | Indirect | Precise ( MD= 0.08; 95% CI: 0.05, 0.10) | Moderate
HDL cholesterol (4 yr followup) | 1; 335 | Unclear | Unknown (single study) | Indirect | Imprecise ( MD = 0.05; 95% CI: 0.0, 0.10) | Insufficient
LDL cholesterol (EoI) | 3; 199 | High | Inconsistent | Indirect | Imprecise (MD = 0.04; 95% CI: −0.16, 0.25) | Low
Total cholesterol (EoI) | 5; 968 | Unclear | Inconsistent | Indirect | Imprecise ( MD = 0.0; 95% CI: −0.12, 0.13) | Low
Impaired plasma glucose (EoI) | 1; 335 | Unclear | Unknown (single study) | Indirect | Precise (MD = 0.34; 95% CI: 0.23, 0.52) | Insufficient
Triglycerides (EoI) | 4; 914 | Unclear (50% high, 50% unclear) | Inconsistent | Indirect | Imprecise (MD = −0.11; 95% CI: −0.26, 0.04) | Low
Triglycerides (4 yr followup) | 1; 335 | Unclear | Unknown (single study) | Indirect | Imprecise (MD = 0.09; 95% CI: −0.22, 0.05) | Insufficient
Blood pressure
Diastolic BP (EoI) | 5; 2,734 | Unclear | Consistent | Indirect | Precise (MD =−2.70; 95% CI: − 3.21, −2.18) | Moderate
Diastolic BP (4 yr followup) | 2; 1,341 | Unclear | Consistent | Indirect | Precise (MD = −1.88; 95% CI: −2.65, −1.12) | Low
Systolic BP (EoI) | 5; 2,734 | Unclear | Consistent | Indirect | Precise (MD = −3.17; 95% CI: −5.02, −1.33) | Moderate
Systolic BP (4 yr followup) | 2;1,341 | Unclear | Consistent | Indirect | Precise (MD = −4.41; 95% CI: −8.47, −0.35) | Low
Change in physical activity
Exercise (EoI) | 4; 2,688 | Unclear | Consistent | Indirect | Precise (SMD = 0.40; 95% CI: 0.2, 0.59) | Moderate
Exercise (4 yr followup) | 1; 1,006 | High | Unknown (single study) | Indirect | Precise (SMD = 0.23; 95% CI: 0.10, 0.35) | Insufficient
Change in dietary or nutrient intake
Energy intake (EoI) | 4; 2,732 | Unclear | Consistent | Indirect | Precise (SMD = −0.23; 95% CI: −0.31, −0.16) | Moderate
SFA intake (EoI) | 2; 441 | Unclear | Consistent | Indirect | Precise (SMD = −0.53; 95% CI: −0.73, −0.34) | Low

Grading the body of evidence: breast or prostate cancer

Outcome | # RCTs; # subjects | Risk of bias | Consistency | Directness | Precision | Strength of evidence
Breast cancer
Change in body composition
BMI (EoI) | 1; 250 | Unclear | Unknown (single study) | Indirect | Imprecise (MD = −0.31; 95% CI: −1.19, 0.57) | Insufficient
Weight (EoI) | 1; 250 | Unclear | Unknown (single study) | Indirect | Imprecise (MD = −3.9; 95% CI: −10.32, 2.52) | Insufficient
Change in physical activity
Exercise (endurance; EoI) | 1; 250 | Unclear | Unknown (single study) | Indirect | Precise ( MD = 25.6; 95% CI: 16.9, 34.8) | Insufficient
Change in dietary or nutrient intake
F&V intake (EoI) | 1; 250 | Unclear | Unknown (single study) | Indirect | Precise ( MD = 1.08; 95% CI: 0.5, 1.66) | Insufficient
Fat intake (calories from fat) (EoI) | 1; 250 | Unclear | Unknown (single study) | Indirect | Imprecise (MD = −1.76; − 2.57, −0.95) | Insufficient
Prostate cancer
Primary outcome
PSA levels (EoI) | 1; 84 | High | Unknown (single study) | Direct | Precise (MD = −0.63; 95% CI: −1.16, −0.10) | Insufficient
Change in body composition
BMI (EoI) | 1; 225 | High | Unknown (single study) | Indirect | Imprecise (MD = −0.61; 95% CI: −1.47, 0.25) | Insufficient
Weight (EoI) | 2; 309 | High | Consistent | Indirect | Imprecise (MD = −7.55; 95% CI: −13.05, −2.05) | Insufficient
Change in metabolic variables
HDL cholesterol (EoI) | 1; 84 | High | Unknown (single study) | Indirect | Precise (MD = −6.4; 95% CI: −9.65, −3.15) | Insufficient
LDL cholesterol (EoI) | 1; 84 | High | Unknown (single study) | Indirect | Precise (MD = −28.6; 95% CI: −40.79, −16.41) | Insufficient
Total cholesterol (EoI) | 1; 84 | High | Unknown (single study) | Indirect | Precise (MD = −34.0; 95% CI: −48.30, −19.7) | Insufficient
Triglycerides (EoI) | 1; 84 | High | Unknown (single study) | Indirect | Imprecise (MD= −9.0; 95% CI: −39.62, 21.62) | Insufficient
Change in physical activity
Exercise (EoI) | 1; 84 | High | Unknown (single study) | Indirect | Precise (SMD = 0.62; 95% CI: 0.20, 1.03) | Insufficient
Exercise (endurance; EoI) | 1; 225 | High | Unknown (single study) | Indirect | Precise ( MD = 16.3; 95% CI: 4.8, 28.5) | Insufficient
Change in dietary or nutrient intake
Fat intake (calories from fat) (EoI) | 2; 307 | High | Consistent | Indirect | Precise (MD = −16.8; 95% CI: −20.3, −13.3) | Insufficient
F&V intake (EoI) | 1; 225 | High | Unknown (single study) | Indirect | Precise ( MD = 1.4; 95% CI: 0.75, 2.05) | Insufficient
Mixed breast and prostate cancer
Change in body composition
BMI (EoI) | 1; 168 | Unclear | Unknown (single study) | Indirect | Imprecise (MD = −0.10; 95% CI: 1.68, 1.48) | Insufficient
BMI (followup) | 1; 160 | Unclear | Unknown (single study) | Indirect | Imprecise (MD = −0.50; 95% CI: −2.13, 1.13) | Insufficient
Change in physical activity
Exercise (EoI) | 1; 168 | Unclear | Unknown (single study) | Indirect | Imprecise (SMD = 0.31; 95% CI: 0, 0.61) | Insufficient
Exercise (followup) | 1; 160 | Unclear | Unknown (single study) | Indirect | Imprecise (SMD = 0.13; 95% CI: −0.18, 0.44) | Insufficient
Change in dietary or nutrient intake
F&V intake (EoI) | 1; 168 | Unclear | Unknown (single study) | Indirect | Imprecise ( MD = 0.4; 95% CI: −0.21, 1.01) | Insufficient
F&V intake (followup) | 1; 160 | Unclear | Unknown (single study) | Indirect | Imprecise ( MD = −0.10; 95% CI: −0.75, 0.55) | Insufficient
Fat intake (calories from fat) (EoI) | 1; 168 | Unclear | Unknown (single study) | Indirect | Imprecise (MD = −0.30 [−2.41, 1.81] | Insufficient
Fat intake calories from fat) (followup) | 1; 160 | Unclear | Unknown (single study) | Indirect | Imprecise (MD = −0.50 [−2.70, 1.70] | Insufficient