# Excluded Studies

156 studies were excluded from the review. Reasons for exclusion include: publication type (n=11), study design (n=17), population (n=28), intervention (n=33), length of intervention or postintervention followup (n=39), comparator (n=5), outcomes (n=16), outcomes not separated by group (n=1), language (n=1), and duplicate (n=1). In addition, we were unable to obtain copies of 4 studies.

## Publication type (n = 11)

1 Culturally appropriate lifestyle interventions promote weight loss in rural dwelling people with type 2 diabetes. Evidence-Based Healthcare and Public Health. 2005;9(3):231-2.
2 Lifestyle therapy for prostate cancer: does it work?. Harv Mens Health Watch. 2007;11(12):1-3.
3 Preventing type 2 diabetes: lifestyle changes work better than drugs. Health News. 2002;8(4):6.
4 Avenell A, Brown TJ, McGee MA, et al. What interventions should we add to weight reducing diets in adults with obesity? A systematic review of randomized controlled trials of adding drug therapy, exercise, behaviour therapy or combinations of these interventions. Journal of Human Nutrition and Dietetics. 2004;17(4):293-316. [pmid: 15250841].
5 Blumenthal JA, Sherwood A, Gullette ECD, et al. Biobehavioral approaches to the treatment of essential hypertension. J Consult Clin Psychol. 2002;70(3):569-89. [pmid: 12090370].
6 Davies M. The reality of glycaemic control in insulin treated diabetes: Defining the clinical challenges. Int J Obes. 2004;28(SUPPL 2):S14-S22.
7 Khare MM, Huber R, Carpenter RA, et al. A lifestyle approach for reducing cardiovascular risk factors in underserved women: Design and methods of the Illinois WISEWOMAN program. J Women’s Health. 2009;18(3):409-19.
8 Rollins G. Modest lifestyle changes significantly reduce the risk of diabetes, study finds. Report on Medical Guidelines & Outcomes Research. 2005;12(18):1-2.
9 Wylie-Rosett J, Herman WH, Goldberg RB. Lifestyle intervention to prevent diabetes: intensive and cost effective. Curr Opin Lipidol. 2006;17(1):37-44. [pmid: 16407714].
10 Yamaoka K, Tango T. Efficacy of lifestyle education to prevent type 2 diabetes: a meta-analysis of randomized controlled trials. Diabetes Care. 2005;28(11):2780-6. [pmid: 16249558].
11 Young D, Furler J, Vale M, et al. Patient Engagement and Coaching for Health: The PEACH study - A cluster randomised controlled trial using the telephone to coach people with type 2 diabetes to engage with their GPs to improve diabetes care: A study protocol. BMC Fam Pract. 2007;8.

## Study design (n = 17)

1 Brunzell JD. Hypertriglyceridemia. New Engl J Med. 2007;357(10):1009-17. [pmid: 17804845].
2 Doggrell SA. Metformin & lifestyle intervention prevent type 2 diabetes: Lifestyle intervention has the greater effect. Expert Opinion on Pharmacotherapy. 2002;3(7):1011-3. [pmid: 12084000].
3 Domenech MI, Assad D, Mazzei ME, et al. Evaluation of the effectiveness of an ambulatory teaching/treatment programme for non-insulin dependent (type 2) diabetic patients. Acta Diabetol. 1995;32(3):143-7. [pmid: 8590781].
4 Fredrikson GN, Hedblad B, Nilsson JA, et al. Association between diet, lifestyle, metabolic cardiovascular risk factors, and plasma C-reactive protein levels. Metab Clin Exp. 2004;53(11):1436-42. [pmid: 15536598].
5 Harwell TS, Moore K, McDowall JM, et al. Cardiovascular risk factors in Montana American Indians with and without diabetes. Am J Prev Med. 2003;24(3):265-9. [pmid: 12657346].
6 Hernandez-Ronquillo L, Tellez-Zenteno JF, Garduno-Espinosa J, et al. Factors associated with therapy noncompliance in type-2 diabetes patients. Salud Publica Mex. 2003;45(3):191-7. [pmid: 12870420].
7 Kaati G, Bygren L-O, Vester M, et al. Outcomes of comprehensive lifestyle modification in inpatient setting. Patient Educ Couns. 2006;62(1):95-103. [pmid: 16139982].
8 Kosmala W, O’Moore-Sullivan T, Plaksej R, et al. Improvement of left ventricular function by lifestyle intervention in obesity: Contributions of weight loss and reduced insulin resistance. Diabetologia. 2009;52(11):2306-16. [pmid: 19727663].
9 Krook A, Holm I, Pettersson S, et al. Reduction of risk factors following lifestyle modification programme in subjects with type 2 (non-insulin dependent) diabetes mellitus. Clin Physiol Funct Imaging. 2003;23(1):21-30. [pmid: 12558610].
10 Linday LA. Trivalent chromium and the diabetes prevention program. Med Hypotheses. 1997;49(1):47-9. [pmid: 9247907].
11 Lowe J, Linjawi S, Mensch M, et al. Flexible eating and flexible insulin dosing in patients with diabetes: Results of an intensive self-management course. Diabetes Res Clin Pract. 2008;80(3):439-43. [pmid: 18353485].
12 McBride PE, Einerson JA, Grant H, et al. Putting the Diabetes Prevention Program into practice: a program for weight loss and cardiovascular risk reduction for patients with metabolic syndrome or type 2 diabetes mellitus. Journal of Nutrition, Health & Aging. 2008;12(10):745S-9S.
13 Ornish D, Lin J, Daubenmier J, et al. Increased telomerase activity and comprehensive lifestyle changes: a pilot study. Lancet Oncology. 2008;9(11):1048-57.
14 Oza N, Eguchi Y, Mizuta T, et al. A pilot trial of body weight reduction for nonalcoholic fatty liver disease with a home-based lifestyle modification intervention delivered in collaboration with interdisciplinary medical staff. J Gastroenterol. 2009;44(12):1203-8. [pmid: 19728009].
15 Prueksaritanond S, Tubtimtes S, Asavanich K, et al. Type 2 diabetic patient-centered care. J Med Assoc Thailand. 2004;87(4):345-52.
16 Satoh N, Shimatsu A, Kato Y, et al. Evaluation of the cardio-ankle vascular index, a new indicator of arterial stiffness independent of blood pressure, in obesity and metabolic syndrome. Hypertens Res. 2008;31(10):1921-30. [pmid: 19015600].
17 Schafer S, Kantartzis K, Machann J, et al. Lifestyle intervention in individuals with normal versus impaired glucose tolerance. Eur J Clin Invest. 2007;37(7):535-43. [pmid: 17576204].

## Population (n = 28)

1 Ades PA, Savage PD, Toth MJ, et al. High-calorie-expenditure exercise: A new approach to cardiac rehabilitation for overweight coronary patients. Circulation. 2009;119(20):2671-8. [pmid: 19433757].
2 Allen P, Thompson JL, Herman CJ, et al. Impact of periodic follow-up testing among urban American Indian women with impaired fasting glucose. Preventing Chronic Disease. 2008;5(3):A76. [pmid: 18558026].
3 Babazono A, Kame C, Ishihara R, et al. Patient-motivated prevention of lifestyle-related disease in Japan. A randomized controlled clinical trial. Disease Management & Health Outcomes. 2007;15(2):119-26.
4 Blum J. Evaluation of a combined approach to weight loss. Internet Journal of Nutrition & Wellness. 2009;7(1):8.
5 Camhi SM, Stefanick ML, Ridker PM, et al. Changes in C-reactive protein from low-fat diet and/or physical activity in men and women with and without metabolic syndrome. Metab Clin Exp. 2010;59(1):54-61. [pmid: 19709693].
6 Davey SG, Bracha Y, Svendsen KH, et al. Incidence of type 2 diabetes in the randomized multiple risk factor intervention trial. Ann Intern Med. 2005;142(5):313-22. [pmid: 15738450].
7 demark-Wahnefried W, Clipp EC, McBride C, et al. Design of FRESH START: A randomized trial of exercise and diet among cancer survivors. Med Sci Sports Exerc. 2003;35(3):415-24. [pmid: 12618570].
8 demark-Wahnefried W, Clipp EC, Lipkus IM, et al. Main outcomes of the FRESH START trial: A sequentially tailored, diet and exercise mailed print intervention among breast and prostate cancer survivors. J Clin Oncol. 2007;25(19):2709-18. [pmid: 17602076].
9 Eakin EG, Bull SS, Riley KM, et al. Resources for Health: A Primary-Care-Based Diet and Physical Activity Intervention Targeting Urban Latinos With Multiple Chronic Conditions. Health Psychol. 2007;26(4):392-400. [pmid: 17605558].
10 Eriksson KM, Westborg CJ, Eliasson MC. A randomized trial of lifestyle intervention in primary healthcare for the modification of cardiovascular risk factors. Scand J Public Health. 2006;34(5):453-61. [pmid: 16990155].
11 Ferrer RL, Mody-Bailey P, Jaén CR, et al. A medical assistant-based program to promote healthy behaviors in primary care. Ann Fam Med. 2009;7(6):504-12. [pmid: 19901309].
12 Goodrich DE, Larkin AR, Lowery JC, et al. Adverse events among high-risk participants in a home-based walking study: A descriptive study. Int J Behav Nutr Phys Act. 2007;4(20).
13 Gorin AA, Wing RR, Fava JL, et al. Weight loss treatment influences untreated spouses and the home environment: evidence of a ripple effect. Int J Obes. 2008;32(11):1678-84.
14 Herbert JR, Ebbeling CB, Olendzki BC, et al. Change in women’s diet and body mass following intensive intervention for early-stage breast cancer. J Am Diet Assoc. 2001;101(4):421-31. [pmid: 11320947].
15 Kalergis M, Pacaud D, Strychar I, et al. Optimizing insulin delivery: Assessment of three strategies in intensive diabetes management. Diabetes, Obesity and Metabolism. 2000;2(5):299-305.
16 Kelley MA. Culturally appropriate breast health educational intervention program for African-American women. J Natl Black Nurses Assoc. 2004;15(1):36-47. [pmid: 15712819].
17 Lakerveld J, Bot SDM, Chinapaw MJ, et al. Primary prevention of diabetes mellitus type 2 and cardiovascular diseases using a cognitive behavior program aimed at lifestyle changes in people at risk: Design of a randomized controlled trial. BMC Endocr Disord. 2008;(6).
18 Lennon O. Cardiac rehabilitation adapted to transient ischaemic attack and stroke (CRAFTS): a randomised controlled trial. BMC Neurol. 2009.
19 Lien LF, Brown AJ, Ard JD, et al. Effects of PREMIER lifestyle modifications on participants with and without the metabolic syndrome. Hypertension. 2007;50(4):609-16. [pmid: 17698724].
20 Mosher CE, Fuemmeler BF, Sloane R, et al. Change in self-efficacy partially mediates the effects of the FRESH START intervention on cancer survivors’ dietary outcomes. PSYCHO ONCOL. 2008;17(10):1014-23.
21 Narayan KM, Hoskin M, Kozak D, et al. Randomized clinical trial of lifestyle interventions in Pima Indians: a pilot study. Diabet Med. 1998;15(1):66-72. [pmid: 9472866].
22 Perry TL, Mann JI, Lewis-Barned NJ, et al. Lifestyle intervention in people with insulin-dependent diabetes mellitus (IDDM). Eur J Clin Nutr. 1997;51(11):757-63. [pmid: 9368810].
23 Snyder DC, Sloane R, Lobach D, et al. Differences in baseline characteristics and outcomes at 1- and 2-year follow-up of cancer survivors accrued via self-referral versus cancer registry in the FRESH START Diet and exercise trial. Cancer Epidemiol Biomarkers Prev. 2008;17(5):1288-94. [pmid: 18483353].
24 Tate DF, Jackvony EH, Wing RR. Effects of Internet behavioral counseling on weight loss in adults at risk for type 2 diabetes: a randomized trial. Journal of the American Medical Association. 2003;289(14):1833-6. [pmid: 12684363].
25 Thoolen BJ, De Ridder D, Bensing J, et al. Beyond good intentions: the role of proactive coping in achieving sustained behavioural change in the context of diabetes management. Psychology & Health. 2009;24(3):237-54. [pmid: 20204991].
26 Vitola BE, Deivanayagam S, Stein RI, et al. Weight loss reduces liver fat and improves hepatic and skeletal muscle insulin sensitivity in obese adolescents. Obesity. 2009;17(9):1744-8. [pmid: 19498349].
27 Weinstock RS, Dai H, Wadden TA. Diet and exercise in the treatment of obesity: effects of 3 interventions in insulin resistance. Arch Intern Med. 1998;158(22):2477-83. [pmid: 9855386].
28 Woollard J, Burke V, Beilin LJ. Effects of general practice-based nurse-counselling on ambulatory blood pressure and antihypertensive drug prescription in patients at increased risk of cardiovascular disease. J Hum Hypertens. 2003;17(10):689-95. [pmid: 14504627].

## Intervention (n = 33)

1 Best JH, Boye KS, Rubin RR, et al. Improved treatment satisfaction and weight-related quality of life with exenatide once weekly or twice daily. Diabet Med. 2009;26(7):722-8. [pmid: 19573122].
2 Carr DB, Utzschneider KM, Boyko EJ, et al. A reduced-fat diet and aerobic exercise in Japanese Americans with impaired glucose tolerance decreases intra-abdominal fat and improves insulin sensitivity but not beta-cell function. Diabetes. 2005;54(2):340-7. [pmid: 15677490].
3 Cocco G, Pandolfi S, Rousson V. Sufficient weight reduction decreases cardiovascular complications in diabetic patients with the metabolic syndrome: A randomized study of orlistat as an adjunct to lifestyle changes (diet and exercise). HeartDrug. 2005;5(2):68-74.
4 Dale KS, Mann JI, McAuley KA, et al. Sustainability of lifestyle changes following an intensive lifestyle intervention in insulin resistant adults: Follow-up at 2-years. Asia Pac J Clin Nutr. 2009;18(1):114-20. [pmid: 19329404].
5 Daly RM, Dunstan DW, Owen N, et al. Does high-intensity resistance training maintain bone mass during moderate weight loss in older overweight adults with type 2 diabetes?. Osteoporos Int. 2005;16(12):1703-12. [pmid: 15937634].
6 Dasgupta K, Grover SA, Da CD, et al. Impact of modified glucose target and exercise interventions on vascular risk factors. Diabetes Res Clin Pract. 2006;72(1):53-60. [pmid: 16256242].
7 Giannopoulou I, Fernhall B, Carhart R, et al. Effects of diet and/or exercise on the adipocytokine and inflammatory cytokine levels of postmenopausal women with type 2 diabetes. Metab Clin Exp. 2005;54(7):866-75. [pmid: 15988694].
8 Kim HS, Jeong HS. A nurse short message service by cellular phone in type-2 diabetic patients for six months. J Clin Nurs. 2007;16(6):1082-7. [pmid: 17518883].
9 Kosaka K, Noda M, Kuzuya T. Prevention of type 2 diabetes by lifestyle intervention: a Japanese trial in IGT males. Diabetes Res Clin Pract. 2005;67(2):152-62. [pmid: 15649575].
10 Kristal AR, Chi C, Tangen CM, et al. Associations of demographic and lifestyle characteristics with prostate-specific antigen (PSA) concentration and rate of PSA increase. Cancer. 2006;106(2):320-8. [pmid: 16342294].
11 Kristal AR, Arnold KB, Schenk JM, et al. Race/ethnicity, obesity, health related behaviors and the risk of symptomatic benign prostatic hyperplasia: results from the prostate cancer prevention trial. J Urol. 2007;177(4):1395-400. [pmid: 17382740].
12 Kyrios M, Moore SM, Hackworth N, et al. The influence of depression and anxiety on outcomes after an intervention for prediabetes. Med J Aust. 2009;190(7:Suppl):5.
13 Lepore SJ, Helgeson VS. Psychoeducational support group enhances quality of life after prostate cancer. Canc Res Ther Contr. 1999;8(1–2):81-91.
14 Liao D, Asberry PJ, Shofer JB, et al. Improvement of BMI, body composition, and body fat distribution with lifestyle modification in Japanese Americans with impaired glucose tolerance. Diabetes Care. 2002;25(9):1504-10. [pmid: 12196418].
15 Maji D. Prevention of type 2 diabetes in the prediabetic population. J Indian Med Assoc. 2005;(11):609-11. [pmid: 16570766].
16 McAuley KA, Williams SM, Mann JI, et al. Intensive lifestyle changes are necessary to improve insulin sensitivity: a randomized controlled trial. Diabetes Care. 2002;25(3):445-52. [pmid: 11874928].
17 Melchionda N, Forlani G, La RL, et al. Disease management of the metabolic syndrome in a community: Study design and process analysis on baseline data. Metabolic Syndrome and Related Disorders. 2006;4(1):7-16. [pmid: 18370765].
18 Newman VA, Thomson CA, Rock CL, et al. Achieving substantial changes in eating behavior among women previously treated for breast cancer -- an overview of the intervention. J Am Diet Assoc. 2005;105(3):382. [pmid: 15746825].
19 Ohira T, Schmitz KH, Ahmed RL, et al. Effects of weight training on quality of life in recent breast cancer survivors: The weight training for breast cancer survivors (WTBS) study. Cancer. 2006;106(9):2076-83. [pmid: 16568409].
20 Pierce JP, Natarajan L, Caan BJ, et al. Influence of a diet very high in vegetables, fruit, and fiber and low in fat on prognosis following treatment for breast cancer: the Women’s Healthy Eating and Living (WHEL) randomized trial. Journal of the American Medical Association. 2007;298(3):289-98. [pmid: 17635889].
21 Pritchard DA, Hyndman J, Taba F. Nutritional counselling in general practice: a cost effective analysis. Journal of Epidemiology & Community Health. 1999;53(5):311-6. [pmid: 10396539].
22 Redmon JB, Raatz SK, Kwong CA, et al. Pharmacologic induction of weight loss to treat type 2 diabetes. Diabetes Care. 1999;22(6):896-903. [pmid: 10372238].
23 Reseland JE, Anderssen SA, Solvoll K, et al. Effect of long-term changes in diet and exercise on plasma leptin concentrations. Am J Clin Nutr. 2001;73(2):240-5. [pmid: 11157319].
24 Ridgeway NA, Harvill DR, Harvill LM, et al. Improved control of type 2 diabetes mellitus: A practical education/behavior modification program in a primary care clinic. South Med J. 1999;92(7):667-72. [pmid: 10414474].
25 Satpute DA, Patil PH, Kuchake VG, et al. Assessment of impact of patient counselling, nutrition and exercise in patients with Type 2 Diabetes Mellitus. International Journal of PharmTech Research. 2009;1(1):1-21.
26 Sun J, Wang Y, Chen X, et al. An integrated intervention program to control diabetes in overweight Chinese women and men with type 2 diabetes. Asia Pac J Clin Nutr. 2008;17(3):514-24. [pmid: 18818173].
27 Torjesen PA, Birkeland KI, Anderssen SA, Hjermann I, Holme I, Urdal P. Lifestyle changes may reverse development of the insulin resistance syndrome. The Oslo Diet and Exercise Study: a randomized trial. Diabetes Care. 1997;(1):26-31. [pmid: 9028689].
28 Varroud-Vial M, Simon D, Attali J, et al. Improving glycaemic control of patients with type 2 diabetes in a primary care setting: A French application of the Staged Diabetes Management programme. Diabet Med. 2004;21(6):592-8. [pmid: 15154945].
29 Watson GS, Reger MA, Baker LD, et al. Effects of exercise and nutrition on memory in Japanese Americans with impaired glucose tolerance. Diabetes Care. 2006;29(1):135-6. [pmid: 16373910].
30 Winters BL, Mitchell DC, Smiciklas-Wright H, et al. Dietary patterns in women treated for breast cancer who successfully reduce fat intake: the Women’s Intervention Nutrition Study (WINS). J Am Diet Assoc. 2004;104(4):551-9. [pmid: 15054339].
31 Wolf AM, Siadaty M, Yaeger B, et al. Effects of Lifestyle Intervention on Health Care Costs: Improving Control with Activity and Nutrition (ICAN). J Am Diet Assoc. 2007;107(8):1365-73. [pmid: 17659904].
32 Wolf AM, Siadaty MS, Crowther JQ, et al. Impact of lifestyle intervention on lost productivity and disability: improving control with activity and nutrition. Journal of Occupational & Environmental Medicine. 2009;51(2):139-45. [pmid: 19209034].
33 Wycherley TP, Brinkworth GD, Noakes M, et al. Effect of caloric restriction with and without exercise training on oxidative stress and endothelial function in obese subjects with type 2 diabetes. Diabetes, Obesity and Metabolism. 2008;10(11):1062-73.

## Length of intervention or postintervention followup (n=39)

1 Atak N, Gurkan T, Kose K. The effect of education on knowledge, self management behaviours and self efficacy of patients with type 2 diabetes. Aust J Adv Nurs. 2008;26(2):66-74.
2 Babamoto KS, Sey KA, Camilleri AJ, et al. Improving diabetes care and health measures among hispanics using community health workers: results from a randomized controlled trial. Health Education & Behavior. 2009;36(1):113-26. [pmid: 19188371].
3 Barclay C, Procter KL, Glendenning R, et al. Can type 2 diabetes be prevented in UK general practice? A lifestyle-change feasibility study (ISAIAH). Br J Gen Pract. 2008;58(553):541-7. [pmid: 18682012].
4 Blickle JF, Hancu N, Piletic M, et al. Insulin glargine provides greater improvements in glycaemic control vs. intensifying lifestyle management for people with type 2 diabetes treated with OADs and 7–8% A1c levels. The TULIP study. Diabetes, Obesity & Metabolism. 2009;11(4):379-86.
5 Cheong SH, McCargar LJ, Paty BW, et al. The First Step First Bite Program: guidance to increase physical activity and daily intake of low-glycemic index foods. J Am Diet Assoc. 2009;109(8):1411-6. [pmid: 19631048].
6 Darga LL, Magnan M, Mood D, et al. Quality of life as a predictor of weight loss in Obese, early-stage breast cancer survivors. Oncol Nurs Forum. 2007;34(1):86-92. [pmid: 17562636].
7 Davies MJ, Heller S, Skinner TC, et al. Effectiveness of the diabetes education and self management for ongoing and newly diagnosed (DESMOND) programme for people with newly diagnosed type 2 diabetes: cluster randomised controlled trial. BMJ. 2008;336(7642):491-5. [pmid: 18276664].
8 Dyson PA, Hammersley MS, Morris RJ, et al. The Fasting Hyperglycaemia Study: II. Randomized controlled trial of reinforced healthy-living advice in subjects with increased but not diabetic fasting plasma glucose. Metabolism: Clinical & Experimental. 1997;46(12:Suppl 1):5.
9 Elder C, Aickin M, Bauer V, et al. Randomized trial of a whole-system ayurvedic protocol for type 2 diabetes. Altern Ther Health Med. 2006;12(5):24-30. [pmid: 17017752].
10 Estabrooks PA, Nelson CC, Xu S, et al. The frequency and behavioral outcomes of goal choices in the self-management of diabetes. Diabetes Educ. 2005;31(3):391-400. [pmid: 15919639].
11 Glasgow RE, Strycker LA, King DK, et al. Robustness of a computer-assisted diabetes self-management intervention across patient characteristics, healthcare settings, and intervention staff. Am J Manag Care. 2006;12(3):137-45. [pmid: 16524346].
12 Guo L-X, Pan Q, Wang X-X, et al. Effect of short term intensive multitherapy on carotid intima-media thickness in patients with newly diagnosed type 2 diabetes mellitus. Chin Med J. 2008;121(8):687-90. [pmid: 18701019].
13 gurs-Collins TD, Kumanyika SK, Ten Have TR, et al. A randomized controlled trial of weight reduction and exercise for diabetes management in older African-American subjects. Diabetes Care. 1997;20(10):1503-11. [pmid: 9314625].
14 Hartwell SL, Kaplan RM, Wallace JP. Comparison of behavioral interventions for control of type II diabetes mellitus. Behavior Therapy. 1986;(4):447-61.
15 Haus JM, Solomon TP, Marchetti CM, et al. Free fatty acid-induced hepatic insulin resistance is attenuated following lifestyle intervention in obese individuals with impaired glucose tolerance. Journal of Clinical Endocrinology & Metabolism. 2010;95(1):323-7. [pmid: 19906790].
16 Kaplan RM, Hartwell SL, Wilson DK, et al. Effects of diet and exercise interventions on control and quality of life in non-insulin-dependent diabetes mellitus. J Gen Intern Med. 1987;2(4):220-8. [pmid: 3302144].
17 Kim SH, Lee SJ, Kang ES, et al. Effects of lifestyle modification on metabolic parameters and carotid intima-media thickness in patients with type 2 diabetes mellitus. Metabolism: Clinical & Experimental. 2006;55(8):1053-9. [pmid: 16839841].
18 Kirkman MS, Weinberger M, Landsman PB, et al. A telephone-delivered intervention for patients with NIDDM. Effect on coronary risk factors. Diabetes Care. 1994;17(8):840-6. [pmid: 7956628].
19 Laitinen J, Uusitupa M, Ahola I, et al. Metabolic and dietary variables associated with glycaemic control in patients with recently diagnosed Type II diabetes mellitus. Diabetes nutr metab clin exp. 1994;7(2):77-87.
20 Lerman RH, Minich DM, Darland G, et al. Enhancement of a modified Mediterranean-style, low glycemic load diet with specific phytochemicals improves cardiometabolic risk factors in subjects with metabolic syndrome and hypercholesterolemia in a randomized trial. Nutr Metab. 2008;5(1).
21 Lindahl B, Nilsson TK, Jansson J-H, et al. Improved fibrinolysis by intense lifestyle intervention. A randomized trial in subjects with impaired glucose tolerance. J Intern Med. 1999;246(1):105-12. [pmid: 10447232].
22 Mayer-Davis EJ, D’antonio A, Martin M, et al. Pilot study of strategies for effective weight management in type 2 diabetes: Pounds off with empowerment (POWER). Fam Commun Health. 2001;24(2):27-35.
23 McKibbin CL, Patterson TL, Norman G, et al. A lifestyle intervention for older schizophrenia patients with diabetes mellitus: a randomized controlled trial. Schizophr Res. 2006;86(1–3):36-44. [pmid: 16842977].
24 Mefferd K, Nichols JF, Pakiz B, et al. A cognitive behavioral therapy intervention to promote weight loss improves body composition and blood lipid profiles among overweight breast cancer survivors. Breast Cancer Res Treat. 2007;104(2):145-52. [pmid: 17058023].
25 Mosher CE, Sloane R, Morey MC, et al. Associations between lifestyle factors and quality of life among older long-term breast, prostate, and colorectal cancer survivors. Cancer. 2009;115(17):4001-9. [pmid: 19637244].
26 Oh J-A, Kim H-S, Yoon K-H, et al. A telephone-delivered intervention to improve glycemic control in type 2 diabetic patients. Yonsei Med J. 2003;44(1):1-8. [pmid: 12619168].
27 Page RC, Harnden KE, Walravens NK, et al. ‘Healthy living’ and sulphonylurea therapy have different effects on glucose tolerance and risk factors for vascular disease in subjects with impaired glucose tolerance. Q J Med. 1993;86(3):145-54. [pmid: 8483989].
28 Parra-Medina D, D’antonio A, Smith SM, et al. Successful recruitment and retention strategies for a randomized weight management trial for people with diabetes living in rural, medically underserved counties of South Carolina: the POWER study. J Am Diet Assoc. 2004;104(1):70-5. [pmid: 14702587].
29 Pettman TL, Buckley JD, Misan GMH, et al. Health benefits of a 4-month group-based diet and lifestyle modification program for individuals with metabolic syndrome. Obes Res Clin Pract. 2009;3(4):221-35. [pmid: 24973150].
30 Pettman TL, Misan GMH, Owen K, et al. Self-management for obesity and cardio-metabolic fitness: Description and evaluation of the lifestyle modification program of a randomised controlled trial. Int J Behav Nutr Phys Act. 2008;5.
31 St GA, Bauman A, Johnston A, et al. Effect of a lifestyle intervention in patients with abnormal liver enzymes and metabolic risk factors. Journal of Gastroenterology & Hepatology. 2009;24(3):399-407. [pmid: 19067776].
32 Straznicky NE, Lambert EA, Nestel PJ, et al. Sympathetic neural adaptation to hypocaloric diet with or without exercise training in obese metabolic syndrome subjects. Diabetes. 2010;59(1):71-9. [pmid: 19833893].
33 Tuthill A, Quinn A, Mccolgan D, et al. A prospective randomized controlled trial of lifestyle intervention on quality of life and cardiovascular risk score in patients with obesity and type 2 diabetes. Diabetes, Obesity and Metabolism. 2007;9(6):917-9.
34 Watanabe M, Okayama A, Shimamoto K, et al. Short-term effectiveness of an individual counseling program for impaired fasting glucose and mild type 2 diabetes in Japan: a multi-center randomized control trial. Asia Pac J Clin Nutr. 2007;16(3):489-97. [pmid: 17704031].
35 Welschen LM, van Oppen P, Dekker JM, Bouter LM, Stalman WA, Nijpels G. The effectiveness of adding cognitive behavioural therapy aimed at changing lifestyle to managed diabetes care for patients with type 2 diabetes: design of a randomised controlled trial. BMC Public Health. 2007.
36 White N, Carnahan J, Nugent CA, et al. Management of obese patients with diabetes mellitus: comparison of advice education with group management. Diabetes Care. 1986;9(5):490-6. [pmid: 3769719].
37 Whittemore R, Melkus GD, Sullivan A, et al. A nurse-coaching intervention for women with type 2 diabetes. Diabetes Educ. 2004;30(5):795-804. [pmid: 15510531].
38 Woo J, Sea MM, Tong P, et al. Effectiveness of a lifestyle modification programme in weight maintenance in obese subjects after cessation of treatment with Orlistat. J Eval Clin Pract. 2007;13(6):853-9. [pmid: 18070255].
39 Yannakoulia M, Poulia KA, Mylona E, et al. Effectiveness of an intensive nutritional intervention in patients with type 2 diabetes mellitus: Results from a pilot study. Rev Diabetic Stud. 2007;4(4):226-30. [pmid: 18338075].

## Comparator (n=5)

1 Aas AM, Bergstad I, Thorsby PM, et al. An intensified lifestyle intervention programme may be superior to insulin treatment in poorly controlled Type 2 diabetic patients on oral hypoglycaemic agents: results of a feasibility study. Diabet Med. 2005;22(3):316-22. [pmid: 15717881].
2 Dixon JB, O’Brien PE, Playfair J, et al. Adjustable gastric banding and conventional therapy for type 2 diabetes: A randomized controlled trial. Journal of the American Medical Association. 2008;299(3):316-23. [pmid: 18212316].
3 Pascale RW, Wing RR, Butler BA, et al. Effects of a behavioral weight loss program stressing calorie restriction versus calorie plus fat restriction in obese individuals with NIDDM or a family history of diabetes. Diabetes Care. 1995;18(9):1241-8. [pmid: 8612437].
4 Smith DE, Heckemeyer CM, Kratt PP, et al. Motivational interviewing to improve adherence to a behavioral weight-control program for older obese women with NIDDM. A pilot study. Diabetes Care. 1997;20(1):52-4. [pmid: 9028693].
5 West DS, DiLillo V, Bursac Z, et al. Motivational interviewing improves weight loss in women with type 2 diabetes. Diabetes Care. 2007;30(5):1081-7. [pmid: 17337504].

## Outcomes (n=16)

1 Ackermann RT, Marrero DG, Hicks KA, et al. An evaluation of cost sharing to finance a diet and physical activity intervention to prevent diabetes. Diabetes Care. 2006;29(6):1237-41. [pmid: 16732002].
2 Chaveepojnkamjorn W, Pichainarong N, Schelp FP, et al. A randomized controlled trial to improve the quality of life of type 2 diabetic patients using a self-help group program. Southeast Asian Journal of Tropical Medicine & Public Health. 2009;40(1):169-76. [pmid: 19323050].
3 Clark M, Hampson SE, Avery L, et al. Effects of a brief tailored intervention on the process and predictors of lifestyle behaviour change in patients with type 2 diabetes. Psychology, Health and Medicine. 2004;9(4):440-9.
4 Clark M, Hampson SE. Implementing a psychological intervention to improve lifestyle self-management in patients with type 2 diabetes. Patient Educ Couns. 2001;42(3):247-56. [pmid: 11164324].
5 Djuric Z, DiLaura NM, Jenkins I, et al. Combining weight-loss counseling with the Weight Watchers plan for obese breast cancer survivors. Obes Res. 2002;10(7):657-65. [pmid: 12105288].
6 Eakin E, Reeves M, Lawler S, et al. Telephone counseling for physical activity and diet in primary care patients. Am J Prev Med. 2009;36(2):142-9. [pmid: 19062240].
7 Eakin EG, Reeves MM, Lawler SP, et al. The Logan Healthy Living Program: a cluster randomized trial of a telephone-delivered physical activity and dietary behavior intervention for primary care patients with type 2 diabetes or hypertension from a socially disadvantaged community--rationale, design and recruitment. Contemp Clin Trials. 2008;29(3):439-54. [pmid: 18055274].
8 Foster GD, Borradaile KE, Sanders MH, et al. A randomized study on the effect of weight loss on obstructive sleep apnea among obese patients with type 2 diabetes: The sleep AHEAD study. Arch Intern Med. 2009;169(17):1619-26. [pmid: 19786682].
9 Graves N, Barnett AG, Halton KA, et al. Cost-effectiveness of a telephone-delivered intervention for physical activity and diet. PLoS ONE [Electronic Resource]. 2009;4(9):e7135.
10 Handley MA, Shumway M, Schillinger D. Cost-effectiveness of automated telephone self-management support with nurse care management among patients with diabetes. Ann Fam Med. 2008;6(6):512-8. [pmid: 19001303].
11 Herman WH, Hoerger TJ, Brandle M, et al. The cost-effectiveness of lifestyle modification or metformin in preventing type 2 diabetes in adults with impaired glucose tolerance. Ann Intern Med. 2005;142(5):323-32. [pmid: 15738451].
12 Ma J, King AC, Wilson SR, et al. Evaluation of lifestyle interventions to treat elevated cardiometabolic risk in primary care (E-LITE): a randomized controlled trial. BMC Fam Pract. 2009;10:71. [pmid: 19909549].
13 Merriam PA, Tellez TL, Rosal MC, et al. Methodology of a diabetes prevention translational research project utilizing a community-academic partnership for implementation in an underserved Latino community. BMC Med Res Methodol. 2009;9:20. [pmid: 19284663].
14 Munakata M. Japanese study to organize proper lifestyle modifications for metabolic syndrome (J-STOP-MetS): design and method. Vasc Health Risk Manage. 2008;(2):415-20.
15 Saxton JM, Daley A, Woodroofe N, et al. Study protocol to investigate the effect of a lifestyle intervention on body weight, psychological health status and risk factors associated with disease recurrence in women recovering from breast cancer treatment. BMC Cancer. 2006;6:35. [pmid: 16469108].
16 Vadstrup ES, Frolich A, Perrild H, et al. Lifestyle intervention for type 2 diabetes patients: trial protocol of The Copenhagen Type 2 Diabetes Rehabilitation Project. BMC Public Health. 2009;9:166. [pmid: 19480671].

## Outcomes not separated by group (n=1)

1 Djuric Z, DiLaura NM, Jenkins I, et al. Combining weight-loss counseling with the Weight Watchers plan for obese breast cancer survivors. Obes Res. 2002;10(7):657-65. [pmid: 12105288].

## Language (n=1)

1 Yoo JS, Kim EJ, Lee SJ. The effects of a comprehensive life style modification program on glycemic control and stress response in type 2 diabetes. Taehan Kanho Hakhoe chi. 2006;(5):751-60. [pmid: 16953132].

## Unable to retrieve (n=4)

1 Hsieh CJ, Wang PW. Effectiveness of weight loss in the elderly with type 2 diabetes mellitus. J Endocrinol Invest. 2005;28(11):973-7. [pmid: 16483174].
2 Malhotra V, Singh S, Tandon OP, et al. Effect of Yoga asanas on nerve conduction in type 2 diabetes. Indian Journal of Physiology & Pharmacology. 2002;46(3):298-306. [pmid: 12613392].
3 Vanninen E, Uusitupa M, Lansimies E, et al. Effect of metabolic control on autonomic function in obese patients with newly diagnosed type 2 diabetes. Diabet Med. 1993;10(1):66-73. [pmid: 8435991].
4 Ratzmann KP, Zander E, Witt S, et al. Effect of a combined diet-training program on the insulin sensitivity of obese persons with normal or disordered glucose tolerance. Z Gesamte Inn Med. 1982;37(10):304-8. [pmid: 7048770].

## Duplicate (n=1)

1 Prediabetes: meeting an epidemic with new treatment goals. Johns Hopkins Med Lett Health After 50. 2009;21(3):1-2.