# List of Companion Publications

Type 2 Diabetes

Main publication | Companion studies
Gaede P, Vedel P, Parving HH, et al. Intensified multifactorial intervention in patients with type 2 diabetes mellitus and microalbuminuria: The Steno type 2 randomized study. Lancet 1999;353(9153):617–22. | Gaede P, Beck M, Vedel P, et al. Limited impact of lifestyle education in patients with Type 2 diabetes mellitus and microalbuminuria: results from a randomized intervention study. Diabet Med 2001;18(2):104–8.
| Gaede P, Lund-Andersen H, Parving HH, et al. Effect of a multifactorial intervention on mortality in type 2 diabetes. N Engl J Med 2008;358(6):580–91.
| Gaede P, Vedel P, Larsen N, et al. Multifactorial intervention and cardiovascular disease in patients with type 2 diabetes. N Engl J Med 2003;348(5):383–93.
Keyserling TC, Samuel-Hodge CD, Ammerman AS, et al. A randomized trial of an intervention to improve self-care behaviors of African-American women with type 2 diabetes: impact on physical activity. Diabetes Care 2002;25(9):1576–83. | Keyserling TC, Ammerman AS, Samuel-Hodge CD, et al. A diabetes management program for African American women with type 2 diabetes. Diabetes Educ 2000;26(5):797–805.
Look AHEAD Research Group, Pi-Sunyer X, Blackburn G, et al. Reduction in weight and cardiovascular disease risk factors in individuals with type 2 diabetes: one-year results of the look AHEAD trial. Diabetes Care 2007;30(6):1374–83. | Bray GA. Baseline characteristics of the randomized cohort from the Look AHEAD (Action for Health in Diabetes) study. Diab Vasc Dis Res 2006;3(3):202–15.
| Espeland M. Look AHEAD (Action for Health in Diabetes): Design and methods for a clinical trial of weight loss for the prevention of cardiovascular disease in type 2 diabetes. Control Clin Trials 2003;24(5):610–28.
| Gorin AA, Niemeier HM, Hogan P, et al. Binge eating and weight loss outcomes in overweight and obese individuals with type 2 diabetes: results from the Look AHEAD trial. Arch Gen Psychiatry 2008;65(12):1447–55.
| Jakicic JM, Jaramillo SA, Balasubramanyam A, et al. Effect of a lifestyle intervention on change in cardiorespiratory fitness in adults with type 2 diabetes: results from the Look AHEAD Study. Int J Obes 2009;33(3):305–16.
| Wadden TA. The look AHEAD study: A description of the lifestyle intervention and the evidence supporting it. Obesity 2006;14(5):737–52.
| Wadden TA, West DS, Neiberg RH, et al. One-year weight losses in the Look AHEAD study: factors associated with success. Obesity 2009;17(4):713–22.
| Williamson DA, Rejeski J, Lang W, et al. Impact of a weight management program on health-related quality of life in overweight adults with type 2 diabetes. Arch Intern Med 2009;169(2):163–71.
Mayer-Davis EJ, D’Antonio AM, Smith SM, et al. Pounds off with empowerment (POWER): A clinical trial of weight management strategies for black and white adults with diabetes who live in medically underserved rural communities. Am J Public Health 2004;94(10):1736–42. | Culturally appropriate lifestyle interventions promote weight loss in rural dwelling people with type 2 diabetes. Evidence-Based Healthcare and Public Health 2005;9(3):231–2.
| Mayer-Davis EJ, D’antonio A, Martin M, et al. Pilot study of strategies for effective weight management in type 2 diabetes: Pounds off with empowerment (POWER). Fam Commun Health 2001;24(2):27–35.
| Parra-Medina D, D’antonio A, Smith SM, et al. Successful recruitment and retention strategies for a randomized weight management trial for people with diabetes living in rural, medically underserved counties of South Carolina: the POWER study. J Am Diet Assoc 2004;104(1):70–5.
Menard J, Payette H, Baillargeon J-P, et al. Efficacy of intensive multitherapy for patients with type 2 diabetes mellitus: A randomized controlled trial. Can Med Assoc J 2005;173(12):1457–63. | Menard J, Payette H, Dubuc N, et al. Quality of life in type 2 diabetes patients under intensive multi-therapy. Diabetes Metab 2007;33(1):54–60.
Toobert DJ, Glasgow RE, Strycker LA, et al. Biologic and quality-of-life outcomes from the Mediterranean Lifestyle Program: A randomized clinical trial. Diabetes Care 2003;26(8):2288–93. | Barrera M, Jr., Toobert DJ, Angell KL, et al. Social support and social-ecological resources as mediators of lifestyle intervention effects for type 2 diabetes. J Health Psychol 2006;11(3):483–95.
Toobert DJ, Glasgow RE, Strycker LA, et al. Biologic and quality-of-life outcomes from the Mediterranean Lifestyle Program: A randomized clinical trial. Diabetes Care 2003;26(8):2288–93. | Toobert DJ, Glasgow RE, Strycker LA, et al. Long-term effects of the Mediterranean lifestyle program: A randomized clinical trial for postmenopausal women with type 2 diabetes. International Journal of Behavioral Nutrition and Physical Activity 4, 2007 Article Number: 1 Date of Publication: 2007 2007.
Toobert DJ, Glasgow RE, Strycker LA, et al. Biologic and quality-of-life outcomes from the Mediterranean Lifestyle Program: A randomized clinical trial. Diabetes Care 2003;26(8):2288–93. | Toobert DJ, Strycker LA, Glasgow RE, et al. Effects of the Mediterranean lifestyle program on multiple risk behaviors and psychosocial outcomes among women at risk for heart disease. Ann Behav Med 2005;29(2):128–37.
Toobert DJ, Glasgow RE, Strycker LA, et al. Biologic and quality-of-life outcomes from the Mediterranean Lifestyle Program: A randomized clinical trial. Diabetes Care 2003;26(8):2288–93. | Toobert DJ, Strycker LA, Glasgow RE, et al. Enhancing support for health behavior change among women at risk for heart disease: the Mediterranean Lifestyle Trial. Health Educ Res 2002;17(5):574–85.

Metabolic Syndrome

Main publication | Companion studies
Bo S, Ciccone G, Baldi C, et al. Effectiveness of a lifestyle intervention on metabolic syndrome. A randomized controlled trial. J Gen Intern Med 2007;22(12):1695–703. | Bo S, Ciccone G, Baldi I, et al. Plasma visfatin concentrations after a lifestyle intervention were directly associated with inflammatory markers. Nutr Metab Cardiovasc Dis 2009;19(6):423–30.
Bo S, Ciccone G, Baldi C, et al. Effectiveness of a lifestyle intervention on metabolic syndrome. A randomized controlled trial. J Gen Intern Med 2007;22(12):1695–703. | Bo S, Ciccone G, Guidi S, et al. Diet or exercise: What is more effective in preventing or reducing metabolic alterations? Eur J Endocrinol 2008;159(6):685–91.
Bo S, Ciccone G, Baldi C, et al. Effectiveness of a lifestyle intervention on metabolic syndrome. A randomized controlled trial. J Gen Intern Med 2007;22(12):1695–703. | Bo S, Gambino R, Ciccone G, et al. Effects of TCF7L2 polymorphisms on glucose values after a lifestyle intervention. Am J Clin Nutr 2009;90(6):1502–8.
Eriksson J, Lindstrom J, Valle T, et al. Prevention of Type II diabetes in subjects with impaired glucose tolerance: The Diabetes Prevention Study (DPS) in Finland. Study design and 1-year interim report on the feasibility of the lifestyle intervention programme. Diabetologia 1999;42(7):793–801. | Evans MF. Can we prevent high-risk patients from getting type 2 diabetes? Can Fam Phys 2002;48(FEB.):279–81.
| Hamalainen H, Ronnemaa T, Virtanen A, et al. Improved fibrinolysis by an intensive lifestyle intervention in subjects with impaired glucose tolerance. The Finnish Diabetes Prevention Study. Diabetologia 2005;48(11):2248–53.
| Herder C, Peltonen M, Koenig W, et al. Anti-inflammatory effect of lifestyle changes in the Finnish Diabetes Prevention Study. Diabetologia 2009;52(3):433–42.
| Kilpelainen TO, Lakka TA, Laaksonen DE, et al. Physical activity modifies the effect of SNPs in the SLC2A2 (GLUT2) and ABCC8 (SUR1) genes on the risk of developing type 2 diabetes. Physiological Genomics 2007;31(2):264–72.
| Kubaszek A, Pihlajamaki J, Komarovski V, et al. Promoter polymorphisms of the TNF-alpha (G-308A) and IL-6 (C-174G) genes predict the conversion from impaired glucose tolerance to type 2 diabetes: The Finnish Diabetes Prevention study. Diabetes 2003;52(7):1872–6
| Laaksonen DE, Lindstrom J, Lakka TA, et al. Physical activity in the prevention of type 2 diabetes: the Finnish diabetes prevention study. Diabetes 2005;54(1):158–65.
| Laukkanen O. Common polymorphisms in the genes regulating the early insulin signalling pathway: effects on weight change and the conversion from impaired glucose tolerance to Type 2 diabetes. The Finnish Diabetes Prevention Study. Diabetologia 2004;(5):871–7.
| Lindstrom J. Sustained reduction in the incidence of type 2 diabetes by lifestyle intervention: follow-up of the Finnish Diabetes Prevention Study. Lancet 2006;(9548):1673–9.
| Lindstrom J, Eriksson JG, Valle TT, et al. Prevention of diabetes mellitus in subjects with impaired glucose tolerance in the Finnish Diabetes Prevention Study: results from a randomized clinical trial. J Am Soc Nephrol 2003;14(7:Suppl 2):Suppl-13.
| Lindstrom J, Louheranta A, Mannelin M, et al. The Finnish Diabetes Prevention Study (DPS): Lifestyle intervention and 3-year results on diet and physical activity. Diabetes Care 2003;26(12):3230–6.
| Tuomilehto J, Lindstrom J, Eriksson JG, et al. Prevention of type 2 diabetes mellitus by changes in lifestyle among subjects with impaired glucose tolerance. New Engl J Med 2001;344(18):1343–50.
| Tuomilehto H, Peltonen M, Partinen M, et al. Sleep duration, lifestyle intervention, and incidence of type 2 diabetes in impaired glucose tolerance: The Finnish Diabetes Prevention Study. Diabetes Care 2009;32(11):1965–71.
| Uusitupa M, Peltonen M, Lindstrom J, et al. Ten-year mortality and cardiovascular morbidity in the Finnish Diabetes Prevention Study - Secondary analysis of the randomized trial. PLoS ONE 2009;4(5).
| Wikstrom K, Peltonen M, Eriksson JG, et al. Educational attainment and effectiveness of lifestyle intervention in the Finnish Diabetes Prevention Study. Diabetes Res Clin Pract 2009;86(1).
Knowler WC, Barrett-Connor E, Fowler SE, et al. Reduction in the incidence of type 2 diabetes with lifestyle intervention or metformin. N Engl J Med 2002;346(6):393–403. | Diabetes Prevention Program Research Group, Crandall J, Schade D, et al. The influence of age on the effects of lifestyle modification and metformin in prevention of diabetes. Journals of Gerontology Series A-Biological Sciences & Medical Sciences 2006;61(10):1075–81.
Knowler WC, Barrett-Connor E, Fowler SE, et al. Reduction in the incidence of type 2 diabetes with lifestyle intervention or metformin. N Engl J Med 2002;346(6):393–403. | Diabetes Prevention Program Research Group, Knowler WC, Fowler SE, et al. 10-year follow-up of diabetes incidence and weight loss in the Diabetes Prevention Program Outcomes Study. Lancet 2009;374(9702):1677–86.
Knowler WC, Barrett-Connor E, Fowler SE, et al. Reduction in the incidence of type 2 diabetes with lifestyle intervention or metformin. N Engl J Med 2002;346(6):393–403. | Fujimoto WY, Jablonski KA, Bray GA, et al. Body size and shape changes and the risk of diabetes in the diabetes prevention program. Diabetes 2007;56(6):1680–5.
Knowler WC, Barrett-Connor E, Fowler SE, et al. Reduction in the incidence of type 2 diabetes with lifestyle intervention or metformin. N Engl J Med 2002;346(6):393–403. | Goldberg RB, Temprosa M, Haffner S, et al. Effect of progression from impaired glucose tolerance to diabetes on cardiovascular risk factors and its amelioration by lifestyle and metformin intervention: the Diabetes Prevention Program randomized trial by the Diabetes Prevention Program Research Group. Diabetes Care 2009;32(4):726–32.
Knowler WC, Barrett-Connor E, Fowler SE, et al. Reduction in the incidence of type 2 diabetes with lifestyle intervention or metformin. N Engl J Med 2002;346(6):393–403. | Haffner S, Temprosa M, Crandall J, et al. Intensive lifestyle intervention or metformin on inflammation and coagulation in participants with impaired glucose tolerance. Diabetes 2005;54(5):1566–72.
Knowler WC, Barrett-Connor E, Fowler SE, et al. Reduction in the incidence of type 2 diabetes with lifestyle intervention or metformin. N Engl J Med 2002;346(6):393–403. | Orchard TJ, Temprosa M, Goldberg R, et al. The effect of metformin and intensive lifestyle intervention on the metabolic syndrome: the Diabetes Prevention Program randomized trial. Ann Intern Med 2005;142(8):611–9.
Knowler WC, Barrett-Connor E, Fowler SE, et al. Reduction in the incidence of type 2 diabetes with lifestyle intervention or metformin. N Engl J Med 2002;346(6):393–403. | Perreault L, Ma Y, gogo-Jack S, et al. Sex differences in diabetes risk and the effect of intensive lifestyle modification in the Diabetes Prevention Program. Diabetes Care 2008;31(7):1416–21.
Knowler WC, Barrett-Connor E, Fowler SE, et al. Reduction in the incidence of type 2 diabetes with lifestyle intervention or metformin. N Engl J Med 2002;346(6):393–403. | Ratner R, Goldberg R, Haffner S, et al. Impact of intensive lifestyle and metformin therapy on cardiovascular disease risk factors in the diabetes prevention program. Diabetes Care 2005;28(4):888–94.
Knowler WC, Barrett-Connor E, Fowler SE, et al. Reduction in the incidence of type 2 diabetes with lifestyle intervention or metformin. N Engl J Med 2002;346(6):393–403. | The Diabetes Prevention Program (DPP): Description of lifestyle intervention. Diabetes Care 2002;25(12):2165–71.
Mensink M, Feskens EJ, Saris WH, et al. Study on Lifestyle Intervention and Impaired Glucose Tolerance Maastricht (SLIM): preliminary results after one year. Int J Obes Relat Metab Disord 2003;27(3):377–84. | Corpeleijn E, Feskens EJ, Jansen EH, et al. Improvements in glucose tolerance and insulin sensitivity after lifestyle intervention are related to changes in serum fatty acid profile and desaturase activities: the SLIM study. Diabetologia 2006;49(10):2392–401.
| Corpeleijn E FEJEM. Lifestyle intervention and adipokine levels in subjects at high risk for type 2 diabetes: the Study on Lifestyle intervention and Impaired glucose tolerance Maastricht (SLIM). Diabetes Care 2007;(12):3125–7.
| Mensink M, Blaak EE, Corpeleijn E, et al. Lifestyle intervention according to general recommendations improves glucose tolerance. Obes Res 2003;11(12):1588–96.
| Mensink M, Blaak EE, Wagenmakers AJ, et al. Lifestyle intervention and fatty acid metabolism in glucose-intolerant subjects. Obes Res 2005;13(8):1354–62.
| Mensink M, Corpeleijn E, Feskens EJ, et al. Study on lifestyle-intervention and impaired glucose tolerance Maastricht (SLIM): design and screening results. Diabetes Res Clin Pract 2003;61(1):49–58
| Roumen C, Corpeleijn E, Feskens EJ, et al. Impact of 3-year lifestyle intervention on postprandial glucose metabolism: the SLIM study. Diabet Med 2008;25(5):597–605.
Oldroyd JC, Unwin NC, White M, et al. Randomised controlled trial evaluating the effectiveness of behavioural interventions to modify cardiovascular risk factors in men and women with impaired glucose tolerance: Outcomes at 6 months. Diabetes Res Clin Pract 2001;52(1):29–43. | Oldroyd JC, Unwin NC, White M, et al. Randomised controlled trial evaluating lifestyle interventions in people with impaired glucose tolerance. Diabetes Res Clin Pract 2006;72(2):117–27.
Pan XR, Li GW, Hu YH, et al. Effects of diet and exercise in preventing NIDDM in people with impaired glucose tolerance: The Da Qing IGT and diabetes study. Diabetes Care 1997;20(4):537–44. | Li G, Hu Y, Yang W, et al. Effects of insulin resistance and insulin secretion on the efficacy of interventions to retard development of type 2 diabetes mellitus: the DA Qing IGT and Diabetes Study. Diabetes Res Clin Pract 2002;58(3):193–200.
Pan XR, Li GW, Hu YH, et al. Effects of diet and exercise in preventing NIDDM in people with impaired glucose tolerance: The Da Qing IGT and diabetes study. Diabetes Care 1997;20(4):537–44. | Li G, Zhang P, Wang J, et al. The long-term effect of lifestyle interventions to prevent diabetes in the China Da Qing Diabetes Prevention Study: a 20-year follow-up study. Lancet 2008;371(9626):1783–9.

Breast and Prostate Cancer

Main publication | Companion studies
Demark-Wahnefried W, Clipp EC, Morey MC, et al. Lifestyle intervention development study to improve physical function in older adults with cancer: Outcomes from project LEAD. J Clin Oncol 2006;24(21):3465–73. | DeMark-Wahnefried W, Morey MC, Clipp EC, et al. Leading the way in exercise and diet (Project LEAD): Intervening to improve function among older breast and prostate cancer survivors. Control Clin Trials 2003;24(2):206–23.
Morey MC, Snyder DC, Sloane R, et al. Effects of home-based diet and exercise on functional outcomes among older, overweight long-term cancer survivors: RENEW: a randomized controlled trial. Journal of the American Medical Association 2009;301(18):1883–91. | Mosher CE, Sloane R, Morey MC, et al. Associations between lifestyle factors and quality of life among older long-term breast, prostate, and colorectal cancer survivors. Cancer 2009;115(17):4001–9.
| Snyder DC, Morey MC, Sloane R, et al. Reach out to ENhancE Wellness in Older Cancer Survivors (RENEW): design, methods and recruitment challenges of a home-based exercise and diet intervention to improve physical function among long-term survivors of breast, prostate, and colorectal cancer. PSYCHO ONCOL 2009;18(4):429–39.
Ornish D, Weidner G, Fair WR, et al. Intensive lifestyle changes may affect the progression of prostate cancer. J Urol 1069;174(3):1065–9. | Daubenmier JJ, Weidner G, Marlin R, et al. Lifestyle and health-related quality of life of men with prostate cancer managed with active surveillance. Urology 2006;67(1):125–30.
Ornish D, Weidner G, Fair WR, et al. Intensive lifestyle changes may affect the progression of prostate cancer. J Urol 1069;174(3):1065–9. | Frattaroli J, Weidner G, Dnistrian AM, et al. Clinical events in prostate cancer lifestyle trial: results from two years of follow-up. Urology 2008;72(6):1319–23.
Ornish D, Weidner G, Fair WR, et al. Intensive lifestyle changes may affect the progression of prostate cancer. J Urol 1069;174(3):1065–9. | Ornish DM LKFWPECP. Dietary trial in prostate cancer: Early experience and implications for clinical trial design. Urology 2001;4(Suppl 1):200–1.