# Sample Forms

B.1 Inclusion Criteria Worksheet: Lifestyle interventions review

B.2 Data Extraction Form: Lifestyle interventions: T2D & Metabolic Syndrome

B.3 Data Extraction Form: Lifestyle interventions review- Breast and Prostate Cancer