# Search Strategies

Table A1 Lifestyle interventions review – MEDLINE

Years/issue searched: 1980-current Search date: June 8, 2010 Number of Results: 354
1. exp Diabetes Mellitus, Type 2/; 2. exp Diabetes Complications/; 3. (obes$ adj6 diabet$).tw,kf,ot.; 4. (MODY or NIDDM or T2DM).tw,kf,ot.; 5. (non insulin$ depend$ or noninsulin$ depend$ or noninsulin?depend$ or non insulin?depend$).tw,kf,ot.; 6. ((typ? 2 or typ? II or typ?2 or typ?II) adj diabet$).tw,kf,ot.; 7. (diabet$ adj (typ? 2 or typ? II or typ?2 or typ?II)).tw,kf,ot.; 8. ((adult$ or matur$ or late or slow or stabl$) adj6 diabet$).tw,kf,ot.; 9. or/1–8; 10. exp Diabetes Insipidus/; 11. diabet$ insipidus.tw,kf,ot.; 12. 10 or 11; 13. 9 not 12; 14. Metabolic Syndrome X/; 15. (metabolic adj syndrome*).tw.; 16. Prediabetic State/; 17. (prediabetes or pre-diabetes).tw.; 18. Insulin Resistance/; 19. (insulin adj resistance).tw.; 20. or/14–19; 21. Prostatic Neoplasms/; 22. (prostat$ adj3 (cancer$ or carcinoma$ or malignan$ or tumo?r$ or neoplas$ or adeno$)).ti,ab.; 23. or/21–22; 24. exp Breast Neoplasms/; 25. (breast$ adj3 (cancer$ or carcinoma$ or malignan$ or tumo?r$ or neoplas$ or adeno$)).ti,ab.; 26. or/24–25; 27. exp Exercise/; 28. Physical Exertion/; 29. exp exercise movement techniques/; 30. exp exercise therapy/; 31. exp sports/; 32. Physical Fitness/; 33. “Physical Education and Training”/; 34. $exercise*.tw.; 35. (aerobic adj2 exercise*).tw.; 36. (Physical adj2 (fitness or training or exertion or activit*)).tw.; 37. ((Endurance adj2 (exercise* or training)) or endurance).tw.; 38. (Exercise adj2 (movement* or therap* or training or counsel*)).tw.; 39. $fitness*.tw.; 40. or/27–39; 41. exp Life Style/; 42. exp Stress, Psychological/pc [Prevention & Control]; 43. Mental Health/; 44. Cognitive Therapy/; 45. exp Relaxation Therapy/; 46. exp Psychotherapy/mt, tu, ut [Methods, Therapeutic Use, Utilization]; 47. exp Behavior Therapy/mt [Methods]; 48. social support/; 49. exp Self Concept/; 50. health education/; 51. exp health promotion/; 52. exp Health Behavior/; 53. Patient Education as Topic/mt, ut [Methods, Utilization]; 54. Health Knowledge, Attitudes, Practice/; 55. “Quality of Life”/px [Psychology]; 56. Counseling/mt, ut [Methods, Utilization]; 57. exp “Tobacco Use Cessation”/; 58. Smoking/pc [Prevention & Control]; 59. exp Mind-Body Therapies/; 60. (aromatherap* or biofeedback or hypnosis or imagery or meditation or psychodrama or psychophysiology or yoga).tw.; 61. (breathing adj exercises).tw.; 62. (laughter adj therapy).tw.; 63. (relaxation adj therapy).tw.; 64. (therapeutic adj touch).tw.; 65. (tai adj (ji or chi)).tw.; 66. or/41–65; 67. exp Diet/; 68. nutrition therapy/ or exp diet therapy/; 69. exp Feeding Behavior/; 70. Weight Loss/; 71. $diet*.tw.; 72. (weight adj2 (loss or reduction or change or program*)).tw.; 73. ((Weight or diet* or nutrition*) adj2 counsel*).tw.; 74. (counsel* adj3 (weight or diet* or nutrition)).tw.; 75. (Caloric adj2 (intake or restriction or reduction or deficit)).tw.; 76. (calorie* adj2 (intake or restriction or reduction or deficit)).tw.; 77. (Diet* adj2 (intervention or change or restriction or program*)).tw.; 78. (healthy adj2 eating).tw.; 79. ((fat or fiber or fibre) adj2 intake).tw.; 80. or/67–79; 81. randomized controlled trial.pt.; 82. controlled clinical trial.pt.; 83. randomi?ed.ab.; 84. placebo.ab.; 85. drug therapy.fs.; 86. randomly.ab.; 87. trial.ab.; 88. groups.ab.; 89. or/81–88; 90. humans/ not (animals and humans).hw,sh.; 91. 89 and 90; 92. and/13,40,66,80,91; 93. and/20,40,66,80,91; 94. and/23,40,66,80,91; 95. and/26,40,66,80,91; 96. or/92–95; 97. limit 96 to (english language and humans and yr=“1980 -Current”); 98. limit 97 to “all adult (19 plus years)”

Table A2 Lifestyle interventions review - CENTRAL

Years/issue searched: 1980-current Search date: March 23, 2010 Number of Results: 186
1. exp Diabetes Mellitus, Type 2/; 2. exp Diabetes Complications/; 3. (obes$ adj6 diabet$).tw,ot.; 4. (MODY or NIDDM or T2DM).tw,ot.; 5. (non insulin$ depend$ or noninsulin$ depend$ or noninsulin?depend$ or non insulin?depend$).tw,ot.; 6. ((typ? 2 or typ? II or typ?2 or typ?II) adj diabet$).tw,ot.; 7. (diabet$ adj (typ? 2 or typ? II or typ?2 or typ?II)).tw,ot.; 8. ((adult$ or matur$ or late or slow or stabl$) adj6 diabet$).tw,ot.; 9. or/1–8; 10. exp Diabetes Insipidus/; 11. diabet$ insipidus.tw,ot.; 12. 10 or 11; 13. 9 not 12; 14. Metabolic Syndrome X/; 15. Insulin Resistance/; 16. (metabolic adj syndrome*).tw.; 17. (insulin adj resistance).tw.; 18. or/14–17; 19. Prostatic Neoplasms/; 20. (prostat$ adj3 (cancer$ or carcinoma$ or malignan$ or tumo?r$ or neoplas$ or adeno$)).ti,ab.; 21. or/19–20; 22. exp Breast Neoplasms/; 23. (breast$ adj3 (cancer$ or carcinoma$ or malignan$ or tumo?r$ or neoplas$ or adeno$)).ti,ab.; 24. or/22–23; 25. exp Exercise/; 26. Physical Exertion/; 27. exp exercise movement techniques/; 28. exp exercise therapy/; 29. exp sports/; 30. Physical Fitness/; 31. “Physical Education and Training”/; 32. $exercise*.tw.; 33. (aerobic adj2 exercise*).tw.; 34. (Physical adj2 (fitness or training or exertion or activit*)).tw.; 35. ((Endurance adj2 (exercise* or training)) or endurance).tw.; 36. (Exercise adj2 (movement* or therap* or training or counsel*)).tw.; 37. $fitness*.tw.; 38. or/25–37; 39. exp Life Style/; 40. exp Stress, Psychological/pc [Prevention & Control]; 41. Mental Health/; 42. Cognitive Therapy/; 43. exp Relaxation Therapy/; 44. exp Psychotherapy/mt, tu, ut [Methods, Therapeutic Use, Utilization]; 45. exp Behavior Therapy/mt [Methods]; 46. social support/; 47. exp Self Concept/; 48. health education/; 49. exp health promotion/; 50. exp Health Behavior/; 51. Patient Education as Topic/mt, ut [Methods, Utilization]; 52. Health Knowledge, Attitudes, Practice/; 53. “Quality of Life”/px [Psychology]; 54. Counseling/mt, ut [Methods, Utilization]; 55. exp “Tobacco Use Cessation”/; 56. Smoking/pc [Prevention & Control]; 57. exp Mind-Body Therapies/; 58. (aromatherap* or biofeedback or hypnosis or imagery or meditation or psychodrama or psychophysiology or yoga).tw.; 59. (breathing adj exercises).tw.; 60. (laughter adj therapy).tw.; 61. (relaxation adj therapy).tw.; 62. (therapeutic adj touch).tw.; 63. (tai adj (ji or chi)).tw.; 64. or/39–63; 65. exp Diet/; 66. nutrition therapy/ or exp diet therapy/; 67. exp Feeding Behavior/; 68. Weight Loss/; 69. $diet*.tw.; 70. (weight adj2 (loss or reduction or change or program*)).tw.; 71. ((Weight or diet* or nutrition*) adj2 counsel*).tw.; 72. (counsel* adj3 (weight or diet* or nutrition)).tw.; 73. (Caloric adj2 (intake or restriction or reduction or deficit)).tw.; 74. (calorie* adj2 (intake or restriction or reduction or deficit)).tw.; 75. (Diet* adj2 (intervention or change or restriction or program*)).tw.; 76. (healthy adj2 eating).tw.; 77. or/65–76; 78. and/13,38,64,77; 79. and/18,38,64,77; 80. and/21,38,64,77; 81. and/24,38,64,77; 82. or/78–81; 83. limit 82 to yr=“1980 -Current”

Table A3 Lifestyle interventions review - CINAHL

Years/issue searched: 1980-current; English only; publication type: clinical trials Search date: March 23, 2010 Number of Results: 160

# | Query
S78 | S74 or S75 or S76 or S77
S77 | S19 AND S31 AND S60 AND S73
S76 | S16 AND S31 AND S60 AND S73
S75 | S13 AND S31 AND S60 AND S73
S74 | S8 AND S31 AND S60 AND S73
S73 | S61 or S62 or S63 or S64 or S65 or S66 or S67 or S68 or S69 or S70 or S71 or S72
S72 | TX healthy eating
S71 | TX calorie intake or TX calorie restriction or TX calorie reduction or TX calorie deficit
S70 | TX caloric intake or TX caloric restriction or TX caloric reduction or TX caloric deficit
S69 | TX diet counseling or TX diet counselling
S68 | TX Weight loss or TX weight reduction or TX weight change or TX weight loss program or TX ( weight counselling or weight counseling )
S67 | TX diet* or TX diet intervention or TX diet change or TX diet restriction or TX diet program*
S66 | (MH “Nutritional Counseling”)
S65 | (MH “Weight Reduction Programs”)
S64 | (MH “Weight Loss”)
S63 | (MH “Eating Behavior+”)
S62 | (MH “Diet Therapy+”)
S61 | (MH “Diet+”)
S60 | S32 or S33 or S34 or S35 or S36 or S37 or S38 or S39 or S40 or S41 or S42 or S43 or S44 or S45 or S46 or S47 or S48 or S49 or S50 or S51 or S52 or S53 or S54 or S55 or S56 or S57 or S58 or S59
S59 | TX qi gong
S58 | TX tai chi OR tai ji
S57 | TX therapeutic touch
S56 | TX relaxation therap*
S55 | TX laughter therap*
S54 | TX breathing exercise*
S53 | TX aromatherap* OR biofeedback OR hypnosis OR imagery OR meditation OR psychodrama OR psychophysiology OR yoga
S52 | (MH “Mind Body Techniques+”)
S51 | (MH “Smoking Cessation Programs”) or (MH “Smoking Cessation”)
S50 | (MH “Counseling+”)
S49 | (MH “Counseling”)
S48 | (MH “Quality of Life+”)
S47 | (MH “Health Knowledge”)
S46 | (MH “Patient Education+”)
S45 | (MH “Health Behavior+”)
S44 | (MH “Health Promotion+”)
S43 | (MH “Health Education+”)
S42 | (MH “Self Concept+”)
S41 | (MH “Support, Psychosocial+”)
S40 | (MH “Behavior Therapy+”)
S39 | (MH “Psychotherapy+”)
S38 | (MH “Alternative Therapies+”)
S37 | (MH “Cognitive Therapy”)
S36 | (MH “Community Mental Health Services”)
S35 | (MH “Stress Management”)
S34 | (MH “Stress, Psychological/PC”)
S33 | (MH “Health Behavior+”) or (MH “Health Behavior Component (Saba CCC)+”) or (MH “Health Seeking Behavior Alteration (Saba CCC)”) or (MH “Domain IV: Health-Related Behaviors Domain (Omaha)+”) or (MH “Health Seeking Behaviors (NANDA)+”) or (MH “Health Behavior (Iowa NOC) (Non-Cinahl)+”) or (MH “Health Knowledge and Behavior (Iowa NOC) (Non-Cinahl)+”) or (MH “Health Promoting Behavior (Iowa NOC)”)
S32 | (MH “Life Style+”) or (MH “Life Style Changes”)
S31 | S19 or S20 or S21 or S22 or S23 or S24 or S25 or S26 or S27 or S28 or S29 or S30
S30 | TX fitness OR physical fitness
S29 | TX endurance exercise* OR endurance training OR endurance
S28 | TX physical fitness OR physical training OR physical exertion OR physical activit*
S27 | (MH “Aerobic Exercises”) or TX aerobic exercise*
S26 | (MH “Physical Activity”)
S25 | (MH “Physical Education and Training+”)
S24 | (MH “Physical Fitness+”)
S23 | (MH “Sports+”)
S22 | (MH “Therapeutic Exercise+”)
S21 | (MH “Exertion”)
S20 | (MH “Exercise+”)
S19 | S17 or S18
S18 | TX Breast cancer or TX breast neoplasm* or TX ( breast tumor* OR breast tumour* )
S17 | (MH “Breast Neoplasms+”)
S16 | S14 or S15
S15 | TX prostat* cancer or TX prostat* neoplasm* or TX ( prostat* tumor* OR prostat* tumour* )
S14 | (MH “Prostatic Neoplasms”)
S13 | S9 or S10 or S11 or S12
S12 | TX insulin resistance
S11 | TX metabolic syndrome or TX metabolic syndrome x
S10 | (MH “Insulin Resistance+”)
S9 | (MH “Metabolic Syndrome X+”)
S8 | S1 or S2 or S3 or S4 or S5 or S6 or S7
S7 | TX diabetes insipidus
S6 | TX MODY OR NIDDM OR T2DM
S5 | TX non-insulin dependent diabetes
S4 | TX diabetes insipidus
S3 | TX diabetes type 2
S2 | (MH “Diabetes Insipidus”)
S1 | (MH “Diabetes Mellitus, Non-Insulin-Dependent”)

Table A4 Lifestyle interventions review - SCOPUS

Years/issue searched: 1980-current; English Search date: March 23, 2010 Number of Results: 320
1(((TITLE-ABS-KEY((breast PRE/0 cancer) OR (breast PRE/0 carcinoma) OR (breast W/2 tumour*) OR (breast W/2 tumor*) OR (breast W/2 neoplasm*))) AND ((TITLE-ABS-KEY((exercise) OR (exercise W/2 movement) OR (exercise W/2 therap*) OR (exercise W/2 training) OR (exercise W/2 counsel*) OR (aerobic W/2 exercise))) OR (TITLE-ABS-KEY((physical W/2 fitness) OR (physical W/2 training) OR (physical W/2 exertion) OR (physical W/2 activit*) OR (physical W/2 exercise*))) OR (TITLE-ABS-KEY((endurance W/2 exercise*) OR (endurance W/2 training) OR (endurance))) OR (TITLE-ABS-KEY((sport*) OR (fitness)))) AND ((TITLE-ABS-KEY((“lifestyle”) OR (“cognitive therapy”) OR (“stress management”) OR (relaxation PRE/0 therapy) OR (psychotherap*) OR (behavior PRE/0 therap*) OR (social PRE/0 support) OR (health PRE/0 education) OR (health PRE/0 promotion) OR (health PRE/0 behavior) OR (patient PRE/0 education) OR (“quality of life”) OR (counsel*) OR (tobacco PRE/0 cessation))) OR (TITLE-ABS-KEY((“mind-body therap*”) OR aromatherap* OR biofeedback OR (hypnosis) OR mediation OR psychodrama OR psychophysiology OR yoga OR qi-gong OR (tai chi) OR (tai ji))) OR (TITLE-ABS-KEY((breathing PRE/0 exercises) OR (laughter PRE/0 therap*) OR (relaxation PRE/0 therap*) OR (therapeutic PRE/0 touch)))) AND ((TITLE-ABS-KEY((diet) OR (diet PRE/0 therapy) OR (nutrition PRE/0 therapy))) OR (TITLE-ABS-KEY((weight W/2 counsel*) OR (weight W/2 loss) OR (weight W/2 reduction) OR (weight W/2 change) OR (weight W/2 program*))) OR (TITLE-ABS-KEY((diet W/2 counsel*) OR (nutrition W/2 counsel*))) OR (TITLE-ABS-KEY((caloric W/2 intake) OR (caloric W/2 restriction) OR (caloric W/2 reduction) OR (caloric W/2 deficit))) OR (TITLE-ABS-KEY((calorie W/2 intake) OR (calorie W/2 restriction) OR (calorie W/2 reduction) OR (calorie W/2 deficit))) OR (TITLE-ABS-KEY((diet W/2 intervention) OR (diet W/2 change) OR (diet W/2 restriction) OR (diet W/2 program*))) OR (TITLE-ABS-KEY((healthy PRE/0 eating))))) OR ((TITLE-ABS-KEY((prostat* PRE/0 cancer) OR (prostat* PRE/0 carcinoma) OR (prostat* W/2 tumour*) OR (prostat* W/2 tumor*) OR (prostat* W/2 neoplasm*))) AND ((TITLE-ABS-KEY((exercise) OR (exercise W/2 movement) OR (exercise W/2 therap*) OR (exercise W/2 training) OR (exercise W/2 counsel*) OR (aerobic W/2 exercise))) OR (TITLE-ABS-KEY((physical W/2 fitness) OR (physical W/2 training) OR (physical W/2 exertion) OR (physical W/2 activit*) OR (physical W/2 exercise*))) OR (TITLE-ABS-KEY((endurance W/2 exercise*) OR (endurance W/2 training) OR (endurance))) OR (TITLE-ABS-KEY((sport*) OR (fitness)))) AND ((TITLE-ABS-KEY((“lifestyle”) OR (“cognitive therapy”) OR (“stress management”) OR (relaxation PRE/0 therapy) OR (psychotherap*) OR (behavior PRE/0 therap*) OR (social PRE/0 support) OR (health PRE/0 education) OR (health PRE/0 promotion) OR (health PRE/0 behavior) OR (patient PRE/0 education) OR (“quality of life”) OR (counsel*) OR (tobacco PRE/0 cessation))) OR (TITLE-ABS-KEY((“mind-body therap*”) OR aromatherap* OR biofeedback OR (hypnosis) OR mediation OR psychodrama OR psychophysiology OR yoga OR qi-gong OR (tai chi) OR (tai ji))) OR (TITLE-ABS-KEY((breathing PRE/0 exercises) OR (laughter PRE/0 therap*) OR (relaxation PRE/0 therap*) OR (therapeutic PRE/0 touch)))) AND ((TITLE-ABS-KEY((diet) OR (diet PRE/0 therapy) OR (nutrition PRE/0 therapy))) OR (TITLE-ABS-KEY((weight W/2 counsel*) OR (weight W/2 loss) OR (weight W/2 reduction) OR (weight W/2 change) OR (weight W/2 program*))) OR (TITLE- ABS-KEY((diet W/2 counsel*) OR (nutrition W/2 counsel*))) OR (TITLE-ABS-KEY((caloric W/2 intake) OR (caloric W/2 restriction) OR (caloric W/2 reduction) OR (caloric W/2 deficit))) OR (TITLE-ABS-KEY((calorie W/2 intake) OR (calorie W/2 restriction) OR (calorie W/2 reduction) OR (calorie W/2 deficit))) OR (TITLE-ABS-KEY((diet W/2 intervention) OR (diet W/2 change) OR (diet W/2 restriction) OR (diet W/2 program*))) OR (TITLE-ABS-KEY((healthy PRE/0 eating))))) OR (((TITLE-ABS-KEY((“metabolic syndrome x”) OR (metabolic PRE/0 syndrome))) OR (TITLE-ABS-KEY((“insulin resistance”) OR (insulin PRE/0 resistance))) OR (TITLE-ABS-KEY(“pre-diabetes”))) AND ((TITLE-ABS-KEY((exercise) OR (exercise W/2 movement) OR (exercise W/2 therap*) OR (exercise W/2 training) OR (exercise W/2 counsel*) OR (aerobic W/2 exercise))) OR (TITLE-ABS-KEY((physical W/2 fitness) OR (physical W/2 training) OR (physical W/2 exertion) OR (physical W/2 activit*) OR (physical W/2 exercise*))) OR (TITLE-ABS-KEY((endurance W/2 exercise*) OR (endurance W/2 training) OR (endurance))) OR (TITLE-ABS-KEY((sport*) OR (fitness)))) AND ((TITLE-ABS-KEY((“lifestyle”) OR (“cognitive therapy”) OR (“stress management”) OR (relaxation PRE/0 therapy) OR (psychotherap*) OR (behavior PRE/0 therap*) OR (social PRE/0 support) OR (health PRE/0 education) OR (health PRE/0 promotion) OR (health PRE/0 behavior) OR (patient PRE/0 education) OR (“quality of life”) OR (counsel*) OR (tobacco PRE/0 cessation))) OR (TITLE-ABS-KEY((“mind-body therap*”) OR aromatherap* OR biofeedback OR (hypnosis) OR mediation OR psychodrama OR psychophysiology OR yoga OR qi-gong OR (tai chi) OR (tai ji))) OR (TITLE-ABS-KEY((breathing PRE/0 exercises) OR (laughter PRE/0 therap*) OR (relaxation PRE/0 therap*) OR (therapeutic PRE/0 touch)))) AND ((TITLE-ABS-KEY((diet) OR (diet PRE/0 therapy) OR (nutrition PRE/0 therapy))) OR (TITLE-ABS-KEY((weight W/2 counsel*) OR (weight W/2 loss) OR (weight W/2 reduction) OR (weight W/2 change) OR (weight W/2 program*))) OR (TITLE-ABS-KEY((diet W/2 counsel*) OR (nutrition W/2 counsel*))) OR (TITLE-ABS-KEY((caloric W/2 intake) OR (caloric W/2 restriction) OR (caloric W/2 reduction) OR (caloric W/2 deficit))) OR (TITLE-ABS-KEY((calorie W/2 intake) OR (calorie W/2 restriction) OR (calorie W/2 reduction) OR (calorie W/2 deficit))) OR (TITLE-ABS-KEY((diet W/2 intervention) OR (diet W/2 change) OR (diet W/2 restriction) OR (diet W/2 program*))) OR (TITLE-ABS-KEY((healthy PRE/0 eating))))) OR (((TITLE-ABS-KEY(“diabetes type 2” OR “diabetes type II”)) OR (TITLE-ABS-KEY(mody OR niddm OR t2dm)) OR (TITLE-ABS-KEY(non-insulin PRE/2 diabetes))) AND ((TITLE-ABS-KEY((exercise) OR (exercise W/2 movement) OR (exercise W/2 therap*) OR (exercise W/2 training) OR (exercise W/2 counsel*) OR (aerobic W/2 exercise))) OR (TITLE-ABS-KEY((physical W/2 fitness) OR (physical W/2 training) OR (physical W/2 exertion) OR (physical W/2 activit*) OR (physical W/2 exercise*))) OR (TITLE-ABS-KEY((endurance W/2 exercise*) OR (endurance W/2 training) OR (endurance))) OR (TITLE-ABS-KEY((sport*) OR (fitness)))) AND ((TITLE-ABS-KEY((“lifestyle”) OR (“cognitive therapy”) OR (“stress management”) OR (relaxation PRE/0 therapy) OR (psychotherap*) OR (behavior PRE/0 therap*) OR (social PRE/0 support) OR (health PRE/0 education) OR (health PRE/0 promotion) OR (health PRE/0 behavior) OR (patient PRE/0 education) OR (“quality of life”) OR (counsel*) OR (tobacco PRE/0 cessation))) OR (TITLE-ABS-KEY((“mind-body therap*”) OR aromatherap* OR biofeedback OR (hypnosis) OR mediation OR psychodrama OR psychophysiology OR yoga OR qi-gong OR (tai chi) OR (tai ji))) OR (TITLE-ABS-KEY((breathing PRE/0 exercises) OR (laughter PRE/0 therap*) OR (relaxation PRE/0 therap*) OR (therapeutic PRE/0 touch)))) AND ((TITLE-ABS-KEY((diet) OR (diet PRE/0 therapy) OR (nutrition PRE/0 therapy))) OR (TITLE-ABS-KEY((weight W/2 counsel*) OR (weight W/2 loss) OR (weight W/2 reduction) OR (weight W/2 change) OR (weight W/2 program*))) OR (TITLE-ABS-KEY((diet W/2 counsel*) OR (nutrition W/2 counsel*))) OR (TITLE-ABS-KEY((caloric W/2 intake) OR (caloric W/2 restriction) OR (caloric W/2 reduction) OR (caloric W/2 deficit))) OR (TITLE-ABS-KEY((calorie W/2 intake) OR (calorie W/2 restriction) OR (calorie W/2 reduction) OR (calorie W/2 deficit))) OR (TITLE-ABS-KEY((diet W/2 intervention) OR (diet W/2 change) OR (diet W/2 restriction) OR (diet W/2 program*))) OR (TITLE-ABS-KEY((healthy PRE/0 eating)))))) AND (INDEXTERMS((randomized controlled trial) OR (controlled clinical trial))) AND (DOCTYPE(ar)) AND (((PUBYEAR IS 1980 OR PUBYEAR AFT 1980) AND (LANGUAGE(english))))

Table A5 Lifestyle interventions review - PsycINFO

Years/issue searched: 1980-current; English Search date: March 23, 2010 Number of Results: 14
1. exp diabetes mellitus/; 2. (diabetes adj type adj “2”).mp. [mp=title, abstract, heading word, table of contents, key concepts]; 3. (MODY or NIDDM or T2DM).tw.; 4. (non-insulin adj depend*).tw.; 5. or/1–4; 6. exp Metabolic Syndrome/; 7. (metabolic adj syndrome adj x).tw.; 8. (metabolic adj syndrome).tw.; 9. (insulin adj resistance).tw.; 10. (impaired adj glucose adj tolerance).tw.; 11. or/6–10; 12. (prostate adj3 (cancer or carcinoma or neoplasm* or tumo?r)).tw.; 13. exp breast neoplasms/; 14. (breast$ adj3 (cancer$ or carcinoma$ or malignan$ or tumo?r$ or neoplas$ or adeno$)).ti,ab.; 15. or/13–14; 16. exp Exercise/; 17. exp Physical Activity/; 18. exp aerobic exercise/; 19. exp Sports/; 20. exp Physical Fitness/; 21. exp Physical Endurance/ or exp Endurance/; 22. (Physical adj2 (fitness or training or exertion or activit*)).tw.; 23. ((Endurance adj2 (exercise* or training)) or endurance).tw.; 24. (Exercise adj2 (movement* or therap* or training or counsel*)).tw.; 25. or/16–24; 26. exp Lifestyle Changes/ or exp Lifestyle/; 27. exp Psychological Stress/; 28. exp Stress Management/; 29. exp Cognitive Therapy/; 30. exp Relaxation Therapy/; 31. exp Psychotherapy/; 32. exp Behavior Therapy/; 33. exp Social Support/; 34. exp Self Concept/; 35. exp Health Education/; 36. exp Client Education/; 37. exp Health Promotion/; 38. exp “Quality of Life”/; 39. exp Counseling/; 40. exp Smoking Cessation/; 41. exp Relaxation Therapy/; 42. exp Aromatherapy/; 43. exp Biofeedback/; 44. exp Hypnosis/; 45. exp Meditation/; 46. exp Yoga/; 47. exp Relaxation/; 48. exp Tactual Stimulation/; 49. (tai chi or tai ji).tw.; 50. or/26–49; 51. exp Diets/; 52. exp Nutrition/; 53. exp Eating Behavior/; 54. exp Weight Loss/; 55. (weight adj2 (loss or reduction or change or program*)).tw.; 56. ((Weight or diet* or nutrition*) adj2 counsel*).tw.; 57. (counsel* adj3 (weight or diet* or nutrition)).tw.; 58. (Caloric adj2 (intake or restriction or reduction or deficit)).tw.; 59. (calorie* adj2 (intake or restriction or reduction or deficit)).tw.; 60. (Diet* adj2 (intervention or change or restriction or program*)).tw.; 61. (healthy adj2 eating).tw.; 62. or/51–61; 63. 4 and 25 and 50 and 62; 64. 11 and 25 and 50 and 62; 65. 12 and 25 and 50 and 62; 66. 15 and 25 and 50 and 62; 67. or/63–66; 68. (randomi?ed or random*).tw.; 69. 67 and 68; 70. limit 69 to (human and english language and yr=“1980 -Current”)

Table A6 Lifestyle interventions review - EMBASE

Years/issue searched: 1980-current; English; RCTs Search date: March 23, 2010 Number of Results: 453
1. exp Diabetes Mellitus, Type 2/; 2. exp Diabetes Complications/; 3. (obes$ adj6 diabet$).tw,kf,ot.; 4. (MODY or NIDDM or T2DM).tw,kf,ot.; 5. (non insulin$ depend$ or noninsulin$ depend$ or noninsulin?depend$ or non insulin?depend$).tw,kf,ot.; 6. ((typ? 2 or typ? II or typ?2 or typ?II) adj diabet$).tw,kf,ot.; 7. (diabet$ adj (typ? 2 or typ? II or typ?2 or typ?II)).tw,kf,ot.; 8. ((adult$ or matur$ or late or slow or stabl$) adj6 diabet$).tw,kf,ot.; 9. or/1–8; 10. exp Diabetes Insipidus/; 11. diabet$ insipidus.tw,kf,ot.; 12. 10 or 11; 13. 9 not 12; 14. Metabolic Syndrome X/; 15. (metabolic adj syndrome*).tw.; 16. impaired glucose tolerance/; 17. (prediabetes or pre-diabetes).tw.; 18. Insulin Resistance/; 19. (insulin adj resistance).tw.; 20. or/14–19; 21. Prostatic Neoplasms/; 22. (prostat$ adj3 (cancer$ or carcinoma$ or malignan$ or tumo?r$ or neoplas$ or adeno$)).ti,ab.; 23. or/21–22; 24. exp Breast Neoplasms/; 25. (breast$ adj3 (cancer$ or carcinoma$ or malignan$ or tumo?r$ or neoplas$ or adeno$)).ti,ab.; 26. or/24–25; 27. exp Exercise/; 28. Physical Exertion/; 29. exp exercise movement techniques/; 30. exp exercise therapy/; 31. exp sports/; 32. Physical Fitness/; 33. “Physical Education and Training”/; 34. $exercise*.tw.; 35. (aerobic adj2 exercise*).tw.; 36. (Physical adj2 (fitness or training or exertion or activit*)).tw.; 37. ((Endurance adj2 (exercise* or training)) or endurance).tw.; 38. (Exercise adj2 (movement* or therap* or training or counsel*)).tw.; 39. $fitness*.tw.; 40. or/27–39; 41. exp Life Style/; 42. Stress Management/; 43. Cognitive Therapy/; 44. exp Relaxation Therapy/; 45. Psychotherapy/; 46. Behavior Therapy/; 47. social support/; 48. exp Self Concept/; 49. health education/; 50. exp health promotion/; 51. exp Health Behavior/; 52. Patient Education/; 53. Health Knowledge, Attitudes, Practice/; 54. “Quality of Life”/; 55. Counseling/; 56. exp “Tobacco Use Cessation”/; 57. exp Mind-Body Therapies/; 58. (aromatherap* or biofeedback or hypnosis or imagery or meditation or psychodrama or psychophysiology or yoga).tw.; 59. (breathing adj exercises).tw.; 60. (laughter adj therapy).tw.; 61. (relaxation adj therapy).tw.; 62. (therapeutic adj touch).tw.; 63. (tai adj (ji or chi)).tw.; 64. or/41–63; 65. exp Diet/; 66. $diet*.tw.; 67. nutrition therapy/ or exp diet therapy/; 68. Weight Loss/; 69. (weight adj2 (loss or reduction or change or program*)).tw.; 70. ((Weight or diet* or nutrition*) adj2 counsel*).tw.; 71. (counsel* adj3 (weight or diet* or nutrition)).tw.; 72. (Caloric adj2 (intake or restriction or reduction or deficit)).tw.; 73. (calorie* adj2 (intake or restriction or reduction or deficit)).tw.; 74. (Diet* adj2 (intervention or change or restriction or program*)).tw.; 75. (healthy adj2 eating).tw.; 76. or/65–75; 77. randomi?ed.ti,ab.; 78. random*.ti,ab.; 79. trial*.ti,ab.; 80. or/77–79; 81. humans/ not (animals and humans).hw,sh.; 82. 80 and 81; 83. and/13,40,64,76,82; 84. and/20,40,64,76,82; 85. and/23,40,64,76,82; 86. and/26,40,64,76,82; 87. or/83–86; 88. limit 87 to (english language and humans and yr=“1980 -Current”); 89. limit 88 to adult <18 to 64 years>

Table A7 Results summary

Database | Dates Searched | Date search ran | Number of results
MEDLINE (OVID) | 1980 - current | 22Mar10 | 354
CENTRAL (OVID) | 1980 - current | 23Mar10 | 186
CINAHL (EBSCO) | 1980 - current | 23Mar10 | 160
SCOPUS (Elsevier) | 1980 - current | 23Mar10 | 320
PsycINFO (OVID) | 1980 - current | 23Mar10 | 14
EMBASE (OVID) | 1980 - current | 23Mar10 | 253
Total results (with duplicates) | | | 1287
Total results (duplicates removed) | | | 802