# Abbreviations and Acronyms

ACE: angiotensin-converting enzyme
ACSM: American College of Sports Medicine
AHA: American Heart Association
AHEAD: Action for Health in Diabetes
ALA: α-linolenic acid
ATP III: Adult Treatment Panel III
approx: approximately
BMI: body mass index
BP: blood pressure
CDC: Centers for Disease Control
CHD: coronary heart disease
CHO: carbohydrate
CI: confidence interval
CONSORT: Consolidated Standards of Reporting Trials
CV: coefficient of variation
CVD: cardiovascular disease
d: day(s)
DAWN: Diabetes Awareness and Wellness Network
DPP: Diabetes Prevention Program
EoI: end of intervention
EPC: Evidence-based practice center
F&V: fruits and vegetables
FDPS: Finnish Diabetes Prevention Study
GRADE: Grading of Recommendations Assessment, Development, and Evaluation
KQ: key question
HbA1c: glycosylated haemoglobin
HDL: high density lipoprotein
HR: heart rate
hr: hour(s)
lb: pound(s)
IFG: impaired fasting glucose
IGT: impaired glucose tolerance
LDL: low density lipoprotein
LEAD: Leading the Way in Exercise and Diet
max: maximum
MD: mean difference
meds: medications
min: minute(s)
mo: month(s)
MUFA: monounsaturated fatty acids
NC: not calculated
NCEP: National Cholesterol Education Program
NHLBI: National Heart, Lung, and Blood Institute
NIH: National Institutes of Health
NNT: number needed to treat
NR: not reported
OHA: oral hypoglycaemic agent
PA: physical activity
PCL: Prostate Cancer Lifestyle
pg: page
POWER: Pounds Off With Empowerment
PUFA: polyunsaturated fatty acids
PSA: prostate-specific antigen
RCT: randomized controlled trial
RENEW: Reach Out to Enhance Wellness
RoB: Risk of Bias
RR: risk ratio
SFA: saturated fatty acids
SLIM: Study on Lifestyle Intervention and Impaired Glucose Tolerance Maastricht
SMD: standardized mean difference
T1D: Type 1 Diabetes
T2D: Type 2 Diabetes
tx: treatment
US: United States of America
WHO: World Health Organization
wk: week(s)
wt: weight
x: times
yr: year