# Peer Reviewers

We wish to acknowledge individuals listed below for their review of this report. This report has been reviewed in draft form by individuals chosen for their expertise and diverse perspectives. The purpose of the review was to provide candid, objective, and critical comments for consideration by the EPC in preparation of the final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

- Reviewer Name: Andrea Ferreira-Gonzalez, Ph.D.
  Position: Professor of Pathology
  Affiliation: Virginia Commonwealth University
  City, State: Richmond, VA
- Reviewer Name: Cathy Fomous, Ph.D.
  Position: Senior Health Policy Analyst
  Affiliation: NIH Office of Biotechnology Activities
  City, State: Bethesda, MD
- Reviewer Name: Margaret Gulley, M.D.
  Position: Professor
  Affiliation: University of North Carolina at Chapel Hill
  City, State: Chapel Hill, NC