# Bibliography

1 Tabar P. The urge to converge. A network primed for data and high-quality voice over IP can accomplish plenty. Healthc Inform. Sep. 2005;22(9):35-66. 38. 40. [pmid: 16222902].
2 Teutsch SM, Bradley LA, Palomaki GE, Haddow JE, Piper M, Calonge N, Dotson WD, Douglas MP, Berg AO. Chair, on behalf of the EGAPP Working Group. The evaluation of genomic applications in practice and prevention (EGAPP) initiative: methods of the EGAPP Working Group. Genet Med. 2008. Dec. 31. Epub ahead of print. [pmid: 18813139].
3 Secretary's Advisory Committee on Genetics, Health, and Society (SACGHS). U.S. system of oversight of genetic testing: a response to the charge of the Secretary of Health and Human Services. Washington (DC). Department of Health & Human Services. Apr. 2008:276. Also available: http://www4.od.nih.gov/oba/SACGHS/reports/SACGHS_oversight_report.pdf.
4 Chen B, Gagnon M, Shahangian S, Anderson NL, Howerton DA, Boone JD. Centers for Disease Control and Prevention (CDC). Good laboratory practices for molecular genetic testing for heritable diseases and conditions. MMWR Recomm Rep. Jun. 12. 2009;58(RR-6):1-37. quiz CE-1-4. [pmid: 19521335].
5 Association for Molecular Pathology (AMP). About AMP. [internet]. Bethesda (MD). Association for Molecular Pathology (AMP). Aug. 7. [accessed 2007 Oct 23]. 2007:1. Available: http://www.amp.org/AboutAMP/aboutAMP.htm.
6 Association for Molecular Pathology (AMP). About AMP, mission and vision. [internet]. Bethesda (MD). Association for Molecular Pathology (AMP). [accessed 2007 Oct 23]. 1. Available: http://www.amp.org/AboutAMP/mission.htm.
7 Jennings L, Van Deerlin VM, Gulley ML. College of American Pathologists Molecular Pathology Resource Committee. Recommended principles and practices for validating clinical molecular pathology tests. Arch Pathol Lab Med. May. 2009;133(5):743-755. [pmid: 19415949].
8 American College of Medical Genetics (ACMG). Standards and guidelines for clinical genetics laboratories (2007 Edition). [internet]. Bethesda (MD). American College of Medical Genetics (ACMG). [accessed 2007 Oct 23]. 2007:79. Available: http://www.acmg.net.
9 New York State Department of Health. Clinical laboratory standards of practice. Albany (NY). New York State Department of Health. Dec. 2006:303. Also available: http://www.wadsworth.org/labcert/clep/Survey/files/NYSDOHClinicalLaboratoryPracticeStandards.pdf.
10 Brophy MA. The Clinical Laboratory Improvement Program: not your ordinary regulatory program. Mil Med. Jul. 2000;165(7 Suppl 2):48-51. [pmid: 10920640].
11 Hackett JL, Archer KJ, Gaigalas AK, Garrett CT, Joseph LJ, Koch WH, Kricka LJ, McGlennen RC, Van Deerlin V, Vasquez GB. Diagnostic nucleic acid microarrays; approved guideline [MM12-A]. Wayne (PA). Clinical and Laboratory Standards Institute (CLSI). May. 30. 2006;vol. 26(no. 20):124.
12 O'Leary TJ, Ben-Ezra J, Domer PH, Fletcher JA, Griffin CA, Kaul K, Presto KT, Segal GH, Wolman S. Nucleic acid amplification assays for molecular hematopathology; approved guideline [MM5-A]. Vol. 23(no. 17). Wayne (PA). National Committee for Clinical Laboratory Standards (NCCLS). Also available: http://www.nccls.org/source/orders/free/mm5-a.pdf.
13 Richards CS, Grody WW, Dequeker E, Wilson JA, Noll WW, Schoonmaker MM, Winn-Deen ES, Williams LO. Molecular diagnostic methods for genetic diseases; approved guideline. 2nd ed. Wayne (PA). Clinical and Laboratory Standards Institute. Jun. 23. 2006:76. (CLSI document MM1-A2; vol. 26, no. 27).
14 Enns RK, Dewald G, Barker PE, Rasmussen DJ, Watson M, Wood G, Wyatt PR. Fluorescence In Situ Hybridization (FISH) methods for medical genetics; approved guideline [MM7-A]. Vol. 24(no. 5). Wayne (PA). National Committee for Clinical Laboratory Standards (NCCLS). Also available: http://www.clsi.org/source/orders/free/mm7-a.pdf.
15 Verification and validation of multiplex nucleic acid assays; proposed guideline [MM17-P]. Wayne (PA). Clinical and Laboratory Standards Institute (CLSI formerly NCCLS). 2007;vol. 27(no. 21).
16 Wolk D, Mitchell S, Patel R. Principles of molecular microbiology testing methods. Infect Dis Clin North Am. Dec. 2001;15(4):1157-1204. [pmid: 11780271].
17 Evaluation of Genomic Applications in Practice and Prevention (EGAPP): implementation and evaluation of a model approach. [internet]. Atlanta (GA). National Office of Public Health Genomics (NOPHG). Dec. 17. [accessed 2007 Dec 19]. 2007:3. Available: http://www.egappreviews.org/about.htm.
18 Owens DK, Holodniy M, Garber AM, Scott J, Sonnad S, Moses L, Kinosian B, Schwartz JS. Polymerase chain reaction for the diagnosis of HIV infection in adults. A meta-analysis with recommendations for clinical practice and study design. Ann Intern Med. May. 1. 1996;124(9):803-815. [pmid: 8610949].
19 Hadziyannis E, Cornish N, Starkey C, Procop GW, Yen-Lieberman B. Amplicor enterovirus polymerase chain reaction in patients with aseptic meningitis: A sensitive test limited by amplification inhibitors. Arch Pathol Lab Med. 1999;123(10):882-884. [pmid: 10506438].
20 Forbes BA. Introducing a molecular test into the clinical microbiology laboratory: development, evaluation, and validation. Arch Pathol Lab Med. Sep. 2003;127(9):1106-1111. [pmid: 12946208].
21 Dimech W, Bowden DS, Brestovac B, Byron K, James G, Jardine D, Sloots T, Dax EM. Validation of assembled nucleic acid-based tests in diagnostic microbiology laboratories. Pathology. Feb. 2004;36(1):45-50. [pmid: 14757556].
22 Winn-Deen ES. Standards and controls for genetic testing. Cancer Biomark. 2005;1(4-5):217-120. [pmid: 17192044].
23 Chen B, O' Connell CD, Boone DJ, Amos JA, Beck JC, Chan MM, Farkas DH, Lebo RV, Richards CS, Roa BB, Silverman LM, Barton DE, Bejjani BA, Belloni DR, Bernacki SH, Caggana M, Charache P, Dequeker E, Ferreira-Gonzalez A, Friedman KJ, Greene CL, Grody WW, Highsmith WE Jr, Hinkel CS, Kalman LV, Lubin IM. Developing a sustainable process to provide quality control materials for genetic testing. Genet Med. Oct. 2005;7(8):534-549. [pmid: 16247292].
24 Wolff AC, Hammond MEH, Schwartz JN, Hagerty KL, Alfred DC, Cote RJ, Dowsett M, Fitzgibbons PL, Hanna WM, Langer A, McShane LM, Paik S, Pegram MD, Perez EA, Press MF, Rhodes A, Sturgeon C, Taube SE, Tubbs R, Vance GH, Van De Vijver M, Wheeler TM, Hayes DF. American Society of Clinical Oncology/College of American Pathologists guideline recommendations for human epidermal growth factor receptor 2 testing in breast cancer. Arch Pathol Lab Med. 2007;131(1):18-43. [pmid: 19548375].
25 Lamy PJ, Nanni I, Fina F, Bibeau F, Romain S, Dussert C, Penault Llorca F, Grenier J, Ouafik LH, Martin PM. Reliability and discriminant validity of HER2 gene quantification and chromosome 17 aneusomy analysis by real-time PCR in primary breast cancer. Int J Biol Markers. Jan-Mar. 2006;21(1):20-29. [pmid: 16711510].
26 Prence EM. A practical guide for the validation of genetic tests. Genet Test. 1999;3(2):201-205. [pmid: 10464668].
27 Nygaard V, Holden M, Loland A, Langaas M, Myklebost O, Hovig E. Limitations of mRNA amplification from small-size cell samples. BMC Genomics. 2005;6:147. [pmid: 16253144].
28 CLSI. Harmonized terminology database. [Web site]. Wayne (PA). Clinical and Laboratory Standards Institute (CLSI). 2008. [accessed 2008 Feb 6]. [various p]. Available: http://www.clsi.org/AM/Template.cfm?Section=Harmonized_Terminology_Database.
29 WHO international biological reference preparations; held and distributed by the WHO international laboratories for biological standards. Geneva (CH). World Health Organization (WHO). Jul. 20. 2007:17. Also available: http://www.who.int/bloodproducts/catalogue/alph_July07.pdf.
30 First international standard for common genetic test approved by WHO. [internet]. Geneva (CH). World Health Organization (WHO). Nov. 17. [accessed 2007 Dec 10]. 2004:2. Available: http://www.who.int/mediacentre/news/releases/2004/pr84/en/index.html.
31 Lasky FD, Harris Kroll M, Tholen TW. Evaluation of Matrix Effects; Approved Guideline—Second Edition. Clinical and Laboratory Standards Institute document EP14-A2 (ISBN 1-56238-561-5). Wayne (PA). Clinical and Laboratory Standards Institute. 2005;vol. 25(no. 4).
32 Aslanzadeh J. Preventing PCR amplification carry over contamination in a clinical laboratory. Ann Clin Lab Sci. Autumn. 2004;34(4):389-396. [pmid: 15648778].
33 Center for Biologic Evaluation and Research. Guidance for industry and FDA staff commercially distributed analyte specific reagents (ASRs): frequently asked questions. Rockville (MD). Food and Drug Administration. Sep. 14. 2007:13. Also available: http://www.fda.gov/cdrh/oivd/guidance/1590.pdf.
34 Patton S, Stenhouse S. Draft best practice guidelines for laboratory internal quality control. [Contract no. SMT4-CT98-7515]. Manchester (UK). European Molecular Genetics Quality Network (EMQN). 2002:4. Also available: http://www.emqn.org/emqn/BestPractice/mainColumnParagraphs/013/document/IQC_eu.pdf.
35 Health Protection Agency. Good laboratory practice when performing molecular amplification assays. [National Standard Method QSOP Issue 3]. London (UK). Health Protection Agency. Feb. 8. 2006:10. Also available: http://www.hpa-standardmethods.org.uk/documents/qsop/pdf/qsop38.pdf.
36 Gulley ML, Braziel RM, Halling KC, Hsi ED, Kant JA, Nikiforova MN, Nowak JA, Ogino S, Oliveira A, Polesky HF, Silverman L, Tubbs RR, Van Deerlin VM, Vance GH, Versalovic J. Molecular Pathology Resource Committee, College of American Pathologists. Clinical laboratory reports in molecular pathology. Arch Pathol Lab Med. Jun. 2007;131(6):852-863. [pmid: 17550311].
37 Matcher DB, Thakur ME, Grossman I, McCrory DC, Orlando LA, Steffens DC, Goldstein DB, Cline KE, Gray RN. Testing for cytochrome P450 polymorphisms in adults with non-psychotic depression treated with selective serotonin reuptake inhibitors (SSRIs). EvidenceReport/Technology Assessment No. 146. (Prepared by the Duke Evidence-based Practice Center. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). Nov. 1. 2006:157. Also available: http://www.ahrq.gov/downloads/pub/evidence/pdf/cyp450/cyp450.pdf.
38 Marchionni L, Wilson RF, Marinopoulos SS, Wolff AC, Parmigiani G, Bass EB, Goodman SN. Impact of gene expression profiling tests on breast cancer outcomes. (Prepared by The Johns Hopkins University Evidence based Practice Center under contract No. 290-02-0018). AHRQ Publication No. 08-E002. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). Jan. 2008:105. (Evidence report/technology assessment; no. 160). Also available: http://www.ahrq.gov/downloads/pub/evidence/pdf/brcancergene/brcangene.pdf.
39 Athena Diagnostics. LRRK2 DNA Test. [internet]. Worcester (MA). Athena Diagnostics, Inc. [accessed 2007 Dec 6]. 2007:2. Available: http://www.athenadiagnostics.com/content/test-catalog/find-test/service-detail/q/id/369.
40 Kay DM, Bird TD, Zabetian CP, Factor SA, Samii A, Higgins DS, Nutt J, Roberts JW, Griffith A, Leis BC, Montimurro JS, Philpott S, Payami H. Validity and utility of a LRRK2 G2019S mutation test for the diagnosis of Parkinson's disease. Genet Test. Sep. 2006;10(3):221-227. [pmid: 17020475].
41 Be sure your patients are sustained responders to Hepatitis C therapy. [internet]. Madison (NJ). Madison (NJ). [accessed 2007 Dec 6]. 2007:2. Available: http://www.questdiagnostics.com/hcp/topics/heptimax/heptimax.html?infectious.
42 Quest Diagnostics. Heptimax HCV RNA; Test summary. [internet]. Madison (NJ). Quest Diagnostics. Aug. [accessed 2007 Dec 6]. 2007:3. Available: http://www.questdiagnostics.com/hcp/intguide/jsp/showintguidepage.jsp?fn=TS_Heptimax.htm.
43 Lyman GH, Kuderer NM. Gene expression profile assays as predictors of recurrence-free survival in early-stage breast cancer: a metaanalysis. Clin Breast Cancer. Dec. 2006;7(5):372-379. [pmid: 17239261].
44 Oncotype DX studies. [internet]. Redwood City (CA). Genomic Health, Inc. Dec. 3. [accessed 2007 Nov 29]. 2007:9. Available: http://www.genomichealth.com/oncotype/studies/default.aspx.
45 Cronin M, Sangli C, Liu ML, Pho M, Dutta D, Nguyen A, Jeong J, Wu J, Langone KC, Watson D. Analytical validation of the Oncotype DX genomic diagnostic test for recurrence prognosis and therapeutic response prediction in node-negative, estrogen receptor-positive breast cancer. Clin Chem. Jun. 2007;53(6):1084-1091. [pmid: 17463177].
46 FDA News. FDA approves updated Warfarin (Coumadin) prescribing information. New genetic information may help providers improve initial dosing estimates of the anticoagulant for individual patients. [internet]. Seattle (WA). Genelex Corporation. Aug. 16. [accessed 2007 Dec 6]. 2007:2. Available: http://www.fda.gov/bbs/topics/NEWS/2007/NEW01684.html.
47 Warfarin (Coumadin) and DNA. Information for anticoagulation patients. [internet]. Seattle (WA). Genelex Corporation. [accessed 2007 Dec 6]. 2006:3. Available: http://www.healthanddna.com/warfarin.html.
48 PGxHealth: Warfarin. Control INR from the start. Newton (MA). Clinical Data Inc. 2007:8. Also available: http://www.pgxhealth.com/genetictests/pdf/54019_Warfarin_Sales_Aid_lr.pdf.
49 Warfarin DoseAdvise genetic test. Denver (CO). Kimball Genetics, Inc. 2007:2. (Pharmacogenetics Genetics Guiding Therapy). Also available: http://www.kimballgenetics.com/pdf/WarfarinEdusheetv7.pdf.
50 Nanosphere, Inc. Nanosphere: Verigene Warfarin metabolism nucleic acid test. [510(k) no. k070804]. Rockville (MD). U.S. Food and Drug Administration (FDA). Sep. 11. 2007:8. Also available: http://www.fda.gov/cdrh/pdf7/K070804.pdf.
51 Evaluation of automatic class III designation, Roche AmpliChip CYP450 test. [regulation no. 21 CFR 862.3360, docket no. k042259]. Rockville (MD). U. S. Food and Drug Administration. Dec. 23. 2004:5. Also available: http://www.fda.gov/OHRMS/DOCKETS/dockets/05n0067/05n-0067-bkg0001-vol1.pdf.
52 Shea BJ, Grimshaw JM, Wells GA, Boers M, Andersson N, Hamel C, Porter AC, Tugwell P, Moher D, Bouter LM. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
53 Deeks JJ. Egger M, Smith GD, Altman DG, editors. Systematic reviews of evaluations of diagnostic and screening tests. Systematic reviews in health care: meta-analysis in context. 2nd ed. London, England. BMJ Books. 2001:248-282.
54 Khan KS. Systematic reviews of diagnostic tests: a guide to methods and application. Best Pract Res Clin Obstet Gynaecol. Feb. 2005;19(1):37-46. [pmid: 15749064].
55 Dujardin B, Van den Ende J, Van Gompel A, Unger JP, Van der Stuyft P. Likelihood ratios: a real improvement for clinical decision making. Eur J Epidemiol. Feb. 1994;10(1):29-36. [pmid: 7957786].
56 Pai M, Flores LL, Hubbard A, Riley LW, Colford JM Jr. Nucleic acid amplification tests in the diagnosis of tuberculous pleuritis: a systematic review and meta-analysis. BMC Infect Dis. Feb. 23. 2004;4(1):6. [pmid: 15102325].
57 Pai M, Flores LL, Pai N, Hubbard A, Riley LW, Colford JM Jr. Diagnostic accuracy of nucleic acid amplification tests for tuberculous meningitis: a systematic review and meta-analysis. Lancet Infect Dis. Oct. 2003;3(10):633-643. [pmid: 14522262].
58 Marr KA, Leisenring W. Design issues in studies evaluating diagnostic tests for aspergillosis. Clin Infect Dis. Sep. 15. Suppl 6. 2005;41:S381-S386. [pmid: 16108003].
59 Zimmern RL, Kroese M. The evaluation of genetic tests. J Public Health (Oxf). May. 24. 2007;29(3):246-250. [pmid: 17526507].
60 Kroese M, Zimmern RL, Sanderson S. Genetic tests and their evaluation: can we answer the key questions. Genet Med. Nov-Dec. 2004;6(6):475-480. [pmid: 15545742].
61 Fryback DG, Thornbury JR. The efficacy of diagnostic imaging. Med Decis Making. Apr-Jun. 1991;11(2):88-94. [pmid: 1907710].
62 Grosse SD, Khoury MJ. What is the clinical utility of genetic testing. Genet Med. Jul. 2006;8(7):448-450. [pmid: 16845278].
63 ACCE: A CDC-sponsored project carried out by the foundation of blood research. [internet]. Atlanta (GA). Centers for Disease Control and Prevention. 2007. Jan. 11. [accessed 2007 May 3]. Available: http://www.cdc.gov/genomics/gtesting/ACCE.htm.
64 Greco S, Girardi E, Navarra A, Saltini C. Current evidence on diagnostic accuracy of commercially based nucleic acid amplification tests for the diagnosis of pulmonary tuberculosis. Thorax. Sep. 2006;61(9):783-790. [pmid: 16738037].
65 Morgan M, Kalantri S, Flores L, Pai M. A commercial line probe assay for the rapid detection of rifampicin resistance in Mycobacterium tuberculosis: a systematic review and meta-analysis. BMC Infect Dis. Jul. 28. 2005;5:62. [pmid: 16050959].
66 Flores LL, Pai M, Colford JM Jr, Riley LW. In-house nucleic acid amplification tests for the detection of Mycobacterium tuberculosis in sputum specimens: meta-analysis and meta-regression. BMC Microbiology. 2005;5:55. [pmid: 16202138].
67 Sarmiento OL, Weigle KA, Alexander J, Weber DJ, Miller WC. Assessment by meta-analysis of PCR for diagnosis of smear-negative pulmonary tuberculosis. J Clin Microbiol. Jul. 2003;41(7):3233-3240. [pmid: 12843069].
68 Dumler JS. Molecular diagnosis of Lyme disease: review and meta-analysis. Mol Diagn. Mar. 2001;6(1):1-11. [pmid: 11257206].
69 Dinnes J, Deeks J, Kunst H, Gibson A, Cummins E, Waugh N, Drobniewski F, Lalvani A. A systematic review of rapid diagnostic tests for the detection of tuberculosis infection. Health Technol Assess. Jan. 2007;11(3):1-196. [pmid: 17266837].
70 Centers for Disease Control and Prevention (CDC). Updated guidelines for the use of nucleic acid amplification tests in the diagnosis of tuberculosis. MMWR Morb Mortal Wkly Rep. Jan. 16. 2009;58(1):7-10. [pmid: 19145221].
71 Mocellin S, Hoon DS, Pilati P, Rossi CR, Nitti D. Sentinel lymph node molecular ultrastaging in patients with melanoma: a systematic review and meta-analysis of prognosis. J Clin Oncol. Apr. 20. 2007;25(12):1588-1595. [pmid: 17443001].
72 Dendukuri N, Khetani K, McIsaac M, Brophy J. Testing for HER2-positive breast cancer: A systematic review and cost-effectiveness analysis. CMAJ. May. 8. 2007;176(10):1429-1434. [pmid: 17485695].
73 Pakos EE, Kyzas PA, Ioannidis JP. Prognostic significance of TP53 tumor suppressor gene expression and mutations in human osteosarcoma: a meta-analysis. Clin Cancer Res. Sep. 15. 2004;10(18 Pt 1):6208-6214. [pmid: 15448009].
74 Zielinski GD, Bais AG, Helmerhorst TJ, Verheijen RH, de Schipper FA, Snijders PJ, Voorhorst FJ, van Kemenade FJ, Rozendaal L, Meijer CJ. HPV testing and monitoring of women after treatment of CIN 3: review of the literature and meta-analysis. Obstet Gynecol Surv. Jul. 2004;59(7):543-553. [pmid: 15199273].
75 Paraskevaidis E, Arbyn M, Sotiriadis A, Diakomanolis E, Martin-Hirsch P, Koliopoulos G, Makrydimas G, Tofoski J, Roukos DH. The role of HPV DNA testing in the follow-up period after treatment for CIN: a systematic review of the literature. Cancer Treat Rev. 2004;30(2):205-211. [pmid: 15023438].
76 Medical Services Advisory Committee (MSAC). Polymerase chain reaction in the diagnosis and monitoring of patients with BCR-ABL gene rearrangement in acute lymphoblastic leukaemia. Canberra (AU). Medical Services Advisory Committee (MSAC). Mar. 2004:120.
77 Medical Services Advisory Committee (MSAC). Polymerase chain reaction in the diagnosis and monitoring of patients with BCR-ABL gene rearrangement in chronic myeloid leukaemia. Canberra (AU). Medical Services Advisory Committee (MSAC). Mar. 2003:153.
78 Tsao H, Nadiminti U, Sober AJ, Bigby M. A meta-analysis of reverse transcriptase-polymerase chain reaction for tyrosinase mRNA as a marker for circulating tumor cells in cutaneous melanoma. Arch Dermatol. Mar. 2001;137(3):325-330. [pmid: 11255333].
79 HER2 testing to manage patients with breast cancer or other solid tumors. Rockville (MD). Agency for Healthcare Research and Quality (AHRQ). Various p. (Evidence report/technology assessment).
80 Gene expression profiling of breast cancer to select women for adjuvant chemotherapy. Technol Eval Cent Asses Program. Apr. 2008;22(13):1-52. Also available: http://www.bcbs.com/blueresources/tec/vols/22/22_13.pdf.
81 CYP2D6 pharmacogenomics of tamoxifen treatment. Technol Eval Cent Asses Program. May. 2008;23(1):1-32. [pmid: 18663817].
82 Pharmacogenomics-based treatment of helicobacter pylori infection. Technol Eval Cent Asses Program. May. 2008;23(2):1-22. [pmid: 18663818].
83 Sanderson S, Emery J, Higgins J. CYP2C9 gene variants, drug dose, and bleeding risk in warfarin-treated patients: a HuGEnet systematic review and meta-analysis. Genet Med. Feb. 2005;7(2):97-104. [pmid: 15714076].
84 Current CLIA regulations (including all changes through 1/24/2004). [internet]. Atlanta (GA). Centers for Disease Control and Prevention (CDC). [accessed 2008 Jan 28]. 6. [updated 2004 Jul 7]. Available: http://wwwn.cdc.gov/clia/regs/toc.aspx.
85 Survey procedures and interpretive guidelines for laboratories and laboratory services. [internet]. Baltimore (MD). Centers for Medicare & Medicaid Services (CMS). 2005. Apr. 4. [accessed 2008 Jan 28]. [various]. Available: http://www.cms.hhs.gov/CLIA/03_Interpretive_Guidelines_for_Laboratories.asp.
86 Clinical Laboratory Improvement Amendments (CLIA): how to obtain a CLIA certificate. Baltimore (MD). Centers for Medicare and Medicaid Services (CMS). Mar. 2006:10. Also available: http://www.cms.hhs.gov/CLIA/downloads/HowObtainCLIACertificate.pdf.
87 Appendix C: Survey procedures and interpretive guidelines for laboratories and laboratory services. Baltimore (MD). Centers for Medicare & Medicaid Services (CMS). 18. Also available: http://www.cms.hhs.gov/CLIA/downloads/apcpolicy.pdf.
88 Clinical laboratory improvement amendments (CLIA). Equivalent Quality Control Procedures, brochure #4. Centers for Disease Control and Prevention (CDC) and Centers for Medicare & Medicaid Services (CMS). 8. Also available: http://www.cms.hhs.gov/CLIA/downloads/6066bk.pdf.
89 Javitt GH, Hudson K. Public health at risk: failures in oversight of genetic testing laboratories. Washington (DC). Genetics and Public Policy Center. Sep. 2006:23. Also available: http://www.dnapolicy.org/resources/PublicHealthatRiskFinalwithCover.pdf.
90 College of American Pathologists. Personal communication. Sep. 8. 2009:1.
91 Commission on Laboratory Accreditation, Laboratory Accreditation Program: sample checklist. Northfield (IL). College of American Pathologists (CAP). Sep. 27. 2007:12. Also available: http://www.cap.org/apps/docs/laboratory_accreditation/sample_checklist.pdf.
92 Willey AM. (Wadsworth Center, NYS DOH). Personal communication. Sep. 4. 2009:1.
93 Center for Biologics Evaluation and Research, Office of In Vitro Diagnostic Device Evaluation and Safety, Center for Devices and Radiological Health. In vitro diagnostic multivariate index assays. Draft guidance for industry, clinical laboratories, and FDA staff [Docket # 2006D-0347]. Rockville (MD). Center for Biologics Evaluation and Research. Jul. 26. 2007:15.
94 Guidance for industry: In the manufacture and clinical evaluation of In Vitro tests to detect nucleic acid sequences of human immunodeficiency viruses types 1 and 2. Rockville (MD). U.S Department of Health and Human Services, Food and Drug Administration, Center for Biologics Evaluation and Research. Dec. 1. 1999:24. Also available: http://www.fda.gov/cber/gdlns/hivnas.pdf.
95 Office of In Vitro Diagnostic Device Evaluation and Safety. Guidance for industry and FDA staff: replacement reagent and instrument family policy. Rockville (MD). Food and Drug Administration, Center for Devices and Radiological Health. Dec. 11. 2003:13. Also available: http://www.fda.gov/downloads/MedicalDevices/DeviceRegulationandGuidance/GuidanceDocuments/ucm071465.pdf.
96 Guidance for Industry and FDA staff: Class II Special Controls Guidance Document: factor V Leiden DNA mutation detection systems. Rockville (MD). U.S. Department of Health and Human Services, Food and Drug Administration, Center for Devices and Radiological Health. Mar. 16. 2004:14. Also available: http://www.fda.gov/cdrh/oivd/guidance/1236.pdf.
97 Guidance for industry and FDA staff. Class II special controls guidance document: drug metabolizing enzyme genotyping system. [Docket No. 2005D-0068]. Rockville (MD). U.S. Department of Health and Human Services, Food and Drug Administration, Center for Devices and Radiological Health. Mar. 10. 2005:17. Also available: http://www.fda.gov/cdrh/oivd/guidance/1551.pdf.
98 Office of In Vitro Diagnostic Device Evaluation and Safety. Guidance for industry and FDA staff: Class II special controls guidance document: instrumentation for clinical multiplex test systems. Rockville (MD). Food and Drug Administration, Center for Devices and Radiological Health. Mar. 10. 2005:13. Also available: http://www.fda.gov/downloads/MedicalDevices/DeviceRegulationandGuidance/GuidanceDocuments/ucm071061.pdf.
99 Guidance for industry and FDA staff: Class II Special Controls Guidance Document: Automated Fluorescence in situ Hybridization (FISH) Enumeration Systems. Rockville (MD). U.S. Department of Health and Human Services, Food and Drug Administration, Center for Devices and Radiological Health. Mar. 23. 2005:13. Also available: http://www.fda.gov/cdrh/oivd/guidance/1550.pdf.
100 Guidance for industry and FDA staff: Class II Special Controls Guidance Document: RNA Preanalytical Systems (RNA Collection, Stabilization and Purification Systems for RT-PCR used in Molecular Diagnostic Testing). Rockville (MD). U.S. Department of Health and Human Services, Food and Drug Administration, Center for Devices and Radiological Health. Aug. 25. 2005:13. Also available: http://www.fda.gov/cdrh/oivd/guidance/1563.pdf.
101 Guidance for industry and FDA staff: Class II Special Controls Guidance Document: CFTR Gene Mutation Detection Systems. Rockville (MD). U.S. Department of Health and Human Services, Food and Drug Administration, Center for Devices and Radiological Health. Oct. 26. 2005:19. Also available: http://www.fda.gov/cdrh/oivd/guidance/1564.pdf.
102 Draft guidance for industry and FDA staff: Nucleic Acid Based In Vitro Diagnostic Devices for Detection of Microbial Pathogens (Draft). Rockville (MD). U.S. Department of Health and Human Services, Food and Drug Administration, Center for Devices and Radiological Health. Dec. 8. 2005:26. Also available: http://www.fda.gov/cdrh/oivd/guidance/1560.pdf.
103 Guidance for industry and FDA staff: Class II Special Controls Guidance Document: Quality Control Material for Cystic Fibrosis Nucleic Acid Assays. Rockville (MD). U.S. Department of Health and Human Services, Food and Drug Administration, Center for Devices and Radiological Health. Jan. 10. 2007:13. Also available: http://www.fda.gov/cdrh/oivd/guidance/1614.pdf.
104 Guidance for industry and FDA staff. Class II special controls guidance document: gene expression profiling test system for breast cancer prognosis. Rockville (MD). U.S. Food and Drug Administration (FDA), Center for Devices and Radiological Health. May. 9. 2007:19. Also available: http://www.fda.gov/cdrh/oivd/guidance/1627.pdf.
105 U.S. Food and Drug Administration (FDA), Center for Devices and Radiological Health (CDRH). Guidance for industry and FDA staff. Pharmacogenetic tests and genetic tests for heritable markers. Rockville (MD). U.S. Food and Drug Administration (FDA), Center for Devices and Radiological Health (CDRH). Jun. 19. 2007:18. Also available: http://www.fda.gov/cdrh/oivd/guidance/1549.pdf.
106 Office of In Vitro Diagnostic Device Evaluation and Safety. Guidance for industry and FDA staff: Class II special controls guidance document: Guidance for industry and FDA staff: class II special controls guidance document: nucleic acid amplification assay for the detection of enterovirus RNA. Rockville (MD). Food and Drug Administration, Center for Devices and Radiological Health. Jan. 2. 2009:24. Also available: http://www.fda.gov/downloads/MedicalDevices/DeviceRegulationandGuidance/GuidanceDocuments/ucm092761.pdf.
107 Introduction to medical device labeling. [internet]. Rockville (MD). U.S. Food and Drug Administration (FDA), Center for Devices and Radiological Health (CDRH). Apr. 24. [accessed 2009 Jan 7]. 2003:3. Available: http://www.fda.gov/CDRH/DEVADVICE/33.html#link_2.
108 Federal Trade Commission, memorandum of understanding between Federal Trade Commission and the Food and Drug Administration. Fed Regist. 1971;36(180):18539.
109 Promotion of Food and Drug Administration-regulated medical products using the internet and social media tools; notice of public hearing. Fed Regist. Sep. 21. 2009;74(181):48083-48088.
110 Federal Trade Commission (FTC). Frequently asked advertising questions: a guide for small business. Washington (DC). Federal Trade Commission (FTC). Apr. 2001:36. Also available: http://www.ftc.gov/bcp/conline/pubs/buspubs/ad-faqs.pdf.
111 Bartlett JM, Ibrahim M, Jasani B, Morgan JM, Ellis I, Kay E, Magee H, Barnett S, Miller K. External quality assurance of HER2 fluorescence in situ hybridisation testing: results of a UK NEQAS pilot scheme. J Clin Pathol. Jul. 2007;60(7):816-819. [pmid: 16963466].
112 Persons DL, Tubbs RR, Cooley LD, Dewald GW, Dowling PK, Du E, Mascarello JT, Rao KW, Wilson KS, Wolff DJ, Habegger-Vance G. HER-2 fluorescence in situ hybridization: results from the survey program of the College of American Pathologists. Arch Pathol Lab Med. Mar. 2006;130(3):325-331. [pmid: 16519559].
113 Clinical laboratory assays for HER-2/neu amplification and overexpression: quality assurance, standardization, and proficiency testing. Arch Pathol Lab Med. Jul. 2002;126(7):803-808. [pmid: 12088449].
114 Mascarello JT, Brothman AR, Davison K, Dewald GW, Herrman M, McCandless D, Park JP, Persons DL, Rao KW, Schneider NR, Vance GH, Cooley LD. Cytogenetics Resource Committee of the College of American Pathologists. Proficiency testing for laboratories performing fluorescence in situ hybridization with chromosome-specific DNA probes. Arch Pathol Lab Med. Dec. 2002;126(12):1458-1462. [pmid: 12456204].
115 Orlando C, Verderio P, Maatman R, Danneberg J, Ramsden S, Neumaier M, Taruscio D, Falbo V, Jansen R, Casini-Raggi C, Malentacchi F, Marubini E, Pizzamiglio S, Vernelen K, Libeer JC, Palicka V, Pazzagli M. EQUAL-qual: A European program for external quality assessment of genomic DNA extraction and PCR amplification. Clin Chem. 2007;53(7):1349-1357. [pmid: 17582151].
116 Ramsden SC, Daly S, Geilenkeuser WJ, Duncan G, Hermitte F, Marubini E, Neumaier M, Orlando C, Palicka V, Paradiso A, Pazzagli M, Pizzamiglio S, Verderio P. EQUAL-quant: an international external quality assessment scheme for real-time PCR. Clin Chem. Aug. 2006;52(8):1584-1591. [pmid: 16740649].
117 Raggi CC, Verderio P, Pazzagli M, Marubini E, Simi L, Pinzani P, Paradiso A, Orlando C. An Italian program of external quality control for quantitative assays based on real-time PCR with Taq-Man probes. Clin Chem Lab Med. 2005;43(5):542-548. [pmid: 15899677].
118 Birch L, English CA, Burns M, Keer JT. Generic scheme for independent performance assessment in the molecular biology laboratory. Clin Chem. Sep. 2004;50(9):1553-1559. [pmid: 15231684].
119 Raggi CC, Pinzani P, Paradiso A, Pazzagli M, Orlando C. External quality assurance program for PCR amplification of genomic DNA: an Italian experience. Clin Chem. May. 2003;49(5):782-791. [pmid: 12709370].
120 Braun A, Deufel T, Geilenkeuser WJ, Neumaier M, Rohle G, Roscher A, Wagener C. External quality assessment of molecular biology-based methods used in laboratories of clinical chemistry and human genetics. Clin Chem Lab Med. Apr. 1998;36(4):231-234. [pmid: 9638348].
121 Chalker VJ, Rossouw A, Mee Z, Patel P, Vaughan H, James VL. External quality assessment for the molecular detection of Hepatitis C virus. J Clin Virol. Jun. 2007;39(2):141-144. [pmid: 17500030].
122 Niedrig M, Meyer H, Panning M, Drosten C. Follow-up on diagnostic proficiency of laboratories equipped to perform orthopoxvirus detection and quantification by PCR: the second international external quality assurance study. J Clin Microbiol. Apr. 2006;44(4):1283-1287. [pmid: 16597852].
123 Templeton KE, Forde CB, Loon AM, Claas EC, Niesters HG, Wallace P, Carman WF. A multi-centre pilot proficiency programme to assess the quality of molecular detection of respiratory viruses. J Clin Virol. Jan. 2006;35(1):51-58. [pmid: 16019258].
124 Drosten C, Doerr HW, Lim W, Stohr K, Niedrig M. SARS molecular detection external quality assurance. Emerg Infect Dis. Dec. 2004;10(12):2200-2203. [pmid: 15663861].
125 Mancini C, Pisani G, Azzi A, Luisa Zerbini M, Gentili G, Mario Bisso G. MS participants. Inter-laboratory comparison of qualitative and quantitative detection of hepatitis C (HCV) virus RNA in diagnostic virology: a multicentre study (MS) in Italy. J Clin Virol. Aug. 2004;30(4):313-319. [pmid: 15163420].
126 Schloss L, van Loon AM, Cinque P, Cleator G, Echevarria JM, Falk KI, Klapper P, Schirm J, Vestergaard BF, Niesters H, Popow-Kraupp T, Quint W, Linde A. An international external quality assessment of nucleic acid amplification of herpes simplex virus. J Clin Virol. Oct. 2003;28(2):175-185. [pmid: 12957188].
127 Schirm J, van Loon AM, Valentine-Thon E, Klapper PE, Reid J, Cleator GM. External quality assessment program for qualitative and quantitative detection of hepatitis C virus RNA in diagnostic virology. J Clin Microbiol. Aug. 2002;40(8):2973-2980. [pmid: 12149361].
128 Valentine-Thon E, van Loon AM, Schirm J, Reid J, Klapper PE, Cleator GM. European proficiency testing program for molecular detection and quantitation of hepatitis B virus DNA. J Clin Microbiol. Dec. 2001;39(12):4407-4412. [pmid: 11724853].
129 Van Vliet KE, Muir P, Echevarria JM, Klapper PE, Cleator GM, Van Loon AM. Multicenter proficiency testing of nucleic acid amplification methods for the detection of enteroviruses. J Clin Microbiol. Sep. 2001;39(9):3390-3392. [pmid: 11526187].
130 van Loon AM, Cleator GC, Ras A. External quality assessment of enterovirus detection and typing. European Union Concerted Action on Virus Meningitis and Encephalitis. Bull World Health Organ. 1999;77(3):217-223. [pmid: 10212511].
131 Read S, Wareing S, Parmar S, Gray J, Desselberger U. The development of a specimen exchange system for quality assessment of polymerase chain reaction tests. Commun Dis Public Health. Mar. 1998;1(1):56-58. [pmid: 9718843].
132 Deplano A, De Mendonca R, De Ryck R, Struelens MJ. External quality assessment of molecular typing of Staphylococcus aureus isolates by a network of laboratories. J Clin Microbiol. Sep. 2006;44(9):3236-3244. [pmid: 16954254].
133 Muyldermans G, Soetens O, Antoine M, Bruisten S, Vincart B, Doucet-Populaire F, Fry NK, Olcen P, Scheftel JM, Senterre JM, van der Zee A, Riffelmann M, Pierard D, Lauwers S. External quality assessment for molecular detection of Bordetella pertussis in European laboratories. J Clin Microbiol. Jan. 2005;43(1):30-35. [pmid: 15634947].
134 Anonymous. Evolution of an external quality assessment program in Canadian Mycobacteriology Laboratories: three years of proficiency testing data. Am J Clin Pathol. Apr. 2004;121(4):566-573. [pmid: 15080309].
135 Wang LN, Zhang R, Shen ZY, Chen WX, Li JM. External quality assessment on detection of hepatitis C virus RNA in clinical laboratories of China. Chin Med J (Engl). Jun. 5. 2008;121(11):1032-1036. [pmid: 18706255].
136 Stelzer-Braid S, Escott R, Baleriola C, Kirkland P, Robertson P, Catton M, Rawlinson WD. Proficiency of nucleic acid tests for avian influenza viruses, Australasia. Emerg Infect Dis. Jul. 2008;14(7):1126-1128. [pmid: 18598638].
137 Hsi ED, Tubbs RR, Lovell MA, Braziel RM, Gulley ML. Detection of bcl-2/JH translocation by polymerase chain reaction: a summary of the experience of the molecular oncology survey of the College of American Pathologists. Arch Pathol Lab Med. Aug. 2002;126(8):902-914. [pmid: 12171487].
138 Bolufer P, Lo Coco F, Grimwade D, Barragan E, Diverio D, Cassinat B, Chomienne C, Gonzalez M, Colomer D, Gomez MT, Marugan I, Roman J, Delgado MD, Garcia-Marco JA, Bornstein R, Vizmanos JL, Martinez B, Jansen J, Villegas A, de Blas JM, Cabello P, Sanz MA. Variability in the levels of PML-RAR alpha fusion transcripts detected by the laboratories participating in an external quality control program using several reverse transcription polymerase chain reaction protocols. Haematologica. Jun. 2001;86(6):570-576. [pmid: 11418365].
139 Bolufer P, Barragan E, Sanz MA, Martin G, Bornstein R, Colomer D, Delgado MD, Gonzalez M, Marugan I, Roman J, Gomez MT, Anguita E, Diverio D, Chomienne C, Briz M. Preliminary experience in external quality control of RT-PCR PML-RAR alpha detection in promyelocytic leukemia. Leukemia. Dec. 1998;12(12):2024-2028. [pmid: 9844933].
140 Dorn-Beineke A, Ahmad-Nejad P, Pfeiffer U, Ramsden S, Pazzagli M, Neumaier M. Improvement of technical and analytical performance in DNA sequencing by external quality assessment-based molecular training. Clin Chem. Nov. 2006;52(11):2072-2078. [pmid: 16990419].
141 Ahmad-Nejad P, Dorn-Beineke A, Pfeiffer U, Brade J, Geilenkeuser WJ, Ramsden S, Pazzagli M, Neumaier M. Methodologic European external quality assurance for DNA sequencing: the EQUALseq program. Clin Chem. Apr. 2006;52(4):716-727. [pmid: 16439604].
142 Patton SJ, Wallace AJ, Elles R. Benchmark for evaluating the quality of DNA sequencing: proposal from an international external quality assessment scheme. Clin Chem. Apr. 2006;52(4):728-736. [pmid: 16455867].
143 Afshar B, Fry NK, Bellamy W, Underwood AP, Harrison TG. Members of the European Working Group for Legionella Infections. External quality assessment of a DNA sequence-based scheme for epidemiological typing of Legionella pneumophila by an international network of laboratories. J Clin Microbiol. Oct. 2007;45(10):3251-3256. [pmid: 17687012].
144 Jarvis M, Iyer RK, Williams LO, Noll WW, Thomas K, Telatar M, Grody WW. A novel method for creating artificial mutant samples for performance evaluation and quality control in clinical molecular genetics. J Mol Diagn. May. 2005;7(2):247-251. [pmid: 15858148].
145 Peterson JC, Hill RH, Black RS, Winkelman J, Tholen D. Identifying best practices in laboratory medicine: review of proficiency testing services for clinical laboratories in the United States - final report of a technical working group. Atlanta (GA). Battelle Memorial Institute. Apr. 2008:61. Also available: http://www.futurelabmedicine.org/Reports/2007_PT_Report_080320_rev_FINAL.pdf.
146 McGovern MM, Benach M, Wallenstein S, Boone J, Lubin IM. Personnel standards and quality assurance practices of biochemical genetic testing laboratories in the United States. Arch Pathol Lab Med. Jan. 2003;127(1):71-76. [pmid: 12521371].
147 Ramsden SC, Deans Z, Robinson DO, Mountford R, Sistermans EA, Grody WW, McQuaid S, Patton SJ, Stenhouse SA. Monitoring standards for molecular genetic testing in the United Kingdom, the Netherlands, and Ireland. Genet Test. 2006;10(3):147-156. [pmid: 17020464].
148 Valdes R Jr, Payne D, Linder MW, Burkhart G, Farkas D, Frueh F, McLeod H, Morrello JP, Rahman A, Ruano G, Shaw L, Jortani S, Steimer W, Wong S. Guidelines and recommendations for laboratory analysis and application of pharmacogenetics to clinical practice. Washington (DC). National Academy of Clinical Biochemistry (NACB). 2006:77.
149 Nolte FS. Molecular diagnostic methods for infectious diseases; approved guideline; MM03-A2. 2nd ed. Wayne (PA). Clinical and Laboratory Standards Institute. Feb. 17. 2007:88.
150 New CLSI guideline for infectious disease genotyping. Wayne (PA). Clinical and Laboratory Standards Institute. Mar. 1. 2006:1. Also available: http://www.clsi.org.
151 ACTG Laboratory Technologist Committee. VQA program testing requirements for new laboratories to obtain approval for HIV DNA testing in NIH-funded protocols. ACTG Lab Man VQA DNA PT Document. [internet]. Washington (DC). National Institute of Allergy and Infectious Diseases. Mar. 12. 2004:3. Available: http://aactg.s-3.com/pub/download/labmanual/64-ALM-VQA-DNA-PT-Document.pdf.
152 Practice guidelines for internal quality control within the molecular genetics laboratory. United Kingdom. Clinical Molecular Genetics Society (CMGS). 2004:1. Also available: http://cmgsweb.shared.hosting.zen.co.uk/BPGs/pdfs%20current%20bpgs/IQC.pdf.
153 Clinical Chemistry. The MIAME Checklist. (Minimum Information About a Microarray Experiment). Washington (DC). American Association for Clinical Chemistry. Jan. 2005:4. (Information for Authors). Also available: http://www.clinchem.org/info_ar/MIAMEcheck_Jan_05.pdf.
154 Guide to program requirements and services. Clinical laboratory evaluation program. Albany (NY). Wadsworth Center, New York State Department of Health. Sep. 2005:132. (Clinical Laboratory Reference System). Also available: http://www.wadsworth.org/labcert/clep/ProgramGuide/pg.htm.
155 Statewide Services Development. Genetic Testing - Guidelines for prioritising genetic tests (GL2007_013). Sydney (AU). Department of Health, NSW. Jul. 6. 2007:4. Also available: http://www.health.nsw.gov.au/policies/gl/2007/pdf/GL2007_013.pdf.
156 Madej RM, Caliendo AM, Day SP, Fernandes H, Ferreira-Gonzalez A, Krajden M, Loeffelholz M, Nolte FS, Pearson JL, Pope L, Ticehurst J. Quantitative molecular methods for infectious diseases; approved guideline [MM6-A]. Wayne (PA). National Committee for Clinical Laboratory Standards (NCCLS). Vol. 23(no. 28):6. Also available: http://www.clsi.org/source/orders/free/mm6-a.pdf.
157 Madej RM, et al. Proficiency testing (external quality assessment) for molecular methods: approved guidline. Wayne (PA). Clinical and Laboratory Standards Institute, International Federation of Clinical Chemistry and Laboratory Medicine. 2005:51. (Clinical and laboratory standards institute; vol. 25, no. 24).
158 Collection, transport, preparation, and storage of specimens for molecular methods; approved guideline. [MM13-A]. Wayne (PA). Clinical and Laboratory Standards Institute (CLSI, formerly NCCLS). 2006. Jan. Also available: http://www.clsi.org.
159 Use of external RNA controls in gene expression assays; approved guideline [MM16-A replaces MM16-P]. Wayne (PA). Clinical and Laboratory Standards Institute (CLSI formerly NCCLS). 2006;vol. 26(no. 29). Also available: http://www.clsi.org/source/orders/free/mm16a.pdf.
160 Centers for Disease Control and Prevention. Guidelines for laboratory test result reporting of human immunodeficiency virus type 1 ribonucleic acid determination: recommendations from a CDC working group. Atlanta (GA). Centers for Disease Control and Prevention (CDC). Nov. 16. 2001:20. (MMWR; vol. 50, no. RR-20). Also available: http://www.cdc.gov/mmwR/PDF/rr/rr5020.pdf.
161 Centers for Disease Control and Prevention (CDC). Good laboratory practices for waived testing sites; survey findings from testing sites holding a certificate of waiver under the Clinical Laboratory Improvement Amendments of 1988 and Recommendations for Promoting Quality Testing. Atlanta (GA). Centers for Disease Control and Prevention (CDC). 2005:32. (MMWR; vol. 54, no. RR-13). Also available: http://www.cdc.gov/mmwr/PDF/rr/rr5413.pdf.
162 American College of Medical Genetics. Standards and guidelines for clinical genetics laboratories. Technical standards and guidelines: molecular genetic testing for ultra-rare disorders. [internet]. Bethesda (MD). American College of Medical Genetics. Oct. 26. [accessed 2007 Oct 22]. 2004:18. Available: http://www.acmg.net/Pages/ACMG_Activities/stds-2002/URD.htm.
163 College of American Pathologists (CAP). Molecular pathology checklist: laboratory accreditation program. Northfield (IL). College of American Pathologists (CAP). Sep. 27. 2007:80. Also available: http://www.cap.org/apps/docs/laboratory_accreditation/checklists/molecular_pathology_sep07.pdf.
164 Gancberg D, Corbisier P, Schimmel H, Emons H. Guidance document on the use of reference materials in genetic testing. Geel, Belgium. European Commission, Joint Research Centre, Institute for Reference Materials and Measurements (IRMM). 2008:30. Also available: http://www.eurogentest.org/web/files/public/unit1/reference_materials/Guidance%20doc%20for%20Use%20RMsGT_report_complete.pdf.
165 EA-EUROLAB-EURACHEM Proficiency Testing Working Group. Use of proficiency testing as a tool for accreditation in testing [publication reference EA-03/04]. European Co-operation for Accreditation (EA). Aug. 2001:18. Also available: http://www.dar.bam.de/pdfe/dar_3_em_12.pdf.
166 McNally E, Cambon-Thomsen A. 25 recommendations on the ethical, legal and social implications of genetic testing. [EUR 21120]. Brussels (BE). European Commission. 2004:32. Also available: http://ec.europa.eu/research/conferences/2004/genetic/pdf/recommendations_en.pdf.
167 Best practice guidelines on reporting in molecular genetic diagnostic laboratories in Switzerland. Binningen (CH). Swiss Society of Medical Genetics. 2003:9. Also available: http://www.ssgm.ch/.
168 DynCorp Health Research Services. General recommendations for quality assurance programs for laboratory molecular genetic tests. [Contract #200-98-0011]. Atlanta (GA). Centers for Disease Control and Prevention (CDC). Aug. 31. 1999:46. Also available: http://wwwn.cdc.gov/dls/pdf/genetics/dyncor.pdf.
169 OECD guidelines for quality assurance in molecular genetic testing. Paris (FR). Organisation For Economic Co-Operation And Development (OECD). 2007:38. Also available: http://www.oecd.org/dataoecd/43/6/38839788.pdf.
170 Enns RK, Altmiller DH, Hinkel CS, Madej RM, O'Leary TJ. Immunoglobulin and T-cell receptor gene rearrangement assays; approved guideline, second edition. [MM2-A2]. Wayne (PA). National Committee for Clinical Laboratory Standards (NCCLS). 2002;Vol. 22(no. 12):40. Also available: http://www.clsi.org/source/orders/free/mm2-a.pdf.
171 Zoccoli MA, Chan M, Erker JC, Ferreira-Gonzalez A, Lubin IM. Nucleic acid sequencing methods in diagnostic laboratory medicine; approved guideline [MM9-A]. Vol. 24(no. 40). Wayne (PA). National Committee for Clinical Laboratory Standards (NCCLS). Also available: http://www.clsi.org/source/orders/free/mm9-a.pdf.
172 Holtzman NA, Watson MS. Promoting safe and effective genetic testing in the United States. [internet]. Bethesda (MD). National Institutes of Health (NIH). Sep. [accessed 2007 Oct 12]. 1997:154. Available: http://www.genome.gov/10001733.
173 Harris L, Fritsche H, Mennel R, Norton L, Ravdin P, Taube S, Somerfield MR, Hayes DF, Bast RC Jr. American Society of Clinical Oncology. American Society of Clinical Oncology 2007 update of recommendations for the use of tumor markers in breast cancer. J Clin Oncol. Nov. 20. 2007;25(33):5287-5312. [pmid: 17954709].
174 National Comprehensive Cancer Network (NCCN). NCCN clinical practice guidelines in oncology: breast cancer. V.1.2010. Fort Washington (PA). National Comprehensive Cancer Network (NCCN). 2009:122. Also available: http://www.nccn.org/professionals/physician_gls/PDF/breast.pdf.
175 Association for Molecular Pathology statement. Recommendations for in-house development and operation of molecular diagnostic tests. Am J Clin Pathol. Apr. 1999;111(4):449-463. [pmid: 10191765].
176 ACMG. Statement on storage and use of genetic materials. Bethesda (MD). American College of Medical Genetics (ACMG). May. 23. 2007:3. Also available: http://www.acmg.net/StaticContent/StaticPages/Storage.pdf.
177 Seabrook JM, Hubbard RA. Achieving quality reproducible results and maintaining compliance in molecular diagnostic testing of human papillomavirus. Arch Pathol Lab Med. Aug. 2003;127(8):978-983. [pmid: 12873170].
178 Barker PE, Watson MS, Ticehurst JR, Colbert JC, O'Connell CD. NIST physical standards for DNA-based medical testing. J Clin Lab Anal. 2002;16(1):5-10. [pmid: 11835524].
179 American College of Medicine Genetics Board of Directors. ACMG statement on direct-to-consumer genetic testing. Genet Med. Jan-Feb. 2004;6(1):60. Also available: http://www.genome.gov. [pmid: 14726812].
180 Scott J, Williams S. Genetic testing practice guidelines: translating genetic discoveries into clinical care. Washington (DC). Genetics and Public Policy Center. Sep. 2006:2.
181 Williams LO, Cole EC, Lubin IM, Iglesias NI, Jordan RL, Elliott LE. Quality assurance in human molecular genetics testing: status and recommendations. Arch Pathol Lab Med. Oct. 2003;127(10):1353-1358. [pmid: 14521456].
182 Appold K. How to manage your laboratory's nonconforming events. Lab Med. Sep. 2007;38(9):537-538.
183 Biotechnology Division (OECD). Quality assurance and proficiency testing for molecular genetic testing: summary results of a survey of 18 OECD member countries. Paris (FR). Organisation for Economic Co-operation and Development (OECD). 2005:47. Also available: http://www.oecd.org/dataoecd/25/12/34779945.pdf.
184 Goold IL, Pearn A, Bettiol S, Ballantyne A. Quality and safety of genetic testing in Australia and New Zealand: a review of the current regulatory framework. Aust N Z Health Policy. 2006;3:13. [pmid: 17092338].
185 Zarbo RJ, Jones BA, Friedberg RC, Valenstein PN, Renner SW, Schifman RB, Walsh MK, Howanitz PJ. Q-tracks: a College of American Pathologists program of continuous laboratory monitoring and longitudinal performance tracking. Arch Pathol Lab Med. Sep. 2002;126(9):1036-1044. [pmid: 12204052].
186 Congressional Record - Senate. Thursday March 1, 2007. 110th Congress, 1st Session. 153 Cong Rec S 2490.
187 Novis DA. Detecting and preventing the occurrence of errors in the practices of laboratory medicine and anatomic pathology: 15 years' experience with the College of American Pathologists' Q-PROBES and Q-TRACKS programs. Clin Lab Med. Dec. 2004;24(4):965-978. [pmid: 15555751].
188 Camenzind E, Steg PG, Wijns W. Stent thrombosis late after implantation of first-generation drug-eluting stents. A cause for concern. Circulation. Mar. 7. 2007;115:1440-1455. [pmid: 17344324].
189 Madej R. Using standards and controls in molecular assays for infectious diseases. Mol Diagn. Dec. 2001;6(4):335-345. [pmid: 11774198].
190 Stinshoff K, Sarl DS. Reference materials for genetic testing. ISO standardization. Leuven (BE). EuroGentest. 18. Also available: http://en.eurogentest.org/files/public/unit1/geel/Stinshoff_ISO_TC212.pdf.
191 Sturgeon CM. Tumor markers in the laboratory: closing the guideline-practice gap. Clin Biochem. Jul. 2001;34(5):353-359. [pmid: 11522270].
192 Office of Population Health Genomics. ACCE review summary hereditary non-polyposis colorectal cancer (HNPCC). Perth (AU). Department of Health Western Australia. Jul. 31. 2006:8. Also available: http://www.genomics.health.wa.gov.au/home/.
193 Abu-Amero KK, Abu-Amero SN. Molecular genetics laboratory: detailed requirements for accreditation by the College of American Pathologists. Mol Biol Today. 2001;2(3):45-59.
194 Abu-Amero KK. Overview of the laboratory accreditation programme of the College of American Pathologists. East Mediterr Health J. Jul-Sep. 2002;8(4-5):654-663. [pmid: 15603049].
195 COLA approved for laboratory accreditation under new CMS process. COLA given authority to accredit labs for next six years. [internet]. New York (NY). PR Newswire Association. Jan. 3. [accessed 2007 Jan 4]. 2007:2. Available: http://www.prnewswire.com/.
196 Clinical laboratory evaluation program submission guidelines for test approval. Albany (NY). Wadsworth Center, New York State Department of Health. Oct. 2006:5. Also available: http://www.wadsworth.org/labcert/TestApproval/submitguide.pdf.
197 In Vitro diagnostic multivariate index assays; Public meeting (IVDMIA). Washington (DC). Neal R. Gross, Court Reporters and Transcribers. Feb. 8. 2007:236.
198 Boone J. Current oversight of genetic testing. Atlanta (GA). Centers for Disease Control and Prevention (CDC). Sep. 28. 2004:24.
199 U.S. System of Oversight of Genetic Testing (SACGHS). A response to the charge of the secretary of HHS. Draft report of the Secretary's Advisory Committee on Genetics, Health, and Society. Available for public comment Nov 5 - Dec 21, 2007. Bethesda (MD). National Institutes of Health (NIH). Nov. 5. 2007:192. Also available: http://www4.od.nih.gov/oba/SACGHS/public_comments.htm.
200 Richards S. Clinical laboratory standard setting. Bethesda (MD). Office of Biotechnology Activities. 31.
201 Lab seeks clear regulations on lab-developed genetic tests. FDA Week. Aug. 31. 2007;13(31). 958 words.
202 Harper CC. FDA oversight of laboratory developed tests: current perspectives. AACC annual meeting and clinical lab expo. 2007. Jul. 15-19. San Diego (CA). Washington (DC). American Association for Clinical Chemistry (AACC). 2007. Jul. Also available: http://www.aacc.org/AACC/events/ann_meet/annual2007.
203 American Society of Clinical Oncology. American Society of Clinical Oncology policy statement update: genetic testing for cancer susceptibility. J Clin Oncol. Jun. 15. 2003;21(12):2397-2406. [pmid: 12692171].
204 Kutz G. Nutrigenetic testing. Tests purchased from four web sites mislead consumers. Statement of Gregory Kutz, Managing Director Forensic Audits and Special Investigations [GAO-06-977T]. Washington (DC). U.S. Government Accountability Office. Jul. 27. 2006:27. Also available: http://www.gao.gov/new.items/d06977t.pdf.
205 Senate bills take differing tack on genetic test oversight. [internet]. Washington (DC). Washington G-2 reports. Apr. 9. [accessed 2008 Jan 28]. 2007:2. Available: http://www.g2reports.com/issues/NIR/2007_7/1612293-1.html.
206 Blue Cross and Blue Shield of Massachusetts. Pharmacogenomics-based treatment of helicobacter pylori infection. [internet]. Boston (MA). Blue Cross and Blue Shield of Massachusetts. 2008:22. Available: http://www.bcbs.com/blueresources/tec/vols/23/23_02.pdf.
207 Fry NK, Afshar B, Bellamy W, Underwood AP, Ratcliff RM, Harrison TG. European Working Group for Legionella Infections. Identification of Legionella spp. by 19 European reference laboratories: results of the European Working Group for Legionella Infections External Quality Assessment Scheme using DNA sequencing of the macrophage infectivity potentiator gene and dedicated. Clin Microbiol Infect. Nov. 2007;13(11):1119-1124. [pmid: 17725649].