# Introduction

The Coverage and Analysis Group at the Centers for Medicare & Medicaid Services (CMS) requested from The Technology Assessment Program (TAP) at the Agency for Healthcare Research and Quality (AHRQ) a horizon scan to summarize the available scientific evidence on the quality of laboratory-developed (“home brew” or “in-house”) molecular tests, which are currently not actively regulated by the U.S. Food and Drug Administration (FDA). CMS has concerns about the quality of laboratory-developed tests and the validation currently being performed on these tests. AHRQ assigned this report to the following Evidence-based Practice Center (EPC): ECRI EPC (Contract Number: 290 2007 10063 I). To help CMS to address its concerns, this horizon scan is intended to: 1) identify types of laboratory-developed molecular tests (LDMTs) currently available for conditions relevant to the Medicare over-65-year-old population, 2) identify the methodologies and the processes that have been developed for the assessment of analytical and clinical performance of molecular tests, 3) summarize the role of Federal agencies in regulating LDMTs, and 4) identify the quality standards that have been developed for molecular tests by regulatory bodies, the industry, and the medical community.

## Scope of this Report

In this report, we use the term “molecular test” (MT) interchangeably with the term “molecular genetic test.” We adopted the definition of molecular genetic test recommended by the Genetic Work Group of the Clinical Laboratory Improvement Advisory Committee. The Work Group defined a genetic molecular test as “an analysis performed on human DNA or RNA to detect heritable or acquired disease-related genotypes, mutations, or phenotypes for clinical purposes.”1 According to this definition, cytogenetic tests, which are performed on human chromosomes, and biochemical genetic tests, which analyze human proteins and certain metabolites, are beyond the scope of this report. However, molecular cytogenetic tests (e.g., the tests using the fluorescence in situ hybridization (FISH) technology) in which analyses cross both the chromosome and the DNA levels are included in this report. In this report, we also consider a test performed on pathogen (e.g., bacterial, viral or fungal) DNA or RNA as a molecular test if the purpose of the test is to diagnose an infectious disease caused by the pathogen in human.

In accordance with the objectives outlined in the scope of work, this horizon scan only includes molecular tests of potential clinical relevance to the Medicare over-65-year-old population as of October 31, 2008. Particularly, molecular tests for the following purposes are addressed:

- tests used for diagnostic purposes in symptomatic individuals,
- tests used as prognostic indicators,
- tests used to monitor response to therapy, and
- tests used to choose therapies for a known disease entity or used to adjust medication dosing.

Excluded from this report are molecular tests used primarily for blood supply screening, tissue typing, epidemiological surveillance, pure research, and forensic purposes. Tests used to screen for inherited diseases of metabolism or other conditions of greater relevance to the pediatric population (e.g., the diagnostic or screening tests for cystic fibrosis) are also beyond the scope of this report.

A molecular test can be performed using either a protocol developed within the laboratory or a test kit developed by a manufacturer for commercial distribution to multiple laboratories. Commercially distributed test kits include all reagents and instructions needed to complete the test procedure and interpret the results. These commercial kits are currently regulated by the FDA as in-vitro diagnostic devices. Laboratory-developed molecular tests (LDMTs), also known as homebrew or in-house molecular tests, are developed within laboratories using either FDA regulated or self-developed analyte specific reagents (ASRs) and intended for use solely in the test developer’s laboratory. LDMTs are not actively regulated by the FDA, although the Agency claims its jurisdiction over such tests. This report focuses on LDMTs; however, in cases where we cannot tell whether a test offered by a laboratory uses a commercial kit or is one developed in house, we included the test and labeled it differently from those clearly identified as LDMTs.

## Overview of Molecular Testing Technology

During the last few decades, advances in genetic science have greatly extended and deepened the understanding of the mechanisms of diseases at the molecular level. This understanding is now being translated into diagnostic, prognostic, and therapeutic tools, and molecular tests have now been developed for a wide variety of clinical conditions.

One of the most popular applications of molecular tests (as we catalog in Chapter 1 of this report) is to detect the presence of particular viruses, bacteria, or other types of pathogens in samples taken from patients. The molecular methods are often faster and more sensitive than traditional microbiological diagnostic techniques such as cultures, antigen detection, and microscopic visualization. Molecular testing is particularly valuable for detecting microorganisms that cannot be easily cultured, require long incubation, or are not easily recovered for technical reasons (specimen transport requirements, prolonged turnaround times, technically demanding procedures, etc.). Molecular tests can also be used to quantify the loads of detected microorganisms, which can be useful in assessing disease severity and monitoring treatment efficacy.

Molecular tests are also widely used in oncology and hematology. As Chapter 1 of this report shows, various malignancy-associated molecular tests have been developed to aid diagnosis, to evaluate prognosis, to detect residual or recurrent disease, and to aid in selecting treatment. For example, molecular tests to detect the ERBB2 gene (also known as HER2) have gained acceptance as a potentially useful aid in customizing treatment strategies for breast cancer. Detection of particular fusion transcripts (a type of genetic marker) in the blood by polymerase chain reaction (PCR), a genetic technique discussed below, has been used in the diagnosis and management of hematological malignancies. FISH (another genetic technique that is discussed later) has also been used to study chromosomal abnormalities in both hematological malignancies and solid tumors.

Molecular techniques are also used outside of the infectious disease and malignancy areas. For example, research has shown that some of the unexpected response to a blood-thinning drug, warfarin (Coumadin®), depends on variants of two genes: CYP2C9 and VKORC1. The FDA has cleared several molecular test kits for detecting such genetic variants. These molecular tests may potentially aid physicians in choosing the right dosage of warfarin for patients. In addition, molecular tests are widely used in blood supply screening, tissue typing, epidemiological surveillance, forensic testing, and heritable disease screening, although these applications are beyond the scope of this report.

### Major Molecular Techniques

Over the years, a number of techniques have been developed for molecular testing. To facilitate the discussions in the coming chapters, we provide a brief overview of two groups of molecular techniques most frequently used in the tests that we cataloged for this report.

#### Polymerase Chain Reaction (PCR)

PCR is a nucleic acid amplification technique widely used in molecular testing. During PCR, the sample containing the DNA pieces for testing (targets) is heated first so that the two strands of the DNA become separated (a process called denaturation). Then, primers—short nucleic acid strands that are complementary to the targets—are used to bind with the targets on each separated DNA strand (a process called annealing). Once primers are annealed to the targeted DNA fragments, a special enzyme called DNA polymerase will start to catalyze the DNA replication process. Each PCR cycle doubles the amount of the targeted DNA sequences. After multiple PCR cycles, a single (or a few fragments of a) DNA strand is exponentially amplified (replicated) into millions or more copies within a short span of time. The PCR technique allows selective isolation and amplification of specific DNA fragments thus permitting methods of analysis that require large amounts of a particular fragment of DNA (e.g., DNA sequencing, genetic fingerprinting, hybridization).

Over the years, the basic PCR technique has been modified to perform a wide array of genetic manipulations and diagnostic tests. As a result, various derivatives of the technique have emerged. For example, reverse transcription PCR (RT-PCR) was developed to detect and quantify messenger RNA (mRNA) sequences to study gene expression within a cell or tissue. During RT-PCR, the RNA strand is first transcribed reversely into its complementary DNA (cDNA), and then the PCR technique is used to amplify the resulting cDNA. Another popular PCR derivative, multiplex PCR, uses multiple, unique primer sets simultaneously to detect multiple targets, which greatly improves testing efficiency. Also a derivative of the basic PCR technique, real-time PCR allows quantitative estimation of the amount of the DNA sequence of interest present in a sample. Since real-time PCR can amplify and quantify targeted DNA or RNA sequences simultaneously throughout the testing process, it significantly reduces test turnaround time.

In addition to those mentioned above, other PCR-based test methods (e.g., allele-specific PCR, assembly PCR, asymmetric PCR, colony PCR, hot-start PCR, intersequence-specific PCR, Inverse PCR, Ligation-mediated PCR, Methylation-specific PCR, nested PCR, overlap-extension PCR, TAIL-PCR, and touchdown PCR), as well as PCR-like nucleic acid amplification techniques (e.g., ligase chain reaction, helicase-dependent amplification and multiplex ligation-dependent probe amplification), have also been developed and are used for clinical or research purposes. PCR (including PCR-based methods and PCR-like nucleic acid amplification techniques) are the most frequently used molecular methods in the tests that we cataloged for this report (see Chapter 1).

#### Hybridization

Hybridization is a molecular technique that involves detection of specific DNA or RNA sequences by hybridizing (i.e., binding or annealing) a labeled probe—a nucleic acid sequence complementary to the target of interest—to the DNA. Several in situ hybridization methods including fluorescence in situ hybridization (FISH), chromogenic in situ hybridization (CISH), and silver in situ hybridization (SISH) have been developed to detect and localize specific DNA sequences on chromosomes. During in situ hybridization, thin slices of a sample tissue are cut and attached to slides, or blood samples are smeared onto slides. The DNA in the cells is denatured by chemicals or heat. Then a piece of labeled DNA probe (in FISH, e.g., labeled fluorescently) is washed across the slide and hybridizes to the exposed gene on the denatured DNA strand by complementary base pairs. After the hybridization procedure, the slides are examined (in FISH, e.g., under a fluorescent microscope) for detection and localization of the gene of interest on the chromosomes. In situ hybridization techniques have been used in many malignancy-related molecular tests that we cataloged for this report. The technique can also be used in some infectious disease testing where the probe binds to the viral DNA/RNA or bacterial material.

Microarray (sometimes referred to as DNA chip) is another hybridization technique that has been used in a small number of tests that we cataloged. This technique allows simultaneous detection of multiple targets (mRNA or DNA sequences) from the same sample within a short span of time. Microarrays are produced by spotting probes (small fragments of DNA complementary to targets) onto the support medium (e.g., glass microscope slides, silicon chips, or nylon membranes) according to a predetermined pattern. During a test using microarrays, targets in the sample hybridize to the probes and the pattern of hybridization is then evaluated. One of the major applications of the microarray technology is to assay gene expression. Using microarrays, scientists can determine the expression levels of genes within a cell by measuring the amount of mRNA bound to each site on the array. Another popular application of microarrays is analysis of single nucleotide polymorphisms (SNP) that are DNA sequence variations that may be associated with susceptibility to disease or related to drug responsiveness.

The hybridization technique is also used as an element in other molecular methods such as Southern blot, a technique to check for the presence of a DNA sequence in a DNA sample, and Northern blot, a technique for gene expression study. Those techniques use a labeled probe to hybridize to the targeted DNA or RNA sequence in the late stage of the test so that the presence or absence of the targeted sequence can be detected.

### Challenges in Molecular Test Assessment and Oversight

With the continuous advances in genetic research and molecular technologies, especially with the completion of the Human Genome Project, molecular diagnostic testing has become a fast-growing service area. Many clinical laboratories or diagnostic test kit manufacturers have entered, or are entering, this potentially lucrative market. For this report alone, we cataloged over 1,400 molecular tests relevant to the Medicare over-65-year-old population (as of October 31, 2008) offered by 95 different laboratories. Chapter 2 provides a detailed listing and discussion of these tests. Note that our catalogue is not all-inclusive, e.g., tests primarily used in the pediatric population or for heritable conditions are not included.

As with any other diagnostic test, molecular tests, whether they are laboratory-developed or commercial kits, can be evaluated at multiple levels. While no consensus has been reached on any of the currently proposed frameworks for the evaluation of molecular tests, many experts in the field argued that such evaluation should cover several key components, including the tests’ analytic validity, clinical validity, and clinical utility.2, 3 Analytic validity simply refers to how well a test performs in the laboratory—how well does the test measure the properties or characteristic it is intended to measure (e.g., a gene mutation)? Clinical validity (also known as diagnostic accuracy) refers to the accuracy with which a test predicts the presence or absence of a clinical condition or predisposition. Clinical utility refers to the usefulness of the test and the value of information to medical practice. If a test has utility, it means that the results of the test can be used to pursue effective treatment or provide other concrete benefit. Chapters 2, 3 and 7 of this report describe how the analytic validity, clinical validity, and clinical utility of molecular tests are assessed.

The oversight of laboratory tests in the U.S. is provided by a still-evolving system that currently includes Government agencies, health care payers, professional associations, and other stakeholders. (A recent report published by the Secretary’s Advisory Committee on Genetics, Health, and Society [SACGHS] provided an overview of the system).3 At the Federal level, the FDA regulates commercially distributed test kits as in-vitro diagnostic devices. However, the majority of molecular tests are laboratory-developed tests (LDTs). LDTs are not actively regulated by the FDA, although the Agency claims its jurisdiction over such tests and currently regulates the commercially distributed ASRs used in LDMTs.

A laboratory that performs tests of moderate or high technical complexity (including most, if not all, molecular tests) is subject to the regulations of the Clinical Laboratory Improvement Amendments (CLIA). Under the current CLIA regulations, the analytic validity of the tests is the primary focus of the assessment. CLIA leave the assessment responsibility for clinical relevance of LDMTs mostly to the directors or clinical consultants of the laboratories that provide the testing service. Although the assessment of clinical relevance of the tests is required to be documented and reviewed in the CLIA certification process, the result of the assessment is rarely available to the public or decision makers for review.

Meanwhile, unlike most of the other tests of moderate or high complexity, molecular tests do not have a CLIA-designated specialty or sub-specialty of their own. No formal CLIA-approved proficiency testing (PT) programs (i.e., external test quality control programs) have been established for molecular tests. Laboratories are currently required to use alternative methods to validate the analytical performance of molecular tests prior to offering them to patients (e.g., through a sample split program or an unofficial PT program). It is still unclear whether the alternative validation methods are as effective as a formal proficiency testing program in detecting potential quality problems.

The current oversight status (the details of which are described in chapters 4, 5 and 6 of this report) has generated concern among the public and medical community alike about the quality of LDMTs. The complex nature of molecular tests further intensifies such concerns. As we discuss in Chapters 2, 3, and 7, many technical problems may occur in the complex molecular testing processes, such as flawed probe, primer, or array design. Recently, the Clinical Laboratory Improvement Advisory Committee (CLIAC) Genetic Testing Good Laboratory Practices Workgroup published a report that provided a series of recommendations for ensuring the quality of molecular genetic testing.4 These recommendations were made to the CLIAC, an advisory entity that has been providing recommendations to the Department of Health and Human Services on approaches needed to ensure the quality of genetic testing since 1997.

## Key Questions and Organization of this Report

This Horizon Scan addresses the following eight Key Questions:

1. What types of laboratory-developed molecular tests are currently available for conditions relevant to the Medicare over-65-year-old population?
2. How is analytic validity established for laboratory-developed molecular tests?
3. What processes have been developed for examining clinical validity and clinical utility of molecular tests?
4. How are molecular tests regulated by the Clinical Laboratory Improvement Amendments (CLIA)?
5. What Food and Drug Administration (FDA) guidance has been issued pertaining to oversight of laboratory-developed molecular testing?
6. What is the role of other Federal agencies (e.g., Federal Trade Commission) in regulating marketing claims regarding the clinical validity and utility of laboratory-developed tests not currently being actively regulated by the FDA?
7. How is proficiency testing accomplished for molecular tests, whether laboratory-developed or commercial?
8. What guidelines and standards exist for laboratories conducting molecular testing?

Based on the Key Questions, this report consists of the Introduction, 8 chapters (each addressing one question) and an Epilogue. The methods and results for each Key Question are described in each chapter. Unless specified otherwise, the literature search strategy for each Key Question is provided in Appendix A of this report.