# Epilogue

Molecular testing is a rapidly expanding area of research and clinical application. The strong growth of this area has largely been fueled by the many groundbreaking advances in genetic research and molecular technology, such as the completion of the Human Genome Project. While the introduction of a wide array of molecular tests has the potential to improve quality of care, many stakeholders have voiced concern about the quality of these tests, in addition to concern about their safety, effectiveness, cost, and ethical implications.3, 89, 204, 205 Laboratory-developed molecular tests (LDMTs) are of particular concern because they comprise the majority of currently available molecular tests and they are not actively regulated by the FDA.

Various efforts have been initiated to address these concerns. The Secretary’s Advisory Committee on Genetic, Health, and Society (SACGHS) was chartered in 2002 to assist the Secretary of Health and Human Services in evaluating policy issues arising from the diffusion of genetic testing into clinical and public health practice. Having identified oversight of genetic testing as a high priority issue, this committee developed a report on the subject and published the report in April 2008.^3^ In this report, the SACGHS recommended funding for development of reference methods, materials and biological samples necessary for assuring the analytic validity of genetic tests. They also recommended additional research to develop robust methods for assessing the performance of the laboratories offering genetic tests other than the current proficiency testing model used by other laboratory disciplines.

In 2007, U.S. Senator Edward Kennedy and then-Senator Barack Obama introduced two proposals, respectively, to enhance genetic test oversight.205 In July 2007, the FDA published a draft guidance indicating the Agency’s intention to regulate in-vitro diagnostic multivariate index assays (IVDMIAs) as medical devices.93 Under the proposed guidance, some LDMTs would be categorized as IVDMIAs. The State of New York, one of the two CLIA-exempt States, has already been using standards that are arguably more stringent than those used by other regulatory bodies to evaluate laboratory-developed tests. Under New York State’s regulations, all laboratories performing molecular tests on specimens collected from the State are required to obtain pre-approval prior to offering a test.3

The Evaluation of Genomic Applications in Practice and Prevention (EGAPP) project was initiated by CDC in 2005 to develop a rigorous, evidence-based process for evaluating genetic tests and their applications for clinical and public health practice. The EGAPP Working Group published a paper in 2008, describing the methods that it developed for establishing the evidence-based assessment process.2 In June 2009, the Clinical Laboratory Improvement Advisory Committee (CLIAC) Genetic Testing Good Laboratory Practices Workgroup published a report that made recommendations for good laboratory practices for ensuring the quality of molecular genetic testing.4 The recommended practices address the total testing process (including the preanalytic, analytic, and postanalytic phases), laboratory responsibilities regarding authorized persons, confidentiality of patient information, personnel competency, considerations before introducing molecular genetic testing or offering new molecular genetic tests, and the quality management system approach to molecular genetic testing.

Our report is among these efforts to address the concerns about the quality of LDMTs. Each of the chapters in our report focuses on one Key Question. In Chapter 1, we addressed Key Question 1 with the goal of providing a quick overview of the molecular tests (both laboratory-developed tests and commercially available kits) currently available to the Medicare over-65-year-old population. Our searches identified 1,441 such tests—of which 812 were clearly identified as laboratory-developed tests—performed by 95 laboratories. Given the time frame of this project, we used the AMP Web site as our primary source for identifying LDMTs of interest. The AMP Web site was chosen over other sites of similar purpose (e.g., www.genetests.org) because the AMP provided more information on the tests and the laboratories. This information permitted us to determine whether the tests within the scope of this Horizon Scan. We also identified a small number of LDMTs from non-AMP sources (e.g., literature reviews and the Web sites of commercial laboratories).

In Chapters 2, 3, 4 and 7, we addressed the Key Questions concerning how analytic validity, clinical validity and clinical utility are established for molecular tests. Our approach to addressing these questions is primarily based on literature review, with published systematic reviews given the highest priority. This approach allowed us to shed light on some of the more popular molecular tests currently in clinical use. The identified systematic reviews suggest that validation of molecular tests is challenging due to some technical hurdles, such as lack of “gold-standard” reference methods and difficulty to obtain testing samples. As a result, the analytic and clinical validity of these tests was often not backed up by quality data in the public domain. Without analytic and clinical validity of molecular tests being adequately established and due to lack of studies—particularly RCTs—that correlate test results with clinical outcomes, clinical utility of molecular tests is difficult to establish.

In Chapters 4, 5, and 6, we addressed the Key Questions regarding the oversight of molecular tests. In addressing these questions, we reviewed government documentations for first-hand information. We also interviewed key government officials from relevant regulatory bodies to collect or confirm information. The information that we collected reveals that, although the FDA claims the authority to oversee laboratory-developed tests, including LDMTs, the agency has been exercising enforcement discretion by far. However, there is a possibility that the agency may step up its oversight on a subset of LDMTs that falls into the category of in vitro diagnostic multivariate index assays (IVDMIAs). The agency has published a draft guidance for industry, clinical laboratories, and the FDA staff, signaling that IVDMIAs might be under the agency’s oversight in the future (discussed in Chapter 5).

Under the Clinical Laboratory Improvement Amendments (CLIA) program, laboratories are required to establish the analytic validity of LDMTs if they perform such tests. However, due to the reasons previously discussed, establishing the analytic validity of LDMTs is a challenging task. Meanwhile, there are concerns about whether the clinical validity and utility of LDMTs have been addressed adequately, or at all, under CLIA.3 Although CLIA requires laboratory directors and clinical consultants to ensure the clinical relevance of the tests being performed, how laboratory directors and clinical consultants establish the clinical relevance (e.g., what types of data were used, where the data came from, and how the data were synthesized) have rarely been revealed to the public.

In Chapter 8, we provided a list of standards and guidelines concerning quality assurance and evaluation of molecular tests. The 41 guidelines and standards that we identified are sponsored by organizations from U.S., Europe, or Australia, and cover a variety of technical issues regarding different types of molecular methods. The vast majority of these guidelines and standards were published within the past five years. The Clinical Laboratory Standards Institute (CLSI), a U.S.-based organization that develops laboratory standards based on voluntary consensus, is the most prominent sponsor of molecular-test-related guidelines. A number of these guidelines, particularly those sponsored by the CLSI, the College of American Pathologists, the Clinical Molecular Genetics Society, DynCorp Health Research Services, the European Molecular Genetics Quality Network, the National Academy of Clinical Biochemistry, the New York State Department of Health (Wadsworth Center), the Organization for Economic Cooperation and Development, and the Standards Unit of the Evaluation and Standards Laboratory of the Health Protection Agency in the United Kingdom, directly address the measures necessary to assure policymakers, clinicians and the public of the analytic validity and proficient performance of laboratory-developed tests.

Given the dynamic nature of the molecular testing area, the assessments of the quality, regulation, or utility of LDMTs need to be frequently updated. One of the major challenges for those making decisions about the oversight of LDMTs will be to keep pace with the future developments in the area. Currently, the experience of the Clinical Laboratory Evaluation Program in New York State should certainly provide some valuable lessons in how the oversight of LDMTs might be accomplished and what resources would be necessary to do so on a national scale.

At this stage in the evolution of laboratory-developed tests, assessments of the appropriate clinical applications and development of evidence-based guidelines for using test results in decision making are only beginning to appear. The EGAPP program is making important contributions in this area, but with the rapid expansion of test offerings, guidance for the use of most laboratory-developed tests will lag far behind. Furthermore, in the absence of specific reimbursement codes for specific laboratory-developed and other molecular tests, it will be difficult to track practice patterns and to understand the impact of these tests on the patient outcomes and on the practice of medicine.