# What Guidelines and Standards Exist for Laboratories Conducting Molecular Testing?

For Key Question 8, we were asked to identify guidelines and standards for laboratories conducting molecular testing.

## Methods

To begin identifying guidelines and standards, we searched the Web sites of the following organizations listed in the statement of work: American College of Medical Genetics, College of American Pathologists, American Society for Clinical Oncology, National Institute of Standards and Technology, Clinical and Laboratory Standards Institute, and the New York State Clinical Laboratory Evaluation Program. We also searched the National Guideline ClearinghouseTM and ECRI Institute’s Healthcare Standards database for additional clinical practice guidelines, published standards, position papers, and peer-reviewed literature.

## Results

Our searches identified a total of 34 guidelines and standards for laboratories conducting molecular tests from the above-mentioned organizations. Twenty-five of the 34 guidelines and standards are sponsored by organizations from the United States, with the remaining ones sponsored by European or Australian organizations. The vast majority of the identified guidelines and standards were published within the past five years. The Clinical Laboratory Standards Institute (CLSI), a U.S.-based organization that develops laboratory standards based on voluntary consensus, is the most prominent sponsor of molecular-test-related guidelines. The 12 guidelines published by CLSI cover a variety of technical issues regarding different types of molecular methods. Table 10 provides a summary of the 41 guidelines and standards. The table highlights the key technical areas covered by the guidelines or standards, including: testing techniques, testing samples, testing validation and verification, proficiency testing, sensitivity and specificity, quality control and quality assurance, safety, results interpretation and reporting, clinical utility, laboratory, personnel, and clinicians, accreditation, certification, and program evaluation, test regulation and recommendations. In addition, we identified 38 peer-reviewed articles that describe or discuss guidelines or standards relevant to molecular testing.

For detailed information about each standard or guideline, including its publisher, title, purposes, description, year of publication, and reference number, refer to Table 36 in Appendix E. Note that, although the U.S. Food and Drug Administration (FDA) has published a series of guidance documents relevant to molecular testing, we only include the two documents that are most relevant to laboratory-developed tests in this chapter. For other FDA-issued guidances, refer to Chapter 5.

Table 10 Summary of Guidelines and Standards for Laboratories Performing Molecular Tests

Source | Title | Year | Region | Testing Techniques | Testing Samples | Testing Validation and Verification | Proficiency Testing | Sensitivity and Specificity | Quality Control and Quality Assurance | Safety | Results Interpretation and Reporting | Clinical Utility | Laboratory, Personnel, and Clinician | Accreditation, Certification, and Program Evaluation | Test Regulations and Recommendations | Reference
NACB | Guidelines and Recommendations for Laboratory Analysis and Application of Pharmacogenetics to Clinical Practice | 2006 | USA | X | | | | | X | | X | X | | | X | 148
FDA | Guidance for Industry and FDA Staff Commercially Distributed Analyte Specific Reagents (ASRs): Frequently Asked Questions | 2007 | USA | | | | | | | | | | | | X | 33
FDA | Draft Guidance for Industry, Clinical Laboratories, and FDA Staff - In Vitro Diagnostic Multivariate Index Assays (IVDMIAs) | 2007 | USA | | | | | | | | | | | | X | 33
CLSI | Molecular Diagnostic Methods for Infectious Disease; Approved Guideline 2nd Edition | 2006 | USA | X | | | | | X | | X | | | | X | 149
CLSI | Molecular Diagnostic Methods for Genetic Diseases; Approved Guideline 2nd Edition | 2006 | USA | X | | X | | | X | X | X | | | | | 13
CLSI | Genotyping for Infectious Diseases: Identification and Characterization; Approved Guideline | 2006 | USA | X | | X | | | | | X | X | | | | 150
ACTG | Virology Quality Assessment (VQA) Program Testing Requirements for New Laboratories to Obtain Approval for HIV DNA Testing in NIH-Funded Protocols | 2004 | USA | | | | | | | | | | | X | | 151
CMGS | Practice Guidelines for Internal Quality Control within the Molecular Genetics Laboratory | 2004 | United Kingdom | X | X | | | | X | | | | | | | 152
MIAME | The MIAME Checklist | 2005 | | | | | | | | | X | | | | | 153
New York State Department of Health - Wads-worth Center | Clinical Laboratory Evaluation Program (CLEP) - Guide to Program Requirements and Services | 2005 | USA | X | X | X | X | X | X | X | X | | X | X | X | 154
NSW Department of Health | Genetic Testing - Guidelines for Prioritizing Genetic Tests | 2007 | Australia | | | | X | | | | | | | | | 155
CLSI | Quantitative Molecular Methods for Infectious Diseases | 2003 | USA | X | X | X | X | | | | X | X | | | | 156
CLSI | Proficiency Testing (External Quality Assessment) for Molecular Methods; Approved Guideline | 2005 | USA | | | | | | | | | | X | | | 157
CLSI | Collection, Transport, Preparation, and Storage of Specimens for Molecular Methods; Approved Guideline | 2005 | USA | X | | | | | | X | | | | | | 158
CLSI | Use of External RNA Controls in Gene Expression Assays; Approved Guideline | 2006 | USA | | | X | | | X | | X | | | | | 159
CLSI | Verification and Validation of Multiplex Nucleic Acid Assays; Proposed Guideline | 2007 | USA | X | X | X | | | | | X | | | | | 15
CDC/MMWR | Guidelines for Laboratory Test Result Reporting of Human Immuno-deficiency Virus Type 1 Ribonucleic Acid Determination | 2001 | USA | | | | | | | | X | | | | | 160
CDC/MMWR | Good Laboratory Practices for Waived Testing Sites | 2005 | USA | | | | X | | X | X | | | | | X | 161
CDC/MMWR | Good Laboratory Practices for Molecular Genetic Testing for Heritable Diseases and Conditions | 2009 | USA | X | X | X | X | X | X | | X | | X | | X | 4
ACMG | Standards and Guidelines for Clinical Genetics Laboratories Technical Standards & Guidelines: Molecular Genetic Testing for Ultra-Rare Disorders | 2006 | USA | X | | X | | | | | X | | | | | 162
CAP | Laboratory Accreditation Program - Molecular Pathology Checklist | 2007 | USA | X | X | X | X | X | X | X | X | | X | X | | 163
CAP | Clinical Laboratory Reports in Molecular Pathology | 2007 | USA | | | | | | | | X | | | | | 36
CAP | Recommended Principles and Practices for Validating Clinical Molecular Pathology Tests | 2009 | USA | | | X | | X | | | X | | | | X | 7
ACMG | Standards and Guidelines for Clinical Genetics Laboratories | 2006 | USA | X | X | X | | | X | | | | | | | 8
European Commission | Guidance Document on the Use of Reference Materials in Genetic Testing | 2008 | Europe | X | | X | | | X | | | | | | | 164
European co-operation for Accreditation | Use of Proficiency Testing as a Tool for Accreditation testing | 2001 | Europe | | | | | | | | | | X | | | 165
Standards Unit, Evaluations and Standards Laboratory | Good Laboratory Practice When Performing Molecular Amplification Assays | 2006 | Europe | | | | X | | | | | | | | | 35
European Commission | 25 Recommendations on the ethical, legal, and social implications of genetic testing | 2004 | Europe | | | | | | | X | | | | | X | 166
Swiss Society of Medical Genetics | Best Practice Guidelines on Reporting in Molecular Genetic Diagnostic Laboratories in Switzerland | 2003 | Europe | | | | | | | | X | | | | | 167
DynCorp Health Research Services | General Recommendations for Quality Assurance Programs for Laboratory Molecular Genetic Tests | 1999 | USA | | | | | | X | | | | X | | | 168
EMQN | Draft Best Practice Guidelines for Laboratory Internal Quality Control | 2002 | Europe | | X | X | | | | | X | | | | | 34
OECD | Guidelines for Quality Assurance in Molecular Genetic Testing | 2007 | Europe | | | | | | X | | | | | | | 169
CLSI | Immunoglobulin and T-cell Receptor Gene Rearrangement Assays; Approved Guideline | 2002 | USA | X | X | | | X | X | | X | | | | | 170
CLSI | Nucleic Acid Amplification Assays for Molecular Hematopathology; Approved Guideline | 2003 | USA | | X | | | X | X | | X | | | | | 12
CLSI | Fluorescence In Situ Hybridization (FISH) Methods for Medical Genetics; Approved Guideline | 2004 | USA | X | | | | | | | | | | | X | 14
CLSI | Nucleic Acid Sequencing Methods in Diagnostic Laboratory Medicine; Approved Guideline | 2004 | USA | | X | | | | | | X | | | | | 171
CLSI | Diagnostic Nucleic Acid Microarrays; Approved Guideline | 2006 | USA | | X | X | | | X | | X | | | | | 11
NHGRI | Promoting Safe and Effective Genetic Testing in the United States | 1997 | USA | | | | | | | X | | | | | | 172
ASCO | Recommendations for the Use of Tumor Markers in Breast Cancer Update | 2007 | USA | | | | | | | | | X | | | | 173
NCCN | Breast Cancer Oncotype DX assay | 2009 | USA | | | | | | | | | X | | | | 174
AMP | Recommendations for In-House Development and Operation of Molecular Diagnostic Tests | 1999 | USA | X | X | X | X | X | X | | X | | X | | X | 175
Peer-reviewed articles | | | | 24,156 | 156,176 | 20,21,156,177,178 | 146,176,179,180 | | 22,30,119,146,156,177,181–190 | 184 | 156 | 24 | 118,156,183,189,191 | 17,192–196 | 184,186,189,197–203

ACMG American College of Medical Genetics

ACTG AIDS Clinical Trials Group

AMP Association for Molecular Pathology Statement

ASCO American Society of Clinical Oncology

CAP College of American Pathologists

CDC/ MMWR Centers for Disease Control and Prevention – Morbidity and Mortality Weekly Report

CLSI Clinical Laboratory Standards Institute

CMGS Clinical Molecular Genetics Society

EMQN European Molecular Genetics Quality Network

FDA Food and Drug Administration

MIAME Minimum information about a microarray experiment

NACB National Academy of Clinical Biochemistry

NCCN National Comprehensive Cancer Network

NHGRI National Human Genome Research Institute

NSW Department of Health New South Wales Department of Health

OECD Organisation for Economic Co-Operation and Development