# How Is Proficiency Testing Accomplished for Molecular Tests?

For Key Question 7, we were asked to take a closer look at how proficiency testing is accomplished for molecular tests, specifically in the following areas:

- Control materials
  - What programs exist to provide human mutation samples or synthetic samples for use as control materials?
  - To what extent do laboratories exchange control samples voluntarily for the purpose of proficiency testing?
- What method-specific (rather than analyte-specific) proficiency tests have been developed?
- What organizations or programs are implementing proficiency testing programs for molecular tests, and what standards have these programs established?
- What proficiency test results for molecular testing have been published by the identified testing organizations?
- Based on these published studies, what factors have been identified which contribute to variability within and across laboratories performing molecular testing?
- Based on published studies, what impact have these proficiency testing programs had on reducing variation within and between laboratories?
- What data are available from the accrediting organizations on the impact of proficiency testing programs on laboratory performance?

## Methods

To address this question, we summarized information relevant to proficiency testing of laboratories performing molecular tests, such as availability of control samples and method-specific proficiency testing. We summarized published studies of proficiency testing, with attention to factors identified in these studies as contributing to variation between laboratories and evidence for the impact of testing programs on performance.

Systematic reviews relevant to the questions were given highest priority followed by other publication types, including evaluation studies. Recent narrative reviews and an interview with a CLIA staff member (see the method section of Chapter 4) were utilized, as necessary, to address questions not covered by systematic reviews or primary studies. Meeting abstracts, Web-based publications, and other “gray literature” were also searched when published literature was not available to address the questions.

## Results

### Published Studies

A proficiency testing program is an essential component of external quality assurance. The organizer of the program routinely sends samples to participating laboratories, which test the samples and return results to the organizer. The organizer uses the results to monitor and improve the performance of the participating laboratories.

We identified 33 published studies of proficiency testing, and no systematic reviews of proficiency testing (Table 5). These studies will be discussed throughout this section. For full details of the published studies, refer to Table 33 and Table 34 in Appendix C.

Table 5 Overview of Published Studies of Proficiency Testing

Type of Publication | Test Type(s) | Number of Publications Identified | References
Systematic review | Any | 0
Reports of proficiency test programs | FISH | 4 | 111–114
Reports of proficiency test programs | PCR, general | 6 | 115–120
Reports of proficiency test programs | PCR, infectious diseases | 16 | 121–136
Reports of proficiency test programs | PCR, oncology | 3 | 137–139
Reports of proficiency test programs | DNA sequencing | 4 | 140–143

### Control Materials

The National Institute of Standards and Technology (NIST) and the World Health Organization (WHO) both create, validate, and distribute primary standards for diagnostic assays. Primary standards are held by an independent organization and are reference materials that have been qualified at the highest level. Primary standards for molecular tests are, however, rare. WHO has developed primary standards only for hepatitis B, hepatitis C, and HIV, and the coagulation disorder caused by the Factor V Leiden mutation.29, 30 The only primary standards for molecular tests that NIST has developed are three standards for use in forensic and paternity testing and one standard for fragile X assays (www.nist.gov).22 However, these tests are beyond the scope of this report.

Laboratories must be able to obtain controls, validation specimens, and proficiency test materials for molecular tests. Controls preferably have been validated against a primary standard, but for molecular testing this may not be possible. Sources of control materials may include commercially available organisms and nucleic acid samples; previously tested and stored patient specimens or their derivatives; inter-laboratory exchanges; materials distributed by proficiency testing surveys; or publicly available collections such as the American Type Culture Collection (www.atcc.org) and the Coriell Cell Repositories (http://ccr.coriell.org).

#### What Programs Exist to Provide Human Mutation Samples or Synthetic Samples for Use as Controls?

Published studies of proficiency programs are summarized in Table 6. Of the materials distributed, nine used actual patient specimens; 14 used cultured bacteria or viruses; four used cell cultures; one used cultured cells infected with viruses; and seven used artificial samples (plasmids or patient specimens spiked with the target materials). These numbers do not add up to 33 because some proficiency testing programs distributed more than one type of material.

Table 6 Sources of Control Materials in Published Proficiency Testing Programs

Source | Number of Publications Identified | References
CAP | 4 | 112–114,137
EMQN | 1 | 142
ENVID | 1 | 122
EQAP | 2 | 138,139
EQUAL | 9 | 115,116,126–130,140,141
INQAT | 2 | 117,119
NEQUAS | 2 | 111,121
Reference laboratories | 12 | 118,120,123–125,131–136,143

CAP College of American Pathologists

EMQN European Molecular Genetics Quality Network

ENVID European Network for Diagnostics of Imported Viral Diseases

EQAP Spanish external quality assessment program

EQUAL European Union Quality Control Concerted Action (now referred to as the Quality Control for Molecular Diagnostics, or QCMD)

INQAT Italian Network for Quality Assurance of Tumor Biomarkers

NEQAS National Quality Assessment Scheme (UK)

The Centers for Disease Control (CDC) organized two workshops in 2003 and 2004 to discuss needs for control materials and to develop recommendations to fulfill these needs.23 As a consequence of these workshops, the CDC established the Genetic Testing Reference Materials Coordination Program (Ge T-RM), formerly known as the Genetic Testing Quality Controls Materials Program (GTQC) (http://wwwn.cdc.gov/dls/genetics/rmmaterials/default.aspx). This repository currently has only a limited number of control materials available, but plans to gradually expand in scope. The CDC is also funding efforts to develop synthetic samples that can be used in place of actual patient specimens.144

In addition, Qnostics currently sells proficiency testing material used in previous Quality Control for Molecular Diagnostics (QCMD) proficiency testing surveys (www.qnostics.com/QCMDPanels.htm).

#### To What Extent do Laboratories Exchange Samples Voluntarily for the Purpose of Proficiency Testing?

Our search of peer-reviewed journals and gray literature sources did not identify any studies (e.g., surveys) that provide sufficient information for us to make an estimation of the extent to which laboratories exchange samples voluntarily for PTs.

#### What Method-specific Proficiency Tests Have Been Developed?

The characteristics of the proficiency testing programs in the 33 published studies we identified are summarized in Table 7. The majority of the programs were intended to test the ability of the laboratory to identify or quantify a particular target gene or organism, using their own ASRs and laboratory-developed testing protocols. Some of the general-method programs did provide analyte-specific reagents (PCR primers) as part of the proficiency test.

Table 7 Published Proficiency Testing Programs

Type of Program | Number of Publications Identified | References
FISH, general | 1 | 114
FISH, specific target | 3 | 111–113
FISH, analyte-specific | 0
PCR, general | 6 | 115–120
PCR, specific target | 19 | 121–139
PCR, analyte-specific | 0
DNA sequencing, general | 3 | 140–142
DNA sequencing, specific target | 1 | 143
DNA sequencing, analyte-specific | 0

### What Organizations or Programs are Implementing Proficiency Testing Programs for Molecular Tests, and What Standards have these Programs Established?

Under CLIA, each laboratory performing nonwaived testing must enroll in one CMS-approved proficiency testing (PT) program for each specialty, subspecialty, and analyte specified in Subpart I of the CLIA regulations (refer to Chapter 4 of the report). For tests that are not associated with any specialty, subspecialty, and analyte specified in Subpart I (e.g., molecular tests), laboratories are still required to participate in some equivalent activity such as exchanges of materials with other laboratories. Refer to the relevant sections in Chapter 5 and the CLIA regulations (42 CFR 493.1236(c)) for additional information.

In a recent overview of laboratory proficiency testing prepared for the Centers for Disease Control and Prevention, Peterson et al. recommended developing methods-based proficiency testing programs, rather than specific test-based proficiency testing programs, as the most practical way to address proficiency testing for molecular tests.145

In their recent report, the Secretary’s Advisory Committee on Genetic, Health, and Society (SACGHS) recommended that studies of the effectiveness of other types of performance assessment methods be conducted to determine whether they are as robust as proficiency testing.3

#### College of American Pathologists

The College of American Pathologists (CAP) and the American College of Medical Genetics (ACMG) jointly administer a proficiency testing scheme (www.cap.org). In 2005, 285 laboratories within the U.S. and 52 from other countries participated in the program. Samples are sent out twice a year with three to five specimens per test in each shipment. The majority of the 17 currently available molecular tests involve testing for germline mutations (important for the pediatric population or prospective parents), which are beyond the scope of this Horizon Scan. The specimens typically consist of purified DNA or metaphase slide preparations, which omits the steps necessary for evaluating a laboratory’s sample preparation competency. Reports are returned on a standardized form instead of in the laboratory’s usual report format.

A laboratory that correctly tests 80% or more of the samples is graded as “acceptable.” Laboratories that fail to achieve a satisfactory performance on three or four successive tests may be required to discontinue testing until the problem is corrected and verified to be corrected by successful completion of an external proficiency test.

#### CLIA-exempt States

Laboratories performing testing on New York State citizens are required to establish their proficiency twice a year (www.wadsworth.org/labcert/clep/clep.html). For tests with no available New York State proficiency test (e.g., most molecular tests) the laboratory itself is required to set up an internal proficiency testing program that may include split-sample performance compared to another validated method, evaluation of clinical outcomes, blind testing of specimens with known results, or other equivalent system. In 2008, CLEP planned to send out several virology proficiency testing panels that may be applicable to molecular diagnostics (www.wadsworth.org/labcert/clep/PT/PTschedule.htm).

Washington State does not itself provide a proficiency testing program, rather, they require proficiency testing be performed as specified by CLIA, and use the proficiency testing programs organized by CAP for monitoring molecular tests (www.doh.wa.gov/hsqa/FSL/lqa_PT_providers.htm).

#### Programs in Europe

##### Quality Control for Molecular Diagnostics

Quality Control for Molecular Diagnostics (QCMD), previously known as the European Union Quality Control Concerted Action (EQUAL), designs and develops quality control materials and proficiency testing programs. In 2008, they offered 29 proficiency testing panels for various infectious diseases (www.qcmd.org). Summary reports from all of their past proficiency tests are available at http://www.qcmd.org/Index2.htm.

##### European Molecular Genetics Quality Network

The European Molecular Genetics Quality Network (EMQN) also operates proficiency testing schemes in Europe (www.emqn.org). The program is voluntary and any laboratory may register and participate. Samples are distributed annually. In 2007, 18 disease-specific proficiency tests and two technique-specific tests (mutation scanning and DNA sequencing) were offered. The majority of the disease-specific tests involve testing the pediatric population or prospective parents for germline mutations. For each test, three samples of purified DNA set within the context of a mock clinical case are sent to each participating laboratory. Laboratory reports are returned to the organizer. Laboratories that are scored as poor performers are contacted informally and offered advice on how to improve performance.

##### National Quality Assessment Scheme

The National Quality Assessment Scheme (NEQAS) for molecular genetics operates proficiency testing programs in the United Kingdom, the Netherlands, and Ireland (www.ukneqas.org.uk). Approximately 40 laboratories participate in the testing scheme each year. The intent of the program is to assess not only the proficiency of the laboratories in genotyping, but also their ability to interpret the results in the context of a realistic clinical scenario. The main function of the organizer is to inform participating laboratories when their performance falls below acceptable levels, and to offer advice and assistance to ensure the laboratory’s performance returns to an acceptable level. NEQAS currently offers testing material for 15 different tests. Some tests involve testing the pediatric population or prospective parents for germline mutations and others are for adult onset heritable conditions, infectious disease, and HLA typing. NEQAS has recently begun offering proficiency testing for FISH assays for ERBB2 (i.e., HER-2/neu) status in breast cancer;111 determination of ERBB2 status in breast cancer may be important for clinical decisions about treatment.

Samples (generally purified DNA) are distributed annually. For each disease, each participating laboratory receives three samples set within the context of a realistic clinical scenario. Performance levels are scored for each individual disease, rather than on an average score across all disease areas. A single significant genotyping error is enough to result in the designation of poor performance. If the laboratory report contains advice which is considered to be dangerously erroneous, the laboratory will also be scored as a poor performer. Non-participation in any available test is also scored as poor performance. Persistent poor performance is defined as poor performance for a particular disease in two consecutive years or poor performance in three out of six years.

##### European Network for Diagnostics of Imported Viral Diseases

The European Network for Diagnostics of Imported Viral Diseases (ENVID) is an organization devoted to diagnostics of “imported,” rare and emerging viral infections of European interest. They organize limited proficiency testing programs and encourage exchange of testing materials between laboratories and the development of standardized testing methods (www.enivd.de/manifest.htm).

##### Italian Network for Quality Assurance of Tumor Biomarkers

The Italian Network for Quality Assurance of Tumor Biomarkers (INQAT) operates proficiency testing programs for tumor biomarkers in Italy (http://www.oncologico.bari.it/).

#### Program in Australia

The Human Genetics Society of Australia coordinates a proficiency testing program for molecular genetics (www.hgsa.com.au/Index.cfm?pid=111713).

### What Proficiency Test Results for Molecular Testing have been Published by the Identified Testing Organizations?

The published results of proficiency testing performed by formal proficiency testing organizations are briefly summarized in Table 8. For full details of the reported results, refer to Table 33 and Table 34 in Appendix C.

Table 8 Published Proficiency Test Results of Formal Testing Programs

Organization | Test Program | Number of Surveys Performed | Results | References
CAP | FISH to detect amplification of ERBB2 (i.e., HER-2/neu) | 5 | 94 to 100% of all results were correct | 112,113
CAP | FISH in general | 7 | 85 to 100% of all results were correct | 114
CAP | PCR-based detection of genetic alterations relevant to oncology | 8 | 91 to 94% of all results were correct | 137
EMQN | DNA sequencing | 1 | 59% of laboratories were rated “excellent” | 142
ENVID | PCR-based detection and typing of viruses | 1 | 80 to 85% of all results were correct | 122
EQAP | PCR-based detection of genetic alterations relevant to oncology | 7 | 90% of all results were correct | 138,139
EQUAL | PCR in general | 2 | 73 to 80% of laboratories performed acceptably | 115,116
EQUAL | PCR-based detection and typing of viruses | 8 | 28 to 98% of all results were correct | 126–130
EQUAL | DNA sequencing | 2 | There was considerable variation in the returned results. A training program resulted in a significant improvement in proficiency | 140,141
INQAT | PCR in general | 2 | 44 to 61% of laboratories were rated as “excellent” or “good” | 117,119
NEQAS | FISH to detect amplification of ERBB2 (HER-2/neu) | 1 | 60% of all results were “acceptable” | 111
NEQAS | PCR-based detection and typing of viruses | 1 | 87 to 100% of all results were correct | 121

CAP College of American Pathologists

EMQN European Molecular Genetics Quality Network

ENVID European Network for Diagnostics of Imported Viral Diseases

EQAP Spanish external quality assessment program

EQUAL European Union Quality Control Concerted Action (now referred to as the Quality Control for Molecular Diagnostics, or QCMD)

INQAT Italian Network for Quality Assurance of Tumor Biomarkers

NEQAS National Quality Assessment Scheme (UK)

### What Factors have been Identified Which Contribute to Variability Within and Across Laboratories Performing Molecular Testing?

Factors reported to contribute (or not contribute) to molecular testing performance variability between and within laboratories are summarized in Table 9. Note that many studies did not explicitly define factors they had examined that were found not to contribute to such variability. Most of the published studies of proficiency testing reported that they were unable to determine causes of variability in the results.

The factor most commonly reported to have caused variability in results was the use of testing material that had very low levels of the target (i.e., genetic analytes of interest). FISH testing programs reported that the use of a low-level amplification sample caused close to 100% of errors.111, 112

Many of the authors of the published proficiency test programs commented that although laboratories used a wide variety of methods, most were able to correctly perform the proficiency tests. The overall performance of the laboratory was not dependent on the methodology chosen; high-quality results instead seem to be dependent on the laboratory’s internal quality control and optimization of the assay used.

Table 9 Reported Factors that Contributed to Molecular Testing Variability

Factor | Number of Studies Reporting it Contributed to Variability in Results | Number of Studies Reporting it Reduced Variability in Results | Number of Studies Reporting it Did Not Affect the Variability of Results
Use of commercial assay kits | 1 128 | 3 122,124,135 | 1 125
Use of laboratory-developed assays | 2 122,124 | 1 128 | 1 125
Use of commercial DNA preparation kits | 1 120 | 0 | 1 122
Use of laboratory-developed DNA preparation methods | 0 | 1 120 | 0
Samples with very low levels of the test target | 12 111,112,121,123,125–128,135,136,138,139 | 0 | 0
Laboratory experience with the test | 0 | 1 141 | 3 114,118,143
Laboratory had a good quality control plan in place | 0 | 2 114,123 | 0
Staff proficiency in testing | 0 | 1 129 | 0
Use of non-optimal DNA extraction methods | 2 115,119 | 0 | 0
Use of non-optimal reagents | 3 115,119,120 | 0 | 0
Use of non-optimal PCR parameters | 5 115,119,120,122,139 | 0 | 0
Use of different PCR primers | 2 131,133 | 0 | 5 123,129,132,133,137
Use of different PCR platforms | 1 117 | 0 | 6 116,123,129,132,133,137

#### Do FDA-reviewed Tests Perform Better than Laboratory-developed Tests for the Same Clinical Intended Use?

Two of the published studies reported that the use of FDA-approved commercially available tests reduced variability in the results,122, 124 but one reported that the use of FDA-approved tests actually increased variability in comparison to the use of LDMTs,128 and one reported that it did not affect the results.125 The authors of one study commented that many of the commercially available FDA-approved tests were not sensitive enough to detect clinically relevant but low viral copy levels that many of the in-house assays were able to detect.128 Braun et al. reported that the quality of DNA prepared using commercially available kits was, on average, lower than the DNA prepared by in-house-developed methods.120

#### Extent of Analytical Validation of the Test

None of the published studies provided information about the extent and quality of analytical validation of the tests being used by the participating laboratories. Authors of nine of the published studies speculated that the use of non-optimal testing methods by some laboratories may have contributed to the variability across laboratories (see Table 9).

#### Test Methodology

In general, proficiency testing demonstrated that FISH tests were rarely performed incorrectly (Table 8). Results for PCR-based tests varied across proficiency testing programs. Proficiency tests that required laboratories to extract DNA before performing PCR generally reported more variation in results than test programs that provided purified DNA.

#### Personnel

None of the published proficiency testing programs commented on personnel employed by the participating laboratories.

McGovern et al. surveyed 133 laboratories and assigned quality scores based on how the laboratory scored on a checklist of common laboratory practices thought to contribute to high quality performance.146 They reported that higher quality scores were associated with the directors of the laboratories having a MD degree vs. a PhD degree, and higher quality scores were also associated with the laboratory directors being board-certified in biochemical genetics.

#### Environmental Conditions

None of the published proficiency testing programs commented on environmental conditions (temperature, air quality, etc.) in the participating laboratories.

### Based on Published Studies, What Impact have these Proficiency Testing Programs had on Reducing Variation Within and Between Laboratories?

We identified several published studies that addressed the impact of proficiency testing on reducing variability of testing. In one study, Niedrig and colleagues reported that the proficiency of 33 laboratories in using PCR to detect and identify viruses was not significantly improved since the first survey conducted by the European Network for Diagnostics of Imported Viral Diseases (ENIVD).122 In another study, Mascarello et al. reported that the proficiency of approximately 130 laboratories in performing FISH tests improved from 1997 to 2000, and the CTLN reported that the proficiency of 12 laboratories in performing PCR tests improved from 2000 to 2002, but it is unclear if the improvements were due to repeated proficiency tests, improvements in technology, or simply greater experience on the part of the laboratories in performing the tests.114, 134 Wang et al. reported that the accuracy of the laboratories improved over the five years after establishment of the proficiency testing program, but the authors of the report attributed the improvement to the development of higher-quality commercial testing kits, not the proficiency testing program.135 Other published studies reported no significant changes in laboratory proficiency upon repeated proficiency testing.113, 126-128

As part of the EQUAL program, Dorn-Beineke reported the impact of a training program on proficiency. Eight laboratories that had performed poorly in a DNA sequencing proficiency test were invited to participate in a three-day training program. Six of the eight participated, and their proficiency scores significantly improved.140

### What Data are Available from the Accrediting Organizations on the Impact of Proficiency Testing Programs on Laboratory Performance?

NEQAS reports that poor performance on their proficiency tests is a sporadic event with a low incidence of recurrence. Identified causes of errors include accidental sample swapping, clerical or interpretive errors, and problems with test analytic validity. Since 1997, NEQAS has identified a single incident of persistent poor performance. The laboratory’s analytical errors were reviewed and corrected to the satisfaction of all concerned.147