# What Is the Role of Other Federal Agencies in Regulating Marketing Claims Regarding the Clinical Validity and Utility of Laboratory-Developed Tests Not Currently Being Actively Regulated by FDA?

This chapter addresses Key Question 6. For this question, we were asked to examine the role of other Federal agencies in regulating marketing claims regarding the clinical validity and utility of laboratory-developed tests not currently being actively regulated by FDA.

## Methods

To address this question, we included information from the Federal Register and other sources of Federal guidance documents. We also performed a literature search of MEDLINE and other suitable databases containing primary literature relevant to this question (Appendix A). We further discussed the results of our literature search with Dr. Steve Gutman while he was Director of the Office of In-Vitro Diagnostic Device Evaluation and Safety of the FDA, to confirm that we had identified the relevant sources.

## Results

Our literature search and interview with Dr. Gutman identified that, in addition to FDA, the U.S. Federal Trade Commission (FTC) may play a role in regulating marketing claims regarding the clinical validity and utility of LDMTs. No other government agencies were identified.

Regulation of marketing claims regarding the clinical performance of medical devices involves oversight of both labeling and advertising. Device labeling covers a broad category of materials including brochures, mailings, journal reprints if distributed by (or on behalf of) a company, sales materials, package inserts, and immediate package label. Advertising is not defined in the Food, Drug and Cosmetic Act. However, the Center for Drug Evaluation and Research of FDA has a technical definition of advertisement, which includes all ads in published journals and magazines, other periodicals and broadcast ads.107

Currently, both FDA and FTC play a role in regulating marketing claims of medical devices. According to a FTC-FDA Memorandum of Understanding in 1971,^108^ FDA has primary jurisdiction over advertising of prescription drugs and of restricted devices—i.e., the devices whose sale, distribution or use is restricted by FDA-approval order or by regulation—and over labeling of all products. FTC has primary jurisdiction over advertising of non-restricted devices and of over-the-counter (OTC) drugs. One potential loophole in this two-agency regulation system is the marketing of products on the Internet. FDA and FTC have not clearly defined Internet promotion as labeling or advertising. However, FDA may soon take steps to address this issue. Recently, FDA announced that, in November 2009, the agency would hold a public hearing on the promotion of drugs and medical devices on the Internet and other new media tools.109

Under this FTC-FDA regulation framework, both Agencies theoretically have a role in overseeing marketing claims regarding the performance of LDMTs. The oversight of LDMT labeling is under FDA’s jurisdiction. The oversight of advertising regarding LDMTs is also under FDA’s jurisdiction if the sale, distribution or use of the LDMTs is restricted by FDA-approval order or by regulation—i.e., these LDMTs are restricted devices. For non-restricted LDMTs, FTC assumes the primary responsibility in the oversight of advertising.

FTC can also take actions against providers of unrestricted LDMTs (i.e., the devices whose sale, distribution or use is not restricted by FDA-approval order or by regulation), when these providers’ advertisements make false or misleading claims regarding the clinical performance of LDMTs. Almost all LDMTs can currently be viewed as non-restricted devices. However, the fact that FDA exercises the oversight discretion on LDMTs affects FTC’s ability to act against false and misleading advertising regarding such tests, because FTC often uses FDA’s labeling requirements as guidance regarding whether a claim is false or misleading.110 Figure 1 is a depiction of the roles played by FTC and FDA in oversight of medical device marketing claims.

Figure 1 Oversight of Medical Device Marketing Claims

Figure 1 is a two-by-two matrix depicting how the two federal agencies, the FDA and the FTC, split the responsibility in the oversight of medical device marketing claims. There are four panels in the matrix, representing the four areas that are regulated: the labeling of restricted devices, the labeling of non-restricted devices, the advertising of restricted devices, and the advertising of non-restricted devices. The matrix shows the following: the FDA is in charge of the labeling of restricted devices; the FDA is in charge of the labeling of non-restricted devices; the FDA is in charge of the advertising of restricted devices, and; the FTC is in charge of the advertising of non-restricted devices.