# What FDA Guidance Has Been Issued Pertaining to Oversight of Laboratory-Developed Molecular Testing?

In this chapter we address the following Key Question 5: What FDA guidance has been issued pertaining to oversight of in-house molecular testing?

## Methods

To address this question, we searched the FDA’s online database containing the guidance documents published by the Agency. We further interviewed Dr. Steve Gutman, former Director of the Office of In-Vitro Diagnostic Device Evaluation and Safety of the FDA, to discuss the oversight of molecular tests by the Agency and verify the accuracy of the guidance documents list that we had generated based on the information from the FDA Web site.

## Results

We identified two FDA guidance documents relevant to laboratory-developed molecular tests (LDMTs). These two documents—one guidance for analyte specific reagents (ASRs) and a draft guidance for in-vitro diagnostic multivariate index assays (IVDMIAs)—address the oversight of laboratory-developed tests (LDTs) and are applicable to LDMTs. In addition, we identified several FDA guidance documents regarding commercially distributed genetic testing systems, which are not directly applicable to LDMTs but provide useful information on how the FDA assesses the performance of molecular tests.

### FDA Guidance for ASRs

On September 14, 2007, FDA issued a guidance document for industry and FDA staff to clarify the regulations regarding commercially distributed ASRs.33 The ASR guidance document clarified that ASRs are medical devices that are regulated by FDA. Most ASRs are classified as Class I devices subject to general controls, but exempt from premarket notification requirements.

FDA defines ASRs as “antibodies, both polyclonal and monoclonal, specific receptor proteins, ligands, nucleic acid sequences, and similar reagents which, through specific binding or chemical reactions with substances in a specimen, are intended for use in a diagnostic application for identification and quantification of an individual chemical substance or ligand in biological specimens.” In the guidance document, FDA provided some molecular test-related ASR examples. These examples include single forward/reverse oligonucleotide primers and nucleic acid probes intended to bind a single complementary amplified or unamplified nucleic acid sequence, if these reagents are marketed without clinical or analytical performance claims. FDA also provided examples of reagents not considered as ASRs, such as products that include more than a single ASR, control materials or calibrators, microarrays, and products with specific performance claims, interpretation for use, or software for interpretation of results.

The ASR guidance allows only physicians and other persons authorized by applicable State law to order LDTs that are developed using ASRs. The guidance requires the laboratory that develops an LDT using an ASR to add a statement disclosing that the laboratory developed the test and it has not been cleared or approved by FDA when reporting the test result to the practitioner. The ASR guidance also prohibits advertising and promotional materials for ASRs from making any claims for clinical or analytical performance. Manufacturers who wish to make analytical and/or clinical performance claims for a product must submit an application to FDA for premarket review rather than marketing the product as an ASR.

### FDA Draft Guidance for IVDMIAs

On July 26, 2007, FDA published a draft guidance document on IVDMIAs for industry, clinical laboratories, and the FDA staff.93 In the document, FDA defined an IVDMIA as a device that:

- Combines the values of multiple variables using an interpretation function to yield a single, patient-specific result (e.g., a “classification,” “score,” “index,” etc.), that is intended for use in the diagnosis of disease or other conditions, or in the cure, mitigation, treatment or prevention of disease, and
- Provides a result whose derivation is non-transparent and cannot be independently derived or verified by the end user.

By this definition, some LDMTs will fall into the category of IVDMIA. The examples of IVDMIA listed in the FDA guidance document include a gene expression profiling assay for breast cancer diagnosis, a device that integrates quantitative results from multiple immunoassays to obtain a qualitative “score” that predicts a person’s risk of developing a disease or condition, and a device that integrates a patient’s age, sex, and genotype of multiple genes to predict risk of or diagnose a disease or condition. FDA would not consider devices with a function that simply facilitates the interpretation of multiple variables that health care practitioners could otherwise interpret themselves to be IVDMIAs.

FDA believes that most IVDMIAs—either as commercial kits or in-house testing systems—will be Class II or III device and, therefore, will require a 510(k) clearance or PMA before being marketed. Like other in-vitro devices (IVDs), IVDMIAs are subject to FDA’s labeling and postmarket requirements, and can be used as investigational devices or humanitarian use devices if they meet certain conditions. Based on the proposed guidance, for a LDMT that qualifies as an IVDMIA, a developer will need to submit data to back up the claims regarding analytical and clinical performance.

Note that the FDA’s IVDMIA Draft Guidance is not a finalized document. As such, this draft guidance only represents FDA’s current thinking on this topic. FDA’s oversight of these devices has not yet been implemented or articulated in a final guidance document.

### FDA Guidance for Commercial Kits or Testing Materials

FDA has so far issued a series of guidance documents for commercially distributed genetic testing kits. These documents do not address the oversight of LDMT and some of them pertain to heritable conditions, which are not within the scope of our report. However, these documents are relevant to the report because they describe how FDA assesses the safety and performance of molecular tests, particularly in the domains of pre-analytical factors, quality control, analytical performance, and clinical validation. Table 4 is a list of these guidance documents for further reference.

Table 4 Published FDA Guidance Documents Related to Molecular Test Kits or Materials

Title | Date of Issuance
Guidance for industry: In the manufacture and clinical evaluation of In Vitro tests to detect nucleic acid sequences of human immunodeficiency viruses types 1 and 2^94^ | December 1999
Guidance for Industry and FDA staff: Replacement Reagent and Instrument Family Policy95 | December 11, 2003
Guidance for Industry and FDA staff: Class II Special Controls Guidance Document: factor V Leiden DNA mutation detection systems96 | March 16, 2004
Guidance for Industry and FDA staff: Class II Special Controls Guidance Document: Drug Metabolizing Enzyme Genotyping System97 | March 10, 2005
Guidance for Industry and FDA staff: Class II Special Controls Guidance Document: Instrumentation for Clinical Multiplex Test Systems98 | March 10, 2005
Guidance for Industry and FDA staff: Class II Special Controls Guidance Document: Automated Fluorescence in situ Hybridization (FISH) Enumeration Systems99 | March 23, 2005
Guidance for Industry and FDA staff: Class II Special Controls Guidance Document: RNA Preanalytical Systems (RNA Collection, Stabilization and Purification Systems for RT-PCR used in Molecular Diagnostic Testing)100 | August 25, 2005
Guidance for Industry and FDA staff: Class II Special Controls Guidance Document: CFTR Gene Mutation Detection Systems101 | October 26, 2005
Draft guidance for industry and FDA staff: Nucleic Acid Based In Vitro Diagnostic Devices for Detection of Microbial Pathogens (Draft)102 | December 8, 2005
Guidance for industry and FDA staff: Class II Special Controls Guidance Document: Quality Control Material for Cystic Fibrosis Nucleic Acid Assays103 | January 10, 2007
Guidance for industry and FDA staff: Class II Special Controls Guidance Document: Class II Special Controls Guidance Document: Gene Expression Profiling Test System for Breast Cancer Prognosis104 | May 9, 2007
Guidance for industry and FDA staff: Pharmacogenetic Tests and Genetic Tests for Heritable Markers105 | June 19, 2007
Guidance for Industry and FDA Staff: Class II Special Controls Guidance Document: Nucleic Acid Amplification Assay for the Detection of Enterovirus RNA106 | January 2, 2009