# How Does CLIA Regulate Molecular Testing?

In this chapter, we address how CLIA regulates molecular testing. For this Key Question, we were asked to look at the following aspects of the CLIA regulation:

- Survey components relevant to molecular testing,
- Quality control requirements,
- Proficiency testing,
- Visibility of test claims (labeling),
- Transparency of data used to support test performance, and
- Handling of complaints or unexpected events.

## Method

For this question, we reviewed the CLIA regulations and associated guidance documents posted on the Web sites of the CLIA program, FDA, and the Centers for Disease Control and Prevention (CDC). We summarized the information from the current CLIA regulations84 and the guidance documents published on the Web site of the CLIA program.85 We also interviewed Penny (Mattingly) Meyers, MA, MT(ASCP)SBB, a staff member in the Centers for Medicare and Medicaid Services (CMS) Division of Laboratory Services of the CLIA program, to discuss CLIA’s oversight of molecular tests and verify the accuracy of the summary that we had generated from the CLIA regulations and the guidance documents.

## Results

### CLIA in Brief

In response to public concerns about the quality of laboratory testing, Congress passed the Clinical Laboratories Improvement Amendments (CLIA) Act in 1988. The goal of this Act was to establish overall quality standards to ensure accuracy, reliability, and timeliness of patient test results regardless of where the test was performed. The final CLIA regulations were published in 1992 and received a major update in 2003. CMS currently assumes primary responsibility for the management of the CLIA program.

Under the CLIA regulations, all facilities that perform tests on “materials derived from the human body for the purpose of providing information for the diagnosis, prevention, or treatment of any disease or impairment of, or the assessment of the health of, human beings” are required to meet certain Federal requirements and must apply and obtain a certificate from the CLIA program. The requirements for CLIA certification are based on the complexity of the tests. FDA has assumed primary responsibility for assigning each test to one of the three CLIA complexity categories: waived tests, tests of moderate complexity and tests of high complexity. Under the CLIA regulation, tests may be waived from oversight if they meet certain requirements. Waived tests are defined as simple laboratory examinations and procedures that are cleared by the Food and Drug Administration (FDA) for home use; or that employ methodologies that are so simple and accurate as to render the likelihood of erroneous results negligible; or that pose no reasonable risk of harm to the patient if the test is performed incorrectly. Detailed criteria for categorizing a test as waived are listed in the CLIA regulations at 42 CFR 493.15(b) and 493.15(c), as well as on FDA’s Web site (http://www.fda.gov/MedicalDevices/DeviceRegulationandGuidance/IVDRegulatoryAssistance/ucm124208.htm, accessed on December 3, 2009).

There are currently five types of CLIA certificates: Certificate of Waiver (COW), Certificate for Provider Performed Microscopy (PPM) Procedures, Certificate of Registration (COR), Certificate of Compliance (COC) and Certificate of Accreditation (COA). COW is issued to a laboratory that performs only waived tests. A certificate for PPM Procedures is issued to a laboratory in which a physician, midlevel practitioner or dentist performs specific microscopy procedures during the course of a patient’s visit. A limited list of microscopy procedures is included under this certificate type and these are categorized as moderate complexity. Laboratories that have a COW or PPM certificate are not subject to routine CLIA surveys (inspections).

COC is issued to a laboratory that performs nonwaived (moderate and/or high complexity) testing once the State surveyor conducts a survey (inspection) and determines that the laboratory is compliant with all applicable CLIA requirements. A laboratory that performs nonwaived (moderate and/or high complexity) testing can also apply for a COA in lieu of COC if the laboratory is accredited by one of the six accreditation organizations approved by CMS (described later in this chapter). To obtain a COC or COA, a laboratory is required to undergo biennial surveys and must meet the CLIA quality standards for quality control (QC), proficiency testing (PT), quality assurance (QA), personnel qualifications, and specimen integrity/recordkeeping. (The requirements will be discussed in detail in the following sections).

Certificate of Registration is issued to a laboratory that has applied for a COC or COA, but the survey has not been completed by the State Department of Health or the accrediting organization. The issuance of Certificate of Registration allows the laboratory to conduct nonwaived (moderate and/or high complexity) testing until the laboratory is surveyed and determined to be compliant with the CLIA regulations.

Under CLIA, clinical tests are categorized under different laboratory specialties (e.g., microbiology, hematology and pathology) and subspecialties (e.g., bacteriology, virology, histopathology and cytology). The specialties and subspecialties under which a laboratory can perform tests are specified on the COC or COA. A laboratory may need to meet additional requirements to be certified to perform tests under these specialties and subspecialties.

In addition, section 353(p) of the Public Health Service Act provides for the exemption of laboratories from the requirements of CLIA when the State in which they are located has requirements equal to or more stringent than those of CLIA. Currently, two States—Washington and New York—have CLIA-exempt status.86

### Molecular Testing Regulation under CLIA

Like any other clinical tests, molecular tests are subject to all general CLIA rules. Since molecular tests are normally categorized as either moderate or high complexity tests, a laboratory performing molecular tests is required to apply for and obtain a COC or a COA. Currently, there is no CLIA specialty or subspecialty for molecular or biochemical genetic testing. Therefore, there are no special personnel, quality control, or proficiency-testing requirements for molecular tests unless the laboratory voluntarily chooses a CMS-approved accrediting organization specifying additional requirements. In the following sections, the general CLIA requirements applicable to molecular tests are described.

#### Survey Components Relevant to Molecular Testing

To obtain a COC or a COA to perform molecular tests, a laboratory is required to be surveyed (inspected) by a CLIA-authorized State agency (for COC) or an accrediting organization (for COA). All general survey components described below are applicable to molecular tests. We did not identify any molecular test-specific survey components. Unless specified otherwise, the content presented in this section is based on the document, Policy for Conducting Surveys, published on the CMS’s CLIA program Web site.87

Under CLIA, a laboratory may be surveyed for different reasons. To perform moderate/high complexity tests like molecular tests, a laboratory must first undergo an initial survey for certification (COC or COA), and then be surveyed biennially for recertification. The laboratory may also be surveyed for complaint (on an unannounced basis), follow-up, and/or validation (for those holding a COA).

The focus of CLIA surveys is to assess how a laboratory monitors its operations and ensures the quality of its testing. Each certification/recertification survey includes a tour of the facility, record review, observation, and interviews with personnel involved in the pre-analytic, analytic, and post-analytic phases of the testing process. The same survey guidelines and protocols published by CMS87 are used by the State agency surveyors to increase consistency in the survey process, although the professional judgments of the surveyors are also a critical element in the process.

Before or during a survey, the surveyors collect and review a large amount of information regarding the laboratory’s operation, personnel, quality control, quality assurance system, and proficiency testing (Table 2). During the survey, the surveyors will observe the laboratory’s physical layout, specimen collection and processing, and the working areas for preparation, testing, reporting, and storage. The focus of the observation is on specimen integrity, quality control performance, skills and knowledge of personnel regarding testing, adequacy of staffing for test volume, and interactions and communication among personnel. The surveyors also observe and verify that reagents, kits, and equipment correlate with the test menu, clients served, and results reported.

During the survey, surveyors may interview staff to confirm observations and obtain additional information, as necessary. Surveyors may also use the interviews as an opportunity to evaluate the laboratory personnel’s knowledge and skills for performing tests and identifying problems and the methods for corrective and remedial actions.

Table 2 Information Collected and Reviewed for CLIA Certification/Recertification Surveys

- Services offered—the list of tests and specialties/subspecialties; - Standard operating procedure manual with all test procedures (e.g., package inserts and supplemental information, as necessary); - Reference laboratory’s client services manual, if applicable; - Records of tests referred to other laboratories; - Personnel records, including diplomas, certificates, degrees, training and experience, continuing education, competency assessment, duties/responsibilities, and personnel changes; - Quality control records, including remedial action information, calibration and calibration verification records, statistical limits, and instrument maintenance and function checks records; - Proficiency testing (PT) reports, including test runs with PT results, direct printouts, and remedial actions for unsatisfactory results; - Quality system assessment plan and documentation; for each of the systems:; - Policies and procedures to monitor, assess, and correct identified problems; - Documentation of ongoing assessment activities, including review of the effectiveness of corrective actions taken, revision of policies and procedures to prevent recurrence of problems, and discussion of assessment reviews with staff; - Safety information; - Patient testing records including requisition (patient charts may be used), work records (direct printouts), and patient test reports (patient charts may be used)

#### Quality Control Requirements

Quality control (QC) consists of the procedures used to detect errors that occur due to test system failure, adverse environmental conditions and variance in operator performance, as well as the monitoring of the accuracy and precision of the test performance over time.88 Subpart K of the CLIA regulations defines the general quality system for nonwaived testing. Section 493.1256 particularly describes in detail the requirements for quality control procedures. Table 3 is a summary of the key QC requirements that a laboratory performing nonwaived tests (including molecular tests) must meet.

Table 3 Key Quality Control Requirements Relevant to Molecular Testing

- For each test system, the laboratory is responsible for having control procedures that monitor the accuracy and precision of the complete analytical process.(42 CFR 493.1256 (a)) The control procedures must:; - detect immediate errors that occur due to test system failure, adverse environmental conditions, and operator performance (42 CFR 493.1256 (c)(1)) and; - monitor over time the accuracy and precision of test performance that may be influenced by changes in test system performance and environmental conditions, and variance in operator performance. (42 CFR 493.1256 (c)(2)); - The laboratory must establish the number, type, and frequency of testing control materials using, if applicable, the performance specifications verified or established by the laboratory. (42 CFR 493.1256 (b)); - Each laboratory that introduces a test system not subject to FDA clearance or approval—including methods developed in-house—must, before reporting patient test results, establish for the test system the performance specifications for the following performance characteristics, as applicable:; - accuracy,; - precision,; - analytical sensitivity,; - analytical specificity to include interfering substances, reportable range of test results for the test system,; - reference intervals (normal values), and; - any other performance characteristic required for test performance. (42 CFR 493.1253 (b)(2)); - For test systems developed in-house, a laboratory must establish a maintenance protocol, and perform and document the maintenance activities, to ensure test system performance to produce accurate and reliable test results (42 CFR 493.1254 (b)).; - Each test system that has an extraction phase, include two control materials, including one that is capable of detecting errors in the extraction process. (42 CFR 493.1256 (d)(3)(iv)); - Each molecular amplification procedure, include two control materials and, if reaction inhibition is a significant source of false negative results, a control material capable of detecting the inhibition. (42 CFR 493.1256 (d)(3)(v))

#### Proficiency Testing

The information provided in this section is from Subparts H and I of the CLIA regulations, unless specified otherwise.

Under CLIA, each laboratory performing nonwaived testing (including molecular tests) must enroll in one CMS-approved proficiency testing (PT) program for each specialty, subspecialty, and analyte specified in Subpart I of the CLIA regulations. The purpose of PT is to externally evaluate the quality of a laboratory’s performance. A sample of (normally five) PT specimens are sent to the laboratories holding a COC three times a year.3 The PT survey specimens contain analytes known to the suppliers but not to the recipient laboratories. The sample specimens must be tested following the same procedures that the laboratory would use to test patient specimens. If a laboratory fails to perform successfully in a CMS-approved PT program, CMS may direct the laboratory to undertake personnel training or to obtain technical assistance, or it may impose various sanctions, including cancellation of Medicare/Medicaid reimbursement, suspension, limitation or revocation of the CLIA certificate.

Molecular tests are not listed in Subpart I, therefore laboratories are not required to participate in a formal PT program for molecular tests. (However, an accredited laboratory may still be required by the accreditation organization to participate in the available PT programs) Under CLIA, a subspecialty of clinical cytogenetics is established under the cytology specialty but this subspecialty is limited to chromosomal analysis and does not include molecular tests.89 Although laboratories can choose to enroll in other specialties (e.g., pathology), they are not required to do so. Meanwhile, no PT programs are mandated for the pathology specialty (except for the subspecialty of cytology, which is limited to gynecologic examinations) or for the clinical cytogenetics subspecialty under current regulations.

Nonetheless, although laboratories are not required to participate in a PT program for molecular tests, they are required by CLIA to establish and maintain the accuracy for the molecular tests that they perform. According to Section 93.1236 (c) of the CLIA regulations, at least twice annually laboratories must verify the accuracy of any test or procedure it performs for which participation in a CMS-approved PT program is not mandatory. To verify the accuracy of molecular tests, laboratories may use methods of their own choosing, which may include participation in a voluntary (i.e., not-CMS-approved) PT program and exchanging samples with other laboratories for cross-validation of test results. Laboratories are also required to document the activities of molecular test accuracy verification and make the data available for onsite survey.

#### Visibility of Test Claims (Labeling)

We did not identify any requirements in the CLIA regulations (including relevant guidance published by CMS) for laboratories to submit data to support claims of performance (analytic or clinical validity or clinical utility). However, there are requirements relevant to analytical and clinical performance. As described previously in Table 3, before reporting patient test results, each laboratory must have established for each laboratory-developed test system introduced after April 24, 2003, the performance specifications for accuracy, precision, analytical sensitivity, analytical specificity to include interfering substances, reportable range of test results for the test system, reference intervals (normal values), and any other applicable performance characteristic required for test performance (42 CFR 493.1253).

#### Transparency of Data Used to Support Test Performance

We identified requirements regarding transparency of data to support test performance in various sections of the CLIA regulations. According to the regulations, a laboratory must:

- Document all activities related to establishment and verification of performance specifications in accuracy, precision, analytical sensitivity, analytical specificity to include interfering substances, reportable range of test results for the test system, reference intervals (normal values), and any other performance characteristic required for test performance (42 CFR 493.1253(c)).
- Document all preanalytic (42 CFR 493.1249 (c)), analytic (42 CFR 493.1289(c)) and postanalytic (42 CFR 493.1299(c)) system assessment activities.
- Provide, upon request, all information and data needed by CMS or a CMS agent to make a determination of the laboratory’s compliance with the applicable requirements of the CLIA regulations (42 CFR 493.1773 (d)).

CMS may disclose accreditation organization inspection results to the public if the results are related to an enforcement action (42 CFR 493.571 (a)). CMS may also disclose the results of all inspections conducted by CMS or its agent (42 CFR 493.571(c)). Disclosure of State inspection results is the responsibility of the approved State licensure program, in accordance with State law (42 CFR 493.571 (b)).

#### Handling of Complaints

The findings presented in this section regarding how complaints are handled under CLIA are based on Subparts Q and R of the CLIA regulation.

A complaint against a laboratory is an allegation that could result in citing noncompliance with any of the CLIA requirements. Upon receiving a complaint, the CMS’s State Agency (SA) or regional office will start an investigation, regardless of the type of CLIA certificate the laboratory has or whether it is State-exempt. The investigation can be conducted by an unannounced onsite survey, by telephone, by electronic communication, by letter, or by a documentary review. If the complaint is substantiated, i.e., sufficient evidence is found to conclude that noncompliance exists at the time of the investigation, CMS will take subsequent actions against the laboratory depending on the severity and nature of the deficiencies cited and the facility’s willingness or ability to correct them. The various sanctions that CMS may impose on the laboratory include enforcement of a plan of correction (POC), State onsite monitoring, civil money penalty, loss of Medicare reimbursement, suspension, limitation or revocation of the CLIA certificate, and civil and criminal suits.

If the cited deficiencies pose immediate jeopardy, CMS requires the laboratory to take immediate action to remove the jeopardy and may impose one or more sanctions to help bring the laboratory into compliance. If the findings of a revisit indicate that the laboratory has not eliminated the jeopardy, CMS suspends, limits, or even revokes the laboratory’s CLIA certificate In addition, if CMS has reason to believe that the continuation of any activity by any laboratory (either the entire laboratory operation or any specialty or subspecialty of testing) would constitute a significant hazard to the public health, CMS may bring suit and seek a temporary injunction or restraining order against continuation of that activity by the laboratory.

If the laboratory has condition-level deficiencies—i.e., serious deficiencies in CLIA’s terminology—that do not pose immediate jeopardy, CMS may cancel the laboratory’s approval to receive Medicare payment for its services, suspend, limit, or revoke the laboratory’s CLIA certificate, or impose any other sanctions previously mentioned until a revisit indicates that the deficiencies have been corrected. However, if the laboratory has deficiencies that are not at the condition level—i.e., less serious deficiencies, it must submit a plan of correction that is acceptable to CMS in content and time frame. If it is found on a revisit that the laboratory has not corrected the deficiencies within 12 months after the last day of inspection, CMS cancels the laboratory’s approval to receive Medicare payment for its services and notifies the laboratory of its intent to suspend, limit, or revoke the laboratory’s CLIA certificate and of the laboratory’s right to a hearing.

In addition, according to 42 CFR 493.1233, each laboratory must have a system in place to ensure that it documents all complaints and problems reported to the laboratory. The laboratory must conduct investigations of complaints, when appropriate.

#### Clinical Validity or Utility of Laboratory Testing

The terms “clinical validity” and “clinical utility” are not explicitly mentioned in the CLIA regulations. However, we identified the following requirements in the regulations that might be interpreted by some stakeholders as the mechanisms to ensure clinical validity or utility of tests:

- The laboratory director must ensure that testing systems developed and used for each of the tests performed in the laboratory provide quality laboratory services for all aspects of test performance, which includes the preanalytic, analytic, and postanalytic phases of testing (42 CFR 493.1445(e)(1))
- The laboratory director must ensure that the test methodologies selected have the capability of providing the quality of results required for patient care. (42 CFR 493.1445(e)(3)(i)) The clinical consultant provides consultation regarding the appropriateness of the testing ordered and interpretation of test results. The clinical consultant must:
  a. Be available to provide clinical consultation to the laboratory’s clients;
  b. Be available to assist the laboratory’s clients in ensuring that appropriate tests are ordered to meet the clinical expectations;
  c. Ensure that reports of test results include pertinent information required for specific patient interpretation; and
  d. Ensure that consultation is available and communicated to the laboratory’s clients on matters related to the quality of the test results reported and their interpretation concerning specific patient conditions. (42 CFR 493.1419)

These requirements do not specify what types of data are appropriate for establishing clinical relevance of the tests, where the data should come from (e.g., from research carried out by the laboratory itself or from data reported in peer-reviewed literature), and how the data should be synthesized to reach conclusions.

In June 2009, the Clinical Laboratory Improvement Advisory Committee (CLIAC) Genetic Testing Good Laboratory Practices Workgroup published a report, providing a series of recommendations for ensuring quality of genetic testing for heritable diseases and conditions.4 The recommendations were made to CLIAC, an advisory entity that provides recommendations to the Department of Health and Human Services on approaches to ensuring the quality of genetic testing. Although genetic testing for heritable diseases or conditions is beyond the scope of this Horizon Scan, most of the recommendations that the Workgroup made on laboratory practice are relevant to the purpose of the report. The following are the Workgroup’s recommendations relevant to testing:

- Laboratories should ensure that the molecular genetic tests they perform are clinically usable and can be interpreted for specific patient situations. Laboratory responsibilities for clinical validity include the following:
  - Documenting information regarding clinical validity (including clinical sensitivity, clinical specificity, positive predictive value, and negative predictive value) of all genetic tests the laboratory performs from available information sources (e.g., published studies and professional practice guidelines)
  - Providing clinical validity information to users of laboratory services before tests are selected and specimens submitted
  - If clinical validity information is not available from published sources, establishing clinical sensitivity, clinical specificity, and predictive values on the basis of internal study results
  - Documenting whether the clinical claims in the references or information sources used can be reproduced in the laboratory and providing this information to users, including indicating test limitations in all test reports
  - Informing users of changes in clinical validity values as a result of knowledge advancement
  - Specifying that the responsibilities of the laboratory director and technical supervisor include ensuring appropriate documentation and reporting of clinical validity information for molecular genetic tests performed by the laboratory
- Directors of laboratories that perform molecular genetic testing for heritable diseases and conditions must fulfill the CLIA responsibility requirements. In addition, these laboratory directors should be responsible for the following:
  - Ensuring documentation of the clinical validity of any molecular genetic tests the laboratory performs, following the recommended practices
  - Ensuring the specimen retention policy is consistent with the laboratory quality assessment activities

#### The Role of Accreditation Organizations and Exempted States under CLIA

According to the CLIA regulations (42 CFR 493.551(a)), CMS may deem a laboratory to meet all applicable CLIA program requirements through accreditation by a private nonprofit accreditation program (that is, grant deemed status), or may exempt from CLIA program requirements all State-licensed or -approved laboratories in a State that has a State licensure program established by law, if the following conditions are met:

1. The requirements of the accreditation organization or State licensure program are equal to, or more stringent than, the CLIA condition-level requirements specified in this part, and the laboratory would meet the condition-level requirements if it were inspected against these requirements.
2. The accreditation program or the State licensure program meets the requirements of this subpart and is approved by CMS.
3. The laboratory authorizes the approved accreditation organization or State licensure program to release to CMS all records and information required and permits inspections as outlined in this part.

According to the CMS CLIA program (http://www.cms.hhs.gov/clia/), currently there are six CLIA-approved accreditation organizations, including AABB (formerly known as the American Association of Blood Banks), American Osteopathic Association (AOA), American Society of Histocompatibility and Immunogenetics (ASHI), COLA (formerly known as the Commission on Office Laboratory Accreditation), College of American Pathologists (CAP), and the Joint Commission. Based on the same source of information, two States—Washington and New York—currently have CLIA-exempt status.

These private organizations and exempted states play an important role under CLIA in ensuring the quality of laboratory testing, particularly molecular testing. For example, CAP requires laboratories in their Laboratory Accreditation Program to demonstrate the analytic validity of these tests as well as to document how they are clinically validated.90 CAP’s Laboratory Accreditation Program has a specialty inspectors list for molecular diagnostics. Inspectors are reviewed for qualifications in the four main areas of molecular testing— infectious disease, hematology/hematopathology, solid tumors, and heritable diseases—and selected on this basis.90 CAP’s accreditation program has established criteria specifically for molecular testing—including its Molecular Pathology Checklist—to ensure the quality of LDMTs and modified FDA kits.91 Working with other organizations, CAP has also established PTs for some molecular tests (discussed in Chapter 7).

As a CLIA-exempt State, New York has a unique regulatory process for laboratory testing. Under the State law, a laboratory must be pre-approved by the State if the laboratory intends to perform any testing on a New York resident, regardless of whether the laboratory is located within or outside of the State’s territory.3 Because of the law, many laboratory tests performed by reference laboratories from other States have been reviewed by the Clinical Laboratory Evaluation Program (CLEP) of New York State.3 CLEP’s review process requires laboratories to demonstrate that a test is validated both analytically and clinically prior to being introduced.92 CLEP also has some specific standards for molecular testing, including requirements for clinical information about test selection and interpretation, patient consent, confidentiality, specimen retention times, quality control procedures, method documentation, and retention of records.92