# What Processes Have Been Developed for Examining Clinical Validity and Clinical Utility of Molecular Tests?

This chapter of the report addresses Key Question 3, which focuses on existing processes for examining the clinical validity and clinical utility of molecular tests. Particularly, we were asked to examine the features unique to molecular testing in the following areas:

- Clinical validity: Test characteristics (sensitivity, specificity, predictive values, likelihood ratios)
- Clinical utility: whether the results of the test can be used to pursue effective treatment or provide other concrete clinical benefit

## Methods

To address this Key Question, we first provide an overview of the processes used to establish the clinical validity and utility of a molecular test. We further discuss the unique challenges in assessing clinical validity and utility of molecular tests. The overview and the discussion are based on the literature we considered relevant to the topic; both reviews and clinical studies are included in this discussion.

To examine the clinical test properties of molecular tests, we also consulted systematic reviews that evaluated clinical validity and/or clinical utility of various molecular tests. For clinical validity, we examined systematic reviews that reported on test characteristics, such as sensitivity, specificity, predictive values, and likelihood ratios. For clinical utility, we considered reviews that reported on patient-oriented health outcomes, such as survival, recurrence of disease, and treatment changes. The literature search strategies for this Key Question are provided in Appendix A of the report.

Quality of the systematic reviews was assessed with the ‘assessment of multiple systematic reviews’ (AMSTAR) measurement tool (Table 29).52 The AMSTAR consists of 11 items, which have been tested for face and content validity. The items assess whether or not a systematic review includes important elements, such as a comprehensive literature search, assessment of study quality, appropriate methods to combine study findings, and assessment of publication bias. Responses to each item are checked as ‘Yes’ if the review includes that item, ‘No’ if it does not, ‘CA’ if the item cannot be answered by the information provided in the review, or ‘NA’ if the item is not applicable. The AMSTAR does not provide a method for rating the quality of a review. To rate the quality of the reviews, we applied the following criteria: a rating of ‘High’ if the review received mostly ‘yes’ responses (at least 8), a rating of ‘Low’ if the review received mostly ‘no’ responses, and a rating of ‘Moderate’ if the review received mixed responses.

## Results

### Assessing Clinical Validity of Molecular Tests

The clinical validity of a molecular test refers to the test’s ability to detect or exclude a disease or a condition in patients compared with a criterion standard or reference test. The methods used to evaluate the clinical validity of molecular tests are similar to those used for any other diagnostic test, which include measuring the following test characteristics: sensitivity, specificity, predictive values, and likelihood ratios.

Sensitivity is the probability of a positive test result when disease is present. Specificity, on the other hand, is the probability of a negative test result when disease is absent. The acceptable levels for clinical sensitivity and specificity may vary depending on the purpose for which a test is used. While sensitivity and specificity are the most widely used outcome measures, they are sensitive to spectrum bias. Spectrum bias may occur when the study population has a different clinical spectrum (more advanced cases, for instance) than the population in whom the test is to be applied.53

Other commonly used measures of diagnostic test performance are the positive and negative predictive values, which reflect the perspective of a clinician interpreting a given test result. The positive predictive value (PPV) of a test is the probability of an individual actually having the disease/condition when the test result is positive. The negative predictive value (NPV) is the probability of an individual not having the disease/condition when the test result is negative. Unlike sensitivity and specificity, predictive values are influenced by the prevalence of disease in the population of individuals being tested. For example, in a situation where disease prevalence is very low, say 1%, the negative predictive value of most tests will easily exceed 95%, given that 99% of the population does not have the disease.

Two other measures of diagnostic test performance can be calculated that may be more clinically useful: the positive likelihood ratio and the negative likelihood ratio.54, 55 The positive likelihood ratio measures the ability of the test to accurately “rule in” disease, whereas the negative likelihood ratio measures the ability of the test to accurately “rule out” disease. Likelihood ratios can be directly used in Bayes’ theorem to calculate posttest odds of having disease from the pretest suspicion of the individual’s odds of having disease.

Two elements are particularly important to consider when assessing the clinical validity of genetic tests—penetrance and modifiers. Penetrance is a measurement of the proportion of individuals in a population with a disease-related genotype or mutation who develop the disease. It is expressed numerically. For example, if 100 individuals all have a particular gene mutation but only 80 of them have the condition associated with that mutation, then the mutation is said to be 80% penetrant.3 Modifiers include other genetic or environmental factors that may interact with the genetic alteration being studied and the outcome(s) of interest. Modifiers can affect expressivity, which refers to the variability of signs or symptoms of disease among individuals with the same genotype.

One frequent tactic for establishing molecular test validity is the use of the case-control study. Case-control studies are studies in which a collection of “cases” (known to have the condition or mutation of interest) and a collection of “controls” (known not to have the condition or mutation of interest) are assembled and tested with the experimental diagnostic test. Case-control studies are generally considered to be a poor method of evaluating diagnostic test accuracy because they have been shown to over-estimate test accuracy. This occurs because the studies usually include only the unambiguous cases, those that are clearly “positive” and those that are clearly “negative,” and fail to include the difficult-to-diagnose cases. Pai et al. reported that this drawback of the case-control design applies to molecular tests.56, 57 The most rigorous study design for assessing the clinical validity of a molecular test, as with any other diagnostic test, is a prospective blinded comparison of the test and a reference standard in a consecutive series of patients from a relevant clinical population.

The Oncotype DX™ assay (Genomic Health, Inc., Redwood City, CA), described in Chapter 2, is used to assess prognosis and guide choice of adjuvant therapy in breast cancer patients (hormonal therapy alone versus hormonal therapy plus chemotherapy). As mentioned in the previous chapter, published studies on the development, clinical validation, and clinical utility of the Oncotype DX™ assay are listed on the Genomic Health Web site. The National Cancer Institute (NCI) is sponsoring an on-going clinical trial that began in 2006 to evaluate the effect of adjuvant chemotherapy on disease-free survival in women with “Mid-Range” Oncotype DX™ Recurrence Scores®. The study (Trial Assigning Individualized Options for Treatment/TAILORx) is planned to enroll about 10,000 breast cancer patients and assess recurrence and mortality outcomes for 20 years. The principal objectives of the trial are:

- To determine whether hormonal therapy alone is equivalent to hormonal therapy plus chemotherapy in women whose tumors meet established clinical guidelines for adjuvant chemotherapy and whose Oncotype DX™ Recurrence Score® test results are in the “uncertain chemotherapy benefit” category as set by study investigators (Recurrence Score® results from 11 to 25).
- To create a tissue and specimen bank for patients enrolled in the trial, including formalin-fixed, paraffin-embedded tumor specimens, tissue microarrays, plasma, and DNA obtained from peripheral blood.

#### Challenges in Assessing Clinical Validity of Molecular Tests

The clinical validity of a molecular test is influenced by a number of factors, including the adequacy of information available to determine how accurate the test is in detecting a health condition, the purpose of the test, and the prevalence of the disease or condition for which the test is being conducted. Forbes noted several issues associated with validating the clinical sensitivity and specificity of an amplification test (e.g., PCR) on clinical specimens for infectious diseases.20 The most significant is the selection of the “gold standard,” whose results will be compared to those obtained with the amplification test. Culture has been traditionally used as the final arbitrator in determining whether a clinical specimen is truly positive or not for a given pathogen. However, according to Forbes, numerous incidents during the past decade have arisen that have demonstrated that culture may be an imperfect standard. She gives two examples in which PCR has been shown to be more sensitive than culture—the detection of Bordetella pertussis in respiratory samples and herpes simplex virus in cerebrospinal fluid. Recognizing that the gold standard may be imperfect, some laboratories use “discrepant resolution” in which patients for whom the reference standard and test method disagree are subjected to a “third” resolver test. A number of objections, however, have been raised with regard to using this method. For instance, Marr and Leisenring argue that discrepant resolution methods are generally more expensive and invasive and are typically biased in favor of amplification tests.58 They suggest resolving discrepancies either through repeated testing or by using, when possible, multiple imperfect reference standards.

A somewhat analogous issue to selecting a “gold standard” in assessing the clinical validity of a molecular genetic test is the characterization of the mutations being tested. In order to accurately validate a genetic test, the exact characterization of the mutations being tested is needed. However, according to Zimmern and Kroese, in many instances, all the main causative mutations will not be known and this will reduce the sensitivity and, hence, clinical validity of the test.59 Further, the key causative mutations for a particular disorder may vary among different populations. Zimmern and Kroese highlight the studies of clinical sensitivity of the ACMG panel of 25 mutations for cystic fibrosis. The overall results of the studies estimated that the clinical sensitivity of the panel was 71.9% for non-Hispanic Caucasians, 41.6% for African Americans and only 23.4% for Asian Americans. The clinical sensitivity of this test, according to Zimmern and Kroese, was limited by the mutations chosen to be included in the panel, which highlights the importance of knowledge of the frequency of specific genetic variations in a defined population.

A number of other issues, such as heterogeneity of disease, mosaicism, and prevalence of disease, are important to consider when assessing the clinical validity of molecular tests. Heterogeneity of disease is particularly relevant to genetic tests, because a particular genetic condition may be caused by more than one gene, or by more than one variant within the gene.60 Thus, a genetic test will perform poorly if genes or variants other than the one tested for are responsible for the disease (i.e., locus heterogeneity or allelic heterogeneity).

False-negative results in individuals may also occur in genetic tests when there is mosaicism, where only a proportion of cells contain a mutation.60 This occurs in genetic conditions caused by sporadic mutations, for example, tuberous sclerosis complex. In this case, false-negative results may occur because of the small number of cells containing the mutation in the sample being tested. Finally, assessing clinical validity may be particularly challenging in the case of tests for ultra-rare diseases.3 As relatively few people have these diseases, gathering statistically significant data can be extremely challenging. Thus, prevalence is a factor in determining how much data on test performance should be available before a test is offered in patient care.

### Assessing Clinical Utility of Molecular Tests

Clinical utility refers to the usefulness of the test and the value of information to medical practice. In molecular testing, clinical utility represents a balance between health-related benefits and the harms that can occur from a test.3 In general, the benefits and harms of a molecular test should be compared to the best alternative test to assess incremental benefits and harms. Alternatively, the incremental benefits and harms of using a molecular test should be compared to using no test at all, if that is the current standard of care. Benefits and harms should be considered at multiple levels including the patient, family, healthcare organizations, and society. Each level will have a different perspective of risk, which will ultimately impact the acceptance of a test into routine clinical practice.

Grosse and Khoury apply the framework previously proposed by Fryback and Thornbury61 to molecular testing.62 According to these authors, beyond assessing the analytical and clinical validity of a test, the following four levels of impact should be considered: diagnostic thinking, therapeutic choice, patient outcome, and societal impacts. Diagnostic thinking refers to the value of information in understanding the diagnosis, cause, and prognosis of a condition. Therapeutic choice refers to the use of test results in clinical management of an individual with a diagnosed disorder. Patient outcomes refer to endpoints such as mortality and quality of life, i.e., clinical results that can be perceived by and that matter to the patient.

The Analytic Validity, Clinical Validity, Clinical Utility, and Ethical, Legal, and Social Implications (ACCE) model suggests to consider the following elements when assessing the utility of molecular genetic tests: 1) the natural history of the disorder, 2) availability and effectiveness of interventions, 3) potential adverse outcomes of having the test done, and 4) available resources (education and expertise) to manage all aspects of service.63

The impact of interventions that occur as a consequence of a molecular test is particularly important in assessing clinical utility. The impact of an intervention on patient outcomes is ideally measured using randomized controlled trials (RCTs). Although they may have a better internal validity, efficacy RCTs typically focus on short-term outcomes in highly selected patient populations, often making it difficult to generalize the findings. Clinical utility is primarily concerned with effectiveness, which involves measuring long-term health outcomes of the general population in real-world settings. The National Cancer Institute (NCI) is currently sponsoring a pragmatic clinical trial - the TAILORx trial described above. Practical clinical trials involve large sample sizes, broad inclusion criteria, and modest data collection, and provide estimates of effectiveness in typical care settings.3

#### Challenges in Assessing Clinical Utility of Molecular Tests

The major challenge in assessing clinical utility is the lack of studies that directly correlate test results with clinical outcomes. RCTs, particularly effectiveness RCTs, are rarely available. Other study designs, such as case series (single group designs) are prone to various internal validity issues. As a result, evaluation of clinical utility often involves inference based on the evidence for the analytic validity and clinical validity of the test. However, evaluation of analytical and clinical validity itself is also challenging (see our previous discussion). For most LDTs, data on analytical and clinical performance are not publicly accessible unless published in peer-reviewed journals. In contrast, FDA-approved or cleared commercially distributed test kits are accompanied by a kit insert that summarizes the analytical and clinical validity data submitted for approval; FDA Decision Summaries are publicly available via the FDA Web site.

### Systematic Reviews

Overall, our searches identified 24 systematic reviews that evaluated the clinical validity or utility of molecular tests. Of the 24 reviews, seven focused on tests for diagnosis of infectious diseases, 12 on tests for diagnosis or treatment monitoring for various cancers, and five on tests used to detect specific gene variants for predicting drug reactions. The purpose, quality, outcomes, and reported findings of the reviews are summarized in Table 30 through Table 32.

#### Tests for Infectious Diseases

Our searches identified seven systematic reviews that evaluated the clinical validity of molecular tests used for diagnosis of infectious diseases. Important information about these reviews is presented (Table 30). In six of the seven reviews, tuberculosis (TB) was the condition of interest. The remaining review considered the limitations and applications of molecular methods used to diagnose Lyme disease. The six reviews on TB were of high quality, as judged by the AMSTAR assessment tool.56, 57, 64-67 The review on molecular methods for Lyme disease, however, received a low quality rating.68 Key elements, such as a comprehensive literature search, listing of all included studies, and assessment of included study quality, were either missing or not reported in this review. See Table 29 in Appendix C for further information about the quality of each of the reviews.

All six of the reviews on TB focused on evaluating the evidence on the diagnostic accuracy of nucleic acid amplification (NAA) tests in the diagnosis of tuberculosis. In all of the reviews, PCR was the primary testing method considered. Four of the six reviews considered both laboratory-developed and commercially available tests. However, one review considered only laboratory-developed tests,66 and one considered only commercially available tests.64 Evidence on the following commercially available tests was assessed: Amplicor MTB tests (Roche Molecular Systems), the Amplified Mycobacterium Tuberculosis Direct Test (MTD) (Gen-Probe, Inc), BDProbeTecET assay (BD Diagnostic Systems), and LCx (Abbott Laboratories).^3^

3 The LCx (Abbott Laboratories) test has been recently discontinued.

The largest and most recent review, published by the U.K.-based National Institute for Health Research (NIHR) in 2007, included 207 studies that evaluated the diagnostic accuracy of PCR methods in patients with suspected TB.69 Of the 207 studies, 106 used commercial tests and 101 used laboratory-developed tests. The majority of studies included in this review and the other reviews on pulmonary TB used sputum samples for detecting the organism. Similarly, mycobacterial culture was the primary reference standard used in most studies. Some studies, however, used microscopy alone, and some used both culture and microscopy. Below, we summarize the findings of the NIHR review, which appear to be consistent with previous reviews on the diagnostic test accuracy of NAA tests for TB:

- Most of the included studies reported very high estimates of specificity, for both pulmonary and extra-pulmonary TB; sensitivity estimates, in contrast, have been much lower and highly variable.
- Sensitivity estimates have been lower in paucibacillary TB (smear negative and extra-pulmonary TB), and higher in smear positive pulmonary TB.
- There is a lack of consistency in accuracy estimates across studies for both commercial and laboratory-developed tests.
- The sensitivity and specificity of laboratory-developed tests, however, have been more variable and inconsistent than commercial tests. Sensitivity estimates for laboratory-developed tests ranged from 9.4% to 100%, and specificity estimates ranged from 5.6% to 100%. In comparison, for commercially available tests, sensitivity ranged from 62% to 100% and specificity ranged from 98% to 100%.
- The main explanatory factors for the variability were the reference standard used, whether the study was laboratory- or hospital-based, and the use of blinded test interpretation.
- Accuracy appeared to be higher when culture alone was used as a reference standard, the study was laboratory-based, and in studies with lack of blinded interpretation of both index and reference tests. (In another review of laboratory-developed NAA tests, Flores et al. (2005) explored potential sources of heterogeneity, and found that the use of IS6110 target sequence and nested PCR methods appear to significantly increase diagnostic accuracy.66)

Overall, the authors of the NIHR review and other reviews on NAA tests for TB concluded that diagnostic accuracy must be further established before NAA tests can replace conventional diagnostic tests (e.g., smear and culture) for TB. Future studies should have a prospective design, include a wide spectrum of patients, use appropriate reference tests, and avoid major sources of bias such as verification bias, lack of blinding, and inclusion of indeterminate results.

Note that the Centers for Disease Control and Prevention (CDC) recently updated its guidelines for the use of NAA tests in the diagnosis of TB. Nucleic acid amplification tests can detect Mycobacterium tuberculosis bacteria in specimens one or more weeks earlier than the culture-based conventional tests, and thus could have significant impact on patient care and public health.70 The new guidelines recommend that NAA testing be performed on at least one respiratory specimen from each patient with signs and symptoms of pulmonary TB for whom a diagnosis of TB is being considered but has not yet been established, and for whom the test result would alter case management or TB control activities, such as contact investigations. The recommendation was made based on a report of a panel of clinicians, laboratorians, and TB control officials that was convened by CDC and the Association of Public Health Laboratories.

#### Tests for Cancers

Our searches identified 12 systematic reviews that evaluated the use of molecular tests for cancer diagnosis or treatment monitoring.38, 43, 71-78 Seven of the 12 reviews assessed the clinical utility of molecular tests, with the primary outcomes being recurrence of disease and/or survival. The remaining five reviews evaluated the diagnostic accuracy of molecular test methods to detect the presence of cancer-related genes. In most of the reviews, the studies used PCR as the amplification method. However, the studies included in one review on the use of ERBB2 gene (also known as HER2) testing to manage cancer patients used various commercially available tests^4^ that used either fluorescence in situ hybridization (FISH, e.g., PathVysion HER2 DNA Probe Kit, INFORM HER2/neu) or immunohistochemistry (IHC, e.g., PATHWAY).79 The overall findings and other important information about the reviews are reported in Table 31 in Appendix C. The quality of the reviews ranged from moderate to high. Below, we provide a more thorough discussion of the five most recent reviews. Each review focuses on a different testing method(s): one on various tests using FISH or IHC methods,79 two on DNA microarrays (including the Oncotype DX® assay),38, 43 and one on PCR methods (e.g., standard PCR, nested PCR, and real-time PCR).71

4 See Table 31 for a complete listing of the tests used in the studies included in this review.

The first review published by Seidenfield et al. in 2008 evaluated the evidence on the application of ERBB2 testing for the management of cancer patients.79 The applications considered included the following: 1) the potential for response to trastuzumab among patients with breast cancer who have negative, equivocal, or discordant ERBB2 assay results; 2) the use of ERBB2 assay results to guide selection of breast cancer treatments other than trastuzumab (i.e., chemotherapy); 3) the use of serum ERBB2 to monitor treatment response or disease progression in patients with breast cancer; and 4) the use of ERBB2 testing to manage patients with ovarian, lung, prostate, or extracranial cancers. Overall, the review included 71 studies— four addressed the first application described above, 26 the second application, 15 the third application, and 26 addressed the fourth application. The studies included in the review used FISH or IHC methods to determine ERBB2 status. While no formal analysis was conducted to assess the concordance and discrepancy of ERBB2 measurements, the authors do provide a narrative discussion of FISH versus IHC. According to the authors, “there is no recognized gold standard to determine the HER2 status of tumor tissue, which precludes consensus on one best HER2 assay.”79

Overall, the authors of this review indicated that the currently available evidence for the key questions addressed in this review was weak. The evidence was weak on outcomes of trastuzumab added to chemotherapy for most ERBB2-equivocal, discordant, or negative patients and for comparing chemotherapy outcomes in ERBB2 positive and ERBB2 negative patient subgroups. The evidence was also weak regarding differences by ERBB2 status for outcomes of chemotherapy for advanced or metastic disease and for testing malignancies of lung, ovary, head and neck, or prostate. The authors concluded that future cancer therapy trial protocols should report the following elements of the potential of ERBB2 testing to improve treatment outcomes: detailed reporting of how ERBB2 status was ascertained, stratified randomization by ERBB2 status or prospectively specified ERBB2 subgroup analysis of outcomes, and detailed recording of all relevant data and archiving of tissue samples for future subgroup analysis.

A second review published in April 2008 by the Blue Cross Blue Shield Technology Assessment group (TEC) examined the clinical utility of three gene-expression profiling tests—the Oncotype DX™, MammaPrint® and the Breast Cancer Gene Expression Ratio (also known as the 2-gene ratio or HOXB13/IL-17BR ratio).80 These tests have permitted the analysis of patterns of gene expression in as many as thousands of genes simultaneously. This technology is primarily of interest for its potential use to predict the risk of disease recurrence and to guide the use of adjuvant systemic therapy. Specifically, the TEC report examined whether, compared to conventional risk assessment tools, the use of these tests “improves outcomes when used to decide whether risk of recurrence is low enough to forgo adjuvant chemotherapy for early stage breast cancer.”80

Overall, the authors concluded that there was insufficient evidence to determine whether MammaPrint® or the Breast Cancer Gene Expression Ratio are better than conventional risk assessment tools in predicting recurrence. However, their analysis of four studies evaluating the OncotypeDX™ indicated that this test provides “information about the risk of recurrence that is incremental to conventional classifiers used to predict risk. Women classified as high risk by conventional methods and reclassified as low risk by OncotypeDX™ have a recurrence of at most 10% to 14%.” The authors of the TEC report, however, suggest that there are several limitations to the available evidence. In particular, which patient groups benefit the most from the test (low versus moderate versus high risk women) and how the presentation of risk information affects choices is unknown.

In January 2008, the Johns Hopkins Evidence-based Practice Center, under contract to AHRQ, also assessed the analytic validity and clinical validity, and impact on clinical decision making of three gene-expression- based tests – Oncotype DX™, MammaPrint® and the Breast Cancer Profiling Test (also known as the H/I ratio test).38 The authors determined that the Oncotype DX® assay had the strongest evidence for its ability to improve assessment of prognosis than standard risk stratification, at least in ER positive, lymph node negative, tamoxifen-treated women considering adjuvant chemotherapy. However, they point out that there is still uncertainty about how best to incorporate the test results into decision making, and how best to use the conventional predictors to which it has been compared. They also note that the utility of the risk estimates derived from the test results to ERBB2 positive patients has not yet been determined. In evaluating studies of the MammaPrint® assay, they noted that it was still unclear who the appropriate target population would be or how much the results would add to decision making based on standard risk factors. They did report that a clinical trial, Microarray in Node-negative Disease (MINDACT), has recently begun in which MammaPrint® will be compared to another method of risk assessment in early stage breast cancer.38

Lyman & Kuderer (2006) also examined the evidence on gene expression profile assays as predictors of recurrence-free survival in early stage breast cancer.43 The primary outcome of interest in this review was disease-free survival based on gene expression risk category. Patients were stratified according to the gene expression profile into a high- or low-risk group. The evidence base for this review consisted of 17 studies that included 2,908 patients ranging from 20 to 668 patients per study. Of the 2,908 patients included in this review, 1,531 (52.6%) were classified as high risk based on the gene assay, and 595 (20.5%) experienced distant breast cancer recurrence during the late period of observation. The reported recurrence rates were 31.2% among gene expression profile patients at high risk, and 8.5% among low-risk patients.

According to the authors of the review, substantial heterogeneity was observed across studies on most measures of test performance. Analysis of test performance measures indicated that the sensitivity of the gene assays for predicting recurrence was relatively high in some studies, but the specificity for identifying those who remain disease free was quite low. The authors suggest that the following may explain study-by-study variation: use of different gene signatures, different risk score cutoff points, and inclusion of different populations of patients with early stage breast cancer (i.e., with respect to disease stage, receptor status, and treatment). Based on the results of their analysis, the authors concluded that gene expression profiles show promise for predicting survival in patients with breast cancer. However, their use in clinical decision making must be considered in light of the between-study variability in assay prognostic performance, specific patient population being evaluated in the included studies (women with early stage breast cancer), and small number of patients included in the studies (50% of studies had fewer than 100 women).43

In 2007, Mocellin et al. published a review that evaluated the evidence on the use of PCR to detect the presence of melanoma cells in sentinel lymph nodes (SLN).71 The authors of the review were primarily concerned with the overall effect of PCR status on patient survival. The evidence base for this review consisted of 22 original articles that included 4,019 patients with stage I or II cutaneous melanoma. Histopathologic examination of SLN consisted of hematoxylin & eosin (HE) staining combined with IHC in all but one study, in which HE only was used. According to the authors of the review, all analyses were performed considering an SLN molecularly positive for melanoma metastasis if at least one tumor marker was observed amplified at PCR analysis. The majority of studies included in the review chose either S-100 or gp100 as tumor markers, and some studies also adopted additional markers (e.g., tyrosinase and/or melanoma antigen recognized by T-cells [MART1]). Ten of the 22 studies used nested PCR, nine used standard PCR, and three used real-time PCR.

According to the authors, meta-analysis of the pooled data of 2,443 patients (not all studies had sufficient data to include in analysis) showed a significantly increased risk of death in patients with PCR positivity (hazard ratio (HR)^5^: 5.08; 95% CI’s 1.83 to 14.08; p = 0.002). Heterogeneity testing, however, indicated significant study variability of effect estimates. Subgroup analysis showed that the findings of two studies caused most of the heterogeneity, with both studies having in common the use of standard PCR and a relatively short follow-up period (<36 months). Further analysis indicated that trials using nested-PCR and longer follow-up periods had the strongest effect in favor of PCR as a prognostic factor. Based on these findings, the authors concluded that PCR status of SLN appears to have a clinically valuable prognostic power in patients with melanoma. However, considering the presence of heterogeneity, the authors warn against overestimating the favorable results of pooled data.71

5 The following is the hazard ratio formula used in the review: observed survived-expected to survive/observed PCR positive-expected PCR positive.

#### Tests for Predicting Drug Reactions

Our searches identified five systematic reviews that focused on studies of tests used to detect specific gene variants involved in drug metabolism. The quality of the reviews ranged from moderate to high. Table 32 in Appendix C presents important information about the characteristics of the studies included in the reviews and the reported results and conclusions of the reviews. Four of the five reviews evaluated the evidence on a specific metabolic enzyme within the cytochrome P450 (CYP450) enzyme system. The CYP450 family of enzymes is found in the liver and is responsible for metabolizing and eliminating a large number of pharmacologic agents. Polymorphisms of some of the genes within this system are known to impact enzymatic activity. Tests, such as the recently FDA-approved Roche AmpliChip® CYP450 Test, are now available to test for CYP450 polymorphisms. The AmpliChip® delivers the results of testing for polymorphisms in the form of “predicted phenotypes”—poor metabolizers (PMs), intermediate metabolizers (IMs), extensive metabolizers (EMs), and ultra-rapid metabolizers (UMs). Drug metabolism is thought to be associated with the potential for toxicity or lack of efficacy. In three of the four reviews on CYP450, the majority of the included studies used the Roche AmpliChip® CYP450 test to examine polymorphisms.37, 81, 82 The authors of the fourth review did not indicate whether the studies used a specific test.83 The fifth review evaluated the diagnostic accuracy of a commercial line probe assay-INNO-LiPA Rif. TB (LiPA) developed to rapidly detect rifampicin resistance, a marker of multi-drug resistant tuberculosis (MDR-TB).65

The first of the five reviews on CYP450 evaluated the evidence for CYP2D6 genotyping, compared to no testing, for guiding treatment for patients at high risk for primary breast cancer or breast cancer recurrence.81 CYP2D6 plays a major role in the metabolism of tamoxifen, which is prescribed as a component of adjuvant endocrine therapy to prevent breast cancer recurrence, treat metastatic breast cancer, and prevent development of the disease in high risk populations. Eleven studies made up the evidence base for this review—seven studies considered the association of the genotype with plasma levels of active tamoxifen metabolism and four considered the association of the genotype with clinical outcomes. None of the included studies were randomized trials. Overall, the authors of this review concluded that the available evidence was insufficient to determine whether or not the use of CYP2D6 genotyping for directing endocrine therapy regimen selection improves health outcomes for women at high risk for or with breast cancer. Thus, the evidence was considered insufficient to support the clinical utility of CYP2D6 testing.

The second review focused on whether the use of CYP2C19 genotyping to direct treatment of Helicobacter pylori (H. pylori) infection improved health outcomes compared to no testing (or standard treatment).82 Polymorphisms in CYP2C19 affect the metabolism of proton pump inhibitors, which could potentially have an impact on the efficacy of H. pylori eradication. Only one randomized controlled trial met the inclusion criteria for this review. The results of the study indicated that H. pylori eradication rates at 1 month were 96% in the pharmacogenomics-based treatment group versus 70% in the standard care group (a statistically significant difference, p <0.001). Eradication rates were greater for extensive metabolizers than poor metabolizers. However, because only one study met the inclusion criteria for this review, the authors concluded that the evidence did not permit conclusions on whether the use of a pharmacogenomics-based treatment regimen for H. pylori improves eradication rates or net health outcomes.

The third review focused on testing for CYP450 polymorphisms in adults beginning selective serotonin reuptake inhibitor (SSRI) treatment for non-psychotic depression. The following CYP450 enzymes are primarily involved in the metabolism of all SSRI’s: CYP2D6, CYP2C19, and CYP2C9.^37^ The primary question addressed in this review is whether CYP450 testing would lead to improved clinical outcomes and whether test results were useful in medical, personal, or public health decision-making. Other questions in the review addressed the analytic validity of the CYP450 test (results discussed in previous chapter), clinical validity of the test (specifically if CYP450 genotypes predict drug metabolism and efficacy of SSRIs), and adverse events or harms that result from the testing. No studies were identified that directly addressed any aspect of the primary questions of clinical utility. Fourteen studies addressed analytic validity, 16 addressed CYP450 genotypes and metabolism of SSRIs, five addressed CYP450 testing and efficacy of SSRIs, and nine studies addressed CYP450 testing and adverse drug reactions. Pooled analysis of study results was not conducted due to the poor quality of the evidence base and between-study heterogeneity (e.g., healthy volunteers vs. patients and use of SSRIs in patients with conditions other than just depression).37

Based on the reported study results, the authors of this review concluded that the data fail to support a clear correlation between CYP polymorphisms and SSRI levels, SSRI efficacy, or tolerability. Further, there are insufficient data regarding whether testing leads to improved outcomes versus no testing in the treatment of depression; whether testing influences medical, personal, or public decision making; or whether any harms are associated with testing itself or with subsequent management.

In the fourth review on the CYP450 enzyme system, Sanderson et al. (2005)83 evaluated CYP2C9 gene variants in patients either starting or already established on warfarin. CYP2C9 isoenzyme is responsible for the metabolism of a number of drugs, including warfarin, phenytoin, and losartan. The gene coding for CYP2C9 has been mapped to the long arm of chromosome 10 (10q24.2), within the cluster of CYP450 genes. Two variants of the CYP2C9 gene are known to reduce metabolism of warfarin: CYP2C9*2 by 30% to 50% and CYP2C9*3 by around 90%. The most serious complication associated with the use of warfarin is bleeding, occurring at a rate of 8 per 100 patients. Individuals with the two identified CYP2C9 gene variants are thought to be more susceptible to bleeding because of reduced metabolism, and thus may require lower maintenance doses of warfarin.

The evidence base for this review included 11 studies with a total of 3,029 patients. No significant between-study heterogeneity was detected. In all but one study, which did not report what test method was used, PCR was the testing method. The outcomes considered in this review were drug dose, indicators of anti-coagulation, and bleeding events. Overall, the results of the review showed that patients with CYP2C9*2 and CYP2C9*3 alleles have lower mean daily warfarin doses and a greater risk of bleeding. Based on these results, the authors of the review concluded that testing for gene variants could potentially alter clinical management in patients starting treatment with warfarin, but more evidence on the clinical utility and cost-effectiveness of genotyping is needed before routine testing can be recommended.83

In the final review, Morgan et al. (2005) assessed the diagnostic accuracy of the commercially available INNO-LiPA Rif. TB kit (LiPA).65 The LiPA is a line probe assay able to identify the M. tuberculosis complex and simultaneously detect genetic mutations in the rpoB gene region related to rifampicin (RIF)-resistance. The test is performed by extracting DNA from cultures or directly from clinical samples and amplifying the RIF-resistance-determining region of the rpoB gene using PCR. The M. tuberculosis isolate is considered RIF susceptible if all of the wild-type S probes give a positive signal and all of the R probes react negatively. RIF-resistance is indicated by absence of one or more wild-type S probes. When RIF-resistance is due to one of the four most frequently observed mutations, a positive reaction is obtained with one of the four R probes.

The evidence base for this review included 15 studies with 1,738 specimens. All the studies included in the review reported on the diagnostic accuracy of LiPA. Significant between-study heterogeneity was not detected in this review. Overall, the results showed that the sensitivity was greater than 95% in 12 of 14 studies that applied LiPA to isolates, and the specificity was 100%. In four studies that applied LiPA directly to clinical specimens, the specificity was 100% and the sensitivity ranged from 80% to 100%. Based on these results, the authors concluded that LiPA is a highly sensitive and specific test for the detection of rifampicin resistance in culture isolates. The test, however, appears to have a relatively lower sensitivity when used directly on clinical specimens.