# How Is Analytic Validity Established for Laboratory-Developed Molecular Tests?

For this Key Question, we were asked to look at how analytic validity is established for laboratory-developed molecular tests. Specifically, we were asked to cover the following aspects of analytic validity:

- Accuracy
  - In comparison to reference methods
  - Type of samples tested (i.e., control material, patient samples, etc.)
  - Number of samples tested
  - Methods for setting a cut-off
- Precision/reproducibility
  - Repeatability: replication studies on a single specimen using a single molecular test method and the same equipment
  - Reproducibility: replication studies assessing day-to-day, operator-to-operator precision. If multiple instruments are used, instrument-to-instrument reproducibility should be assessed; if the test is performed in multiple laboratories, site-to-site reproducibility should be also assessed.
  - Duration of study
  - Type of sample tested (i.e., control material, patient samples, etc.)
  - Number of samples tested
  - Performance near clinically critical cut-points and covering the assay’s detection range
- Assay linearity, recovery and high-dose hook-effect
- Limit of detection and limit of quantitation (at low and high ranges)
- Analytical specificity (cross-reactivity, interference)
- Matrix effects
- Quality assurance for manufactured and/or purchased reagents utilized in laboratory-developed molecular tests
- Pre-analytical factors influencing assay results
- Assay output (reading ranges)

## Methods

To address Key Question 2, we provide an overview of the processes used to establish the analytic validity for new laboratory-developed tests. In the literature search, systematic reviews relevant to the questions were given highest priority, followed by other publication types, including evaluation studies. Recent narrative reviews were utilized as necessary to address questions not covered by systematic reviews or primary studies. Meeting abstracts, Web-based publications, and other “gray literature” were included if published literature was not available to address the various sub-questions. The literature search strategy for this Key Question is provided in Appendix A of the report.

In addition to the information from the literature, expert input was also utilized in addressing Key Question 2. We also selected a representative sample of molecular tests and discussed the validation process used for each test.

## Results

The initial step of developing a molecular test is to design and optimize the test. For example, a large number of tumor samples may be screened to identify a panel of markers that appear to predict response to chemotherapy. The initial developmental stage is not discussed here. Once the test has been developed, it needs to be validated. The College of American Pathologists (CAP) published recommendations on how to perform analytic and clinical validation studies and the checklists used for CAP accreditation describe standards to be met in validation studies.7 The American College of Medical Genetics (ACMG) guidelines on molecular testing state that each laboratory must validate the analytical performance characteristics (sensitivity, specificity, reproducibility) of the technique chosen for analysis of each gene.8 New York State Clinical Laboratory Standards of Practice guidelines on validation also state that laboratories must establish performance specifications for accuracy, precision, reportable range, reference intervals, analytical sensitivity and specificity, and other applicable performance characteristics (www.wadsworth.org/labcert/TestApproval/submitguide.htm). Validation studies must be submitted to New York State and approved before the test may be commercially offered for use on samples submitted from New York State.9 The Clinical Laboratory Improvement Amendments (CLIA) program requires that any new test be validated by the laboratory, but unlike New York State, does not require submission of a formal demonstration of validation prior to offering the test, as long as the laboratory is in compliance with CLIA regulations.10

The following sections of this chapter address specific aspects of the process for validating analytical performance of molecular tests based on the literature described in the Methods section. In addition, the Clinical and Laboratory Standard Institute (CLSI), a well-regarded organization that develops laboratory standards based on voluntary consensus, has published a series of molecular-test-related guidelines (listed in Chapter 8 and Appendix D). Some of these CLSI guidelines discuss analytic validity regarding microarrays11 (pp. 61–63), nucleic acid amplification for hematopathology12 (p. 34), molecular diagnostic methods for genetic diseases13 (pp. 38–44), florescence in situ hybridization14 (pp. 11–20), and multiplex nucleic acid assays15 (pp. 35–42). Refer to the CLSI guidelines for the detailed discussions. Another useful source with detailed descriptions of the processes involved in establishing analytic validity of microbiology tests is the review by Wolk, Mitchell and Patel (2001).16

Clinically oriented literature on validation of diagnostic tests sometimes merges the concepts of analytic validity (at the level of the substance being detected or measured) with those of clinical validity (at the level of the disease or condition), particularly when referring to test “accuracy.” Most evidence-based processes for evaluating diagnostic tests assume that evaluating clinical validity will address any analytic validity problems, and thus do not formally consider analytic validity. However, the Evaluation of Genomic Applications in Practice and Prevention (EGAPP) Working Group states that formal evaluation of analytic validity for genetic technologies is important because the technologies are complex and rapidly evolving and tests may not have been fully validated in multiple sites, for all populations of interest, or under routine clinical laboratory conditions over time; in addition, review of analytic validity can also determine whether clinical validity can be improved by addressing test performance.17

Strictly speaking, analytic validity includes the concepts of accuracy, precision, analytic sensitivity, analytic specificity, linear range and determination of normal range or cut-off points for positivity. The CLIA regulations require laboratories to establish these parameters prior to offering the test to the public (42 CFR 493.1253). When, as is the case with many molecular tests, there is no reference standard for the analyte, analytic validity is more narrowly defined, and descriptions of “accuracy” are actually about “diagnostic accuracy,” or “clinical validity.”

### Accuracy

#### Accuracy in Comparison to Reference Methods

Accuracy refers to how well the test measures what it purports to measure, and is determined for most laboratory tests by using the test to detect and often to measure the quantity of a known substance of a known concentration in a specimen. The identification of true-positive samples and the amount of the substance present in the sample are determined independently by a reference method.

Establishing reference methods for molecular tests is problematic. The analytical accuracy of many quantitative molecular assays cannot be established because no reference standard exists. An additional complication is that in many cases, the PCR-based assay being validated may be more sensitive than the current “gold standard” reference assay.18-21 Direct sequencing of genetic material can be used as the “gold standard” for many tests intended to detect mutations.21-23 Other methods that can be used to confirm the accuracy of molecular tests include specific hybridization, nested PCR, or restriction enzyme digest assays.21 Restriction enzymes are used to break DNA at specific sequence sites, creating more specific DNA fragments. These fragments can then be hybridized, tagged, and separated by electrophoresis, creating patterns indicative of mutations. Nested PCR uses two sets of PCR primers for a single target. The first set of primers amplify the target as with any standard PCR. The second set of primers (nested primers) bind within the product from the first PCR amplification and produce a second PCR product that will be shorter than the first one. Nested PCR is used to reduce the chance of amplifying unwanted DNA sequences. The ACMG guidelines indicate that in the absence of “gold standards” for comparison of results of new assays, the splitting of samples with another laboratory with an established clinical assay may be considered.8

The American Society of Clinical Oncology, in conjunction with the College of American Pathologists, suggests comparing the new assay to a previously validated assay, and if the results are 95% concordant, the new assay may also be considered to be valid.24 One laboratory published the results of its attempts to validate their in-house PCR assay by following this approach.25 The laboratory compared the results of its HER2/neu (also known as ERBB2) assay to four other available methods of measuring HER-2/neu amplification or over-expression. Complete agreement between methods was obtained for only 94.5% of the 163 samples tested. Because no true reference standard was available, the discrepancies could not be resolved.

#### Type of Samples Tested

The question of how and from where specimens are to be obtained for validation of a molecular test has not been clearly addressed in the literature. For some conditions, such as rare genetic disorders, there are very few positive clinical samples available.20, 22 There are some public repositories of cell lines and other biological materials that may be suitable for validation of some molecular tests, for example, both the Coriell Cell Repositories (http://ccr.coriell.org) and the American Type Culture Collection (http://www.atcc.org) maintain an extensive collection of biological materials. It is, however, important to ensure that the specimens used to validate the test are collected, stored, and processed in the same way samples will be prepared for actual clinical use of the test, and therefore artificially constructed samples may not be appropriate for validating many molecular tests.16, 20 In its 2008 report on the U.S. system of oversight of genetic testing, SACGHS recommended that the Human Health Services (HHS) should ensure funding for the development and characterization of reference materials, methods, and samples for the validation of genetic tests.3

#### Number of Samples Tested

Dimech et al. recommend that at least 100 positive and 100 negative samples be tested during the analytical validation phase.21 Dimech et al. further suggest that if positive samples are difficult to obtain, a minimum of 20 “real” positive samples should be tested, and this data should be supplemented with tests of artificially-constructed positive samples.21 The American Society of Clinical Oncology/College of American Pathologists suggests testing 25 to 100 samples during the analytical validation phase.24 Prence recommends testing at least 20, preferably more than 100, samples to establish validity, noting that care should be taken in selecting samples in order to simulate a clinically relevant population.26 Factors such as age, sex, pregnancy, ethnic background, use of medications, and anything else that could affect the test result should be considered in determining an appropriate sample number. Another factor that needs to be considered is the use of healthy normal volunteers as negative samples, because such practice may skew the testing results. In some cases, negative samples selected from patients with other, similar, disorders may be necessary to truly validate the test.

#### Methods for Setting a Cut-off Threshold

The cut-off threshold is the point at which the test is declared “positive” or “negative.” Methods to establish the cut-off point depend on the test and its intended purpose. For example, a test intended to measure levels of virus in the blood may have no cut-off point; whereas a test intended to detect amplification of HER2/neu (i.e., ERBB2) may be declared “positive” if the test indicates three or more copies of the gene are present.

### Precision/Reproducibility

#### Repeatability/Precision

Repeatability is defined as replication of results when the assay is performed multiple times on a single specimen. Repeatability is also referred to as precision when the test result is expressed quantitatively.16 Both Dimech et al. and Prence recommend testing a dilution series, with each sample tested at least 20 times, to establish the precision of the assay.21, 26 The degree of precision is commonly expressed in terms of the coefficient of variation (CV) of the test.

Nygarrd et al. have reported that the repeatability of PCR amplification from small-size samples is limited.27 Although samples with small amounts of starting mRNA can reproducibly be amplified, when the sample size (defined as number of cells) falls below certain levels, the proportion of transcript in the original material is not reproducibly maintained in the amplified material. For example, in samples of 1000 cells, only transcripts expressed with at least 121 transcripts per cell were reliably amplified in proportions representative of the starting material, and for samples of 250 cells, only transcripts expressed at 1806 or more copies per cell reliably amplified in proportions representative of the starting material. These results have important implications for test assays that rely on microdissected cells or other extremely small samples.27

#### Reproducibility

Reproducibility refers to replication studies assessing day-to-day and operator-to-operator precision. If multiple instruments are used, instrument-to-instrument reproducibility should be assessed; if the test is performed in multiple laboratories, site-to-site reproducibility should also be assessed.9 We identified one study that discussed how reproducibility of molecular test assays should be assessed, the details of which are described below.21

#### Type of Sample Tested

Reproducibility studies may be performed on the same dilution series used to establish the precision of the test.21 However, if the assay incorporates an extraction step, reproducibility of the extraction step should be incorporated into the validation studies, and likewise for any other steps of the procedure.

#### Number of Samples Tested

Dimech et al. recommend performing reproducibility testing at clinically critical cut-points covering the assay’s measurement range at no more than ten times this level.21

#### Performance Near Clinically Critical Cut-points and Covering the Assay’s Detection Range

Reproducibility studies of assays should provide an estimate of the precision of the method at analyte concentrations near the cut-off threshold and at clinically critical cut-points covering the assay’s measurement range.21

### Assay Linearity, Recovery, and High-dose Hook Effect

Assay linearity is defined by the Clinical Laboratory Standards Institute (CLSI) as “the ability (within a given range) to provide results that are directly proportional to the concentration (amount) of the analyte in the test sample.”28 Linearity of tests is established by testing a dilution series of a positive sample.21 The term “recovery” refers to “the measurable increase in analyte concentration or activity in a sample after adding a known amount of that analyte to the sample.”28 For some quantitative tests to give accurate results, there must be an excess of reagents, relative to the analyte being detected. As the concentration of analyte begins to exceed the amount of reagent, the dose response curve will plateau, and with further increase may paradoxically become negatively sloped in a phenomenon termed “High-Dose Hook Effect.” Failure to validate the potential for high-dose hook effect (by linear dilution of samples) can result in severe underestimation of the true amount of the analyte.

### Analytic Sensitivity or Lower Limit of Detection/Quantitation

Analytical sensitivity describes how effectively a test can detect all true positive specimens. Alternatively, for quantitative tests, analytic sensitivity (also referred to as the lower limit of detection), may be defined as the smallest quantity of a substance that can be reliably detected or quantified. For example, for a molecular test the lower limit of detection could refer to the lowest number of organisms or RNA copies that can be reliably and reproducibly detected by the assay. This parameter is established by serially diluting samples and running the assay repeatedly.20 The World Health Organization (WHO) has established that limits of detection for certain targets should be expressed as IU/ml.16 Standard reference materials to establish an absolute measure of limit of detection for molecular tests are currently limited to a few viruses (hepatitis B and HIV) and a genetic test for the Factor V Leiden mutation, which causes a coagulation disorder.29, 30

### Analytical Specificity

Analytical specificity refers to the ability of a test to measure the target substance when potentially interfering or cross-reacting substances are present in the specimen. For example, with many standard chemistry tests, the presence of hemolysis or bilirubin in the sample would cause interference with measurement of the desired substance. Potential for cross-reactivity is often not fully investigated during validation of molecular tests for practical reasons. For example, a real-time PCR assay intended to amplify DNA from a particular strain of bacteria cross-reacts with and also amplifies DNA from a different strain of bacteria. In order to detect this cross-reaction the developers of the test would have to first suspect it may occur and then somehow obtain suitable samples to verify the effect. Alternatively, the cross-reaction may be detected accidently during the validation process. However, careful design of primers can reduce the potential for cross reactivity. The chosen sequence should be compared to genome sequences in appropriate databases to confirm the specificity of the primer.21 Dimech et al. suggest creating a sample spiked with a high concentration of potentially cross-reacting organisms and human cells to test for analytical specificity.21

### Matrix Effects

The term “matrix effects” refers to the combined effect of all components of the sample other than the analyte on the detection or value of the measurement of the analyte. The potential for matrix effects is often a concern when using external controls that differ from fresh specimens typically used in a clinical laboratory. CLSI distinguishes this concept from “interference,” which implies an identified substance or property (e.g., pH, surface tension, viscosity) of the patient sample, control sample or calibration material that alters the test result.31 In the context of molecular testing, the most commonly encountered matrix effect is the presence of substances in the sample that inhibit PCR reactions. Such substances are commonly encountered and may cause false-negative results or under-estimation of the amount of the target substance in the sample. However, inclusion of an endogenous or spiked exogenous control in the test methodology can sometimes detect or control for this possibility.19, 20

An internal control can be constructed that contains nucleic acid of a different size and sequence than the target, but with the same target primer sequences at each end; once constructed, the control can be added to each sample before beginning the assay. Alternatively, a housekeeping gene (a gene expressed in virtually all cell types) such as -globin can be simultaneously amplified along with the target sequence.20 Ambion manufactures ready-to-use RNA products (Armored RNA) that can be used as controls in many types of assays.20

Other possible causes of matrix effects include cross-contamination during sample processing, inclusion of normal, non-diseased tissue with the diseased tissue of interest (e.g., normal tissue contained within a tumor block), and tissue from a source additional to the desired sample (e.g., blood cells in a biopsy specimen). Sources of cross-contamination should be assessed and preventive measures taken accordingly.32

### Quality Assurance for Commercial Reagents

Manufacturers of both analyte-specific reagents and general laboratory reagents are required by FDA to follow current Good Manufacturing Practices.33 Forbes recommends that laboratories ensure the quality of PCR test reagents by performing functional validation assays to determine the efficacy of new reagents run in parallel with old reagents.20 Most “good laboratory practice” guidelines concur with this suggestion.9, 34, 35

### Pre-analytical Factors Influencing Assay Results

Pre-analytical factors that can influence assay results include type of specimens (e.g., fixed tissue vs. fresh-frozen tissue), how specimens are collected, proper processing and storage to prevent contamination or degradation of the sample, and transport of the sample. The methods used to extract nucleic acid from the samples, if performed, can also influence the results.

### Assay Output

Assay output is the raw data generated from a molecular test procedure. Numerous options exist for presenting the output of molecular tests, but the data require further clinical interpretation in conjunction with controls and patient information before clinical laboratory reports can be issued.36

### Systematic Reviews Addressing Analytic Validity

Literature searches identified two systematic reviews addressing analytic validity. As part of a technology assessment prepared for AHRQ in 2006, Matcher et al. addressed the analytic validity of the tests for detection of cytochrome p450 polymorphisms in adults with depression.37 They stated that the “gold standard” reference for these tests is bidirectional sequencing. In this method, forward and reverse primers are utilized, permitting confirmation of the sequence in the region of the mutation. They identified 12 published articles and two documents from the FDA Web site (on performance of the Roche AmpliChip®) that described methods for genotyping various CYP450 enzymes. Only four of the studies used the “gold standard” reference of DNA sequencing; the others compared their results to other methods of genotyping, or to published allele frequencies in populations similar to the ones employed in the study. Sensitivity and specificity were generally high (in the range of 94 to 100 percent) for the various tests. Sample sizes used in the validation studies ranged from approximately 50 to approximately 400, of which most were negative for any of the target polymorphisms; the numbers of positive samples were generally very low, in the single digits for most of the tests and polymorphisms. Some of the validation studies also reported on the reproducibility and repeatability of the tests. Repeatability assays varied, and were performed on one to four samples anywhere from only twice to up to 12 times. Reproducibility assays also varied, and may have incorporated between-laboratory, between-operator, and day-to-day assays; however, few studies reported performing all three types of reproducibility assays.

Another systematic review performed by the Johns Hopkins EPC under contract to AHRQ was released in 2008. In this review, the authors examined analytic and clinical validity of three currently marketed molecular tests for risk stratification of patients with breast cancer. They found limited published evidence for analytic validity, with the most complete documentation being for the Oncotype DX® assay (Genomic Health, Inc., Redwood City, CA). The authors noted that, given the absence of reference standards, the majority of published analytical validation studies only addressed repeatability and reproducibility rather than the other test properties discussed above.38 Unpublished validation data may be available in the testing laboratory.

### Establishment of Analytic Validity for Molecular Tests - Examples

Our searches revealed that few validation studies of laboratory-developed or commercially available molecular tests have been published. We selected a few tests representing the following categories relevant to the Medicare population:

- tests used for diagnostic purposes in symptomatic individuals,
- tests used as prognostic indicators,
- tests used to monitor response to therapy, and
- tests used to choose therapies for a known disease entity or used to adjust medication dosing.

#### Tests Used for Diagnosis in Symptomatic Individuals: Parkinson’s Disease

Some commercial laboratories, such as Athena Diagnostics,39 offer genetic tests to aid in diagnosis of Parkinson’s disease (PD). We were unable to identify any published validation studies of these specific laboratory-developed tests. However, the Wadsworth Center published a clinical and analytical validation study of a genetic test to aid diagnosis of Parkinson’s disease (PD) in 2006.^40^ This validation study is typical for molecular tests used for diagnosis.

PD is a progressive neurodegenerative disorder. Differential diagnosis of PD can be complicated, especially in the early stages of the disease. At present, a definitive diagnosis can only be achieved after death by examination of the brain. PD is caused by both genetic and environmental factors. A number of mutations of different genes have been linked to PD. Mutations in the gene LRRK2 are associated with the most common forms of PD, and the most commonly identified mutation in LRRK2 is G2019S.

The validation study published by the Wadsworth Center recruited 1518 individuals diagnosed with PD and 1733 without PD (a case-control study). The test being validated uses genomic DNA purified from peripheral blood and employs a real-time PCR (Taqman) assay. All identified mutations were verified by direct sequencing, and results from a random sample of 26% of the subjects were also verified by direct sequencing. The sequencing verified that the Taqman assay had 100% sensitivity and specificity in detecting the mutation. The sensitivity of the assay in diagnosing PD was poor, only 1.3%, but the specificity was very high at 99.9%. The authors concluded that the test may have clinical utility for confirming the diagnosis of PD in a subset of suspected cases. They further speculated that the detection of the mutation in asymptomatic carriers will predict a substantially increased risk of PD, but does not guarantee that the individual will develop PD nor can it predict age at onset.

As discussed previously, case-control studies tend to over-estimate the accuracy of diagnostic tests. The case-control design of this study weakens its claim to have established the clinical validity of this test (further discussion of clinical validity and utility of molecular testing is in the next chapter). Verification of mutation identification by sequencing does establish the analytical accuracy of the test. However, other aspects of analytic validity, such as reproducibility and repeatability, were not addressed in the published report.

#### Tests Used for Diagnosis and Monitoring: Heptimax®

Heptimax® is a laboratory-developed test developed by Quest Diagnostics. The test is used to confirm active hepatitis C viral (HCV) infection, to monitor response to HCV therapy, and to confirm resolution of infection.41 The test uses real-time PCR to measure viral load in plasma.

HCV infection is a major cause of hepatic disease. Acute HCV infection is often asymptomatic and often is not diagnosed. Most patients then go on to develop chronic HCV infection, which is associated with increased risk of cirrhosis of the liver and hepatocellular carcinoma.

Quest Diagnostics has not published a validation study of Heptimax in the peer-reviewed medical literature. Unpublished data may be available in the testing laboratory. The company reports the range of the assay as 5 to 50,000,000 IU/ml on its Web site.42 The Web site references seven publications as supporting the clinical utility of the test, but none of the published studies appear to have actually used or studied Heptimax® specifically.42

#### Tests Used to Determine Prognosis and Guide Choice of Therapy: Oncotype DX®

The Oncotype DX® assay is a gene-profiling assay that uses real-time PCR to measure the expression levels of a panel of 21 genes in breast tumor tissue samples. Physicians use a sample kit provided by Genomic Health to send fixed, paraffin-embedded breast tumor tissue to the Genomic Health laboratory. Within two weeks of specimen receipt, the laboratory reports a “recurrence score” of 0 to 100 and an explanation of the estimated risk of tumor recurrence associated with that score. The assay results are intended to be used in conjunction with other clinical information to guide treatment decisions. Although the Oncotype DX® assay may fall into the in vitro multivariate index assay (IVDMIA) class that the FDA has recently declared interest in regulating, it has been marketed since 2004 as a laboratory-developed test, and its publication history is instructive. One of the systematic reviews of clinical validity that we identified (Lyman et al.43) reviewed the Oncotype DX® assay and other similar assays intended to predict the likelihood of breast cancer recurrence. Clinical validity is addressed in detail in the next chapter.

On the company’s Web site, Genomic Health lists five published studies that were used to develop the Oncotype DX® assay.44 After development of the assay, the company published one analytical validation study and two clinical validation studies. The analytical validation study was performed on a pooled sample of fixed tissues. The study reported data on the reproducibility (across instruments, operators, reagents, and day-to-day variation) and the repeatability (multiple assays run on the same sample) of the assay, and the linear performance of the assay over a broad range of sample concentrations.45 The authors of the study reported that analytical accuracy could not be assessed because there is no standard reference material for each of the 21 analytes. They did measure quantitative bias by comparing predicted RNA concentrations for each gene to expected RNA concentrations calculated for a range of sample dilutions.

#### Tests Used to Adjust Medication Dosing: Genetic Testing to Guide Warfarin Dosing

Warfarin is an oral anticoagulant prescribed to treat a variety of health conditions. Warfarin acts by interfering with the synthesis of clotting factors in the liver. Bleeding is a common adverse event associated with taking warfarin, and establishing the safe and effective dose of warfarin for each patient can be difficult. Certain polymorphisms in the genes CYP2C9 (which encodes the protein cytochrome P450 2C9) and VKORC1 (which encodes vitamin K epoxide reductase complex subunit 1) affect the metabolism and action of warfarin. In August 2007, the FDA updated the product label for warfarin (Coumadin®) to include genetic variations in CYP2C9 and VKORC1 as factors to consider for more precise initial dosing.46

At least three laboratories offer laboratory-developed tests for genetic variations in CYP2C9 and VKORC1: Genelex’s Warfarin Target Dose Safety Test,47 Clinical Data Inc.’s PGxPredict: Warfarin™,48 and Kimball Genetics Inc.’s Warfarin Dose Advise™.49 However, we were unable to identify any published studies validating these tests, and the company Web sites contained no information about their development or validation.

A number of kits to assess genetic variation in CYP2C9 and/or VKORC1 have received clearance for marketing from the FDA under the 510(k) process (refer to Table 26 in Appendix B). For example, the Verigenen Warfarin Metabolism Nucleic Acid Test (Nanosphere, Inc., Northbrook, IL) was cleared in September 2007.^50^ The company reported information about their test’s accuracy relative to bi-directional sequencing, reproducibility, limit of detection, and lack of interference by five common contaminants to the FDA as part of their 510(k) application.

Roche Molecular Systems, Inc. received 510(K) clearance of a test to evaluate genetic variation of CYP2C19 and CYP2D6 in December 2004 (Roche Amplichip CYP450).51 Validation studies of the Amplichip for use in guiding medication dosing (medications for depression) were evaluated in the Matcher et al. systematic review, discussed above.37