# What Types of Laboratory-Developed Molecular Tests Are Currently Available for Conditions Relevant to the Medicare Over-65-Year-Old Population?

For Key Question 1, we were asked to identify and catalogue laboratory-developed molecular tests (LDMTs) currently being performed that may be relevant to the Medicare over-65-year-old population. Particularly, we were asked to include tests used for the following purposes:

- to confirm diagnosis in symptomatic individuals;
- to choose therapies for a known disease entity or to adjust medication dosing;
- as prognostic indicators; or
- to make treatment decisions and monitor therapy.

As we described in the previous chapter, we excluded tests used primarily for forensic purposes, to screen donated blood for infectious diseases, to screen for inherited diseases of metabolism or other conditions of greater relevance to the pediatric population, and tests for which there are currently no clinical (diagnostic, prognostic or therapeutic) applications (i.e., tests used primarily for research purposes).

## Methods

To identify LDMTs, we considered scientific literature published in peer-reviewed journals and other publications, giving highest priority to systematic reviews, followed by other publication types, including evaluation studies. We also consulted a variety of gray literature sources, including laboratory Web sites and accrediting organization Web sites, such as the College of American Pathologists (CAP) and the Association for Molecular Pathology (AMP). For this question, we found that the most useful and efficient method of identifying LDMTs was through the AMP Web site (www.amptestdirectory.org).

The AMP is a not-for-profit scientific society founded in 1995^5^, that is dedicated to the advancement, practice, and science of clinical molecular laboratory medicine and translational research.6 AMP membership includes laboratories from academia, government, and industry.5 The AMP members voluntarily list their laboratories and research or clinical molecular tests for inclusion in the AMP test directory. Because membership and listing is voluntary, the AMP test directory is not inclusive of all laboratories or available tests.

Within the AMP Web site, molecular tests are categorized according to the following three conditions: infectious diseases, solid tumors, and hematopathology. The information available from the AMP online test directory is presented in Table 11 in Appendix B. We used the AMP Web site as a starting point for identifying and cataloging molecular tests. This Web site contains information about molecular tests available from most of the laboratories identified in the Statement of Work (SOW) as relevant sources for this report, which include the following:

- Armed Forces Institute of Pathology
- ARUP Laboratories
- Barnes and Jewish Hospital Molecular Diagnostics Laboratory
- Duke University Medical Center
- Mayo Medical Laboratories
- MD Anderson Molecular Diagnostic Laboratory
- Oregon Health and Sciences University
- Targeted Diagnostics and Therapeutics Inc.
- University of Nebraska
- University of Pennsylvania
- University of Utah
- Upstate Medical University
- Vanderbilt University Medical Center
- Yale University

The AMP directory also contains information about available molecular tests from 63 additional laboratories. The AMP test directory did not, however, include test information from the following three commercial diagnostic laboratories identified in the SOW: Quest Diagnostics, LabCorp, and Specialty Labs. To obtain information about tests available through these laboratories, we consulted the individual laboratory Web sites. We assumed, unless otherwise specified, that the tests listed in their comprehensive test catalogues were developed by the individual laboratory.

We also searched the Web sites of two other organizations that collect information about available molecular tests—GENDIA and Genetest. GENDIA (for GENetic DIAgnostics) consists of a network of international laboratories performing molecular genetic testing in the United States, Europe, and Australia. Genetest is a publicly-funded medical genetics resource developed for physicians, other healthcare providers, and researchers. Their Web site provides information on genetic testing and its use in diagnosis, management, and genetic counseling. In all, we obtained test information from 95 laboratories. Table 12 in Appendix B presents a list of all laboratories from which test information was obtained.^1^

1 All laboratories located outside of the United States were excluded from our list.

Once an initial list of tests and laboratories offering each test was compiled, we searched for laboratory-specific information through the laboratory details page located in the AMP test directory. The laboratory details page of the AMP Web site provides a list of all the molecular tests performed by each laboratory along with the information on whether any of the tests were developed by the particular laboratory itself or performed by the laboratory using a “commercial kit.” Unfortunately, the laboratories often do not indicate whether they use a FDA-approved or cleared commercial kit (a full testing system), FDA-cleared analyte specific reagents (ASRs, also called “commercial kits” by some laboratories), and, in some cases, the source of the commercial kit.^2^ Information about commercial kits was also not often available from individual laboratory Web sites. Thus, we conservatively included all tests using “commercial kits”—which could be either full testing systems or laboratory-developed systems using commercial ASRs—in our inventory to decrease the risk of missing significant LDMTs. In our inventory, these tests are tabled separately from confirmed LDMTs.

2 A listing of all FDA-approved test kits as of December 11, 2009, is provided in Table 24 and Table 28.

## Results

Using information from the AMP Web site, the laboratory details page, and individual laboratory Web sites, we created a set of tables that list laboratory-developed molecular tests available as of October 31, 2008, that are relevant to the Medicare over-65 population. The tables are located in Appendix B of this report. Separate tables were created for the following clinical conditions: infectious diseases, solid tumors, and hematopathology. For infectious diseases, separate tables were created for diseases caused by bacterial agents (Table 14 and Table 19), viral agents (Table 15 and Table 20), or fungal or parasitic agents (Table 16). For all clinical conditions, separate tables were created for tests clearly identified as laboratory developed (Table 14 through Table 18), and those available through commercial ASRs or kits (Table 19 through Table 23). We include tables of tests available through “commercial kits” because, as indicated previously, it was unclear from the information provided in the AMP test directory whether the “commercial kits” used by laboratories are FDA-approved full testing systems or ASRs. When specified in the AMP test directory or on individual laboratory Web sites, we indicate the source of the commercial full testing system.

Further information about how the tables are organized is presented in the Guide to Molecular Test Tables section of this report, which is located in Appendix B.

In all, we cataloged 1,441 molecular tests, of which 812 were clearly identified as laboratory-developed tests and 629 were tests that used commercially available full testing systems or ASRs (meaning that some of them are still laboratory developed, if they use commercial ASRs). Table 1 below summarizes the results of our cataloging efforts. The test numbers reported in the table were calculated by ECRI Institute by summing the number of laboratories performing a test for a specific clinical condition. If two laboratories both offer a test developed in-house for the detection of the same clinical condition (e.g., mycobacterium tuberculosis), we counted them as two separate LDMTs. We counted each laboratory separately because testing protocols may vary significantly across the laboratories even though the tests are intended to detect the same pathogen/clinical condition.

Table 1 Summary of Molecular Tests

Test Category | Number of LDMTs | Number of Tests Using Commercial Kits or ASRs | Total Number of Tests
Infectious Disease Tests, Bacterial | 153 | 151 | 304
Infectious Disease Tests, Viral | 259 | 214 | 473
Infectious Disease Tests, Parasitic or Fungal | 34 | 0 | 34
Solid Tumor Tests | 145 | 97 | 242
Hematopathology Tests | 221 | 167 | 388

Overall, we cataloged 811 molecular tests for infectious diseases. The majority of these tests used PCR (including PCR-based methods and PCR-like nucleic acid amplification techniques) as the testing method, and were used to confirm diagnosis. Of these 811 tests, 304 tests were used for bacterial infectious diseases that covered a wide range of conditions, including clostridium difficile, legionella pneumophilia, and mycobacterium tuberculosis. Most tests using commercial kits or commercially available ASRs were for tuberculosis (n = 29), and in most cases, Gen-Probe was the laboratory that supplied the test kit (n = 24). No one condition appeared more prevalent among the laboratory-developed tests.

Tests used for viral infectious diseases also covered a number of conditions, ranging from cytomegalovirus to West Nile virus. The majority of tests, both in-house and commercially available, were for the following conditions: hepatitis (in-house = 20, commercial = 67), herpes simplex virus (in-house = 63, commercial = 5), and human immunodeficiency virus (in-house = 9, commercial = 77). Finally, tests used for parasitic- or fungal-related infectious diseases covered a number of conditions, ranging from blastomyces dermatitidis to toxoplasma gondii.

Overall, we cataloged 630 molecular tests currently available for clinical use in oncology, including solid tumors and hematological malignancies. Most of these tests are for the purpose of diagnosis; only limited numbers of tests are for disease monitoring or for determining treatment strategies. The most commonly used techniques in these tests are PCR and FISH. Breast cancer, colorectal cancer, sarcomas, acute myeloid leukemia, and B and T cell neoplasms are the conditions that have the highest number of tests (or laboratories offering the tests) available.