# Guidelines and Standards for Molecular Testing

Table 35 Organization Abbreviations

Organization | Abbreviation
American College of Medical Genetics | ACMG
AIDS Clinical Trials Group | ACTG
Clinical Molecular Genetics Society | CMGS
College of American Pathologists | CAP
Centers for Disease Control and Prevention – Morbidity and Mortality Weekly Report | CDC/ MMWR
Clinical Laboratory Standards Institute | CLSI
DynCorp Health Research Services | N/A^1^
European Commission | N/A^1^
European Co-operation for Accreditation | N/A^1^
European Molecular Genetics Quality Network | EMQN
U.S. Department of Health and Human Services/Food and Drug Administration | HHS/FDA
Minimum information about a microarray experiment | MIAME
National Academy of Clinical Biochemistry | NACB
National Human Genome Research Institute | NHGRI
New South Wales Department of Health | NSW Department of Health
New York State Department of Health – Wadsworth Center | N/A^1^
Organisation for Economic Co-Operation and Development | OECD
Standards Unit, Evaluations and Standards Laboratory | N/A^1^
Swiss Society of Medical Genetics | N/A^1^

1 Abbreviations have not been used for these organizations.

Table 36 Guidelines and Standards for Laboratories Performing Molecular Tests

Organization | Title | Purpose | Description | Year | Reference
ACMG | Standards and Guidelines for Clinical Genetics Laboratories Technical Standards & Guidelines: Molecular Genetic Testing for Ultra-Rare Disorders | An overview of the specific issues that arise when performing molecular diagnosis for disorders in which the test is available in only one laboratory or very few laboratories. | Specific Issues addressed include custom mutation analysis and prenatal diagnosis, choice of analytic technique to identify private mutations, concerns about test validation, and interpretation of results. | 2006 | 162
ACMG | Standards and Guidelines for Clinical Genetics Laboratories | These voluntary standards have been established as an educational resource to assist medical geneticists in providing accurate and reliable diagnostic genetic laboratory testing consistent with currently available technology and procedures in the areas of clinical cytogenetics, biochemical genetics and molecular diagnostics. | Section G: Clinical Molecular Genetics: Specifically refers to the use of molecular techniques to examine heritable or somatic changes in the human genome. Some of the topics covered include specimens & records, quality control, DNA preparation, assay validation, hybridization, PCR methodologies, controls and standards, and RT-PCR. | 2006 | 8
ACTG | Virology Quality Assessment (VQA) Program Testing Requirements for New Laboratories to Obtain Approval for HIV DNA Testing in NIH-Funded Protocols | Lists requirements for HIV DNA testing approval | Areas covered include pre-certification and certification testing; re-certification; normal and fast track approval; continued approval; withdrawal/removal from proficiency program; and proficiency test panels. | 2004 | 151
CAP | Laboratory Accreditation Program - Molecular Pathology Checklist | Laboratory accreditation checklist used in preparation for an inspection of a laboratory | Topics covered include proficiency testing, quality management and quality control, personnel, physical facilities and equipment, laboratory safety, and radiation safety | 2007 | 163
CDC/ MMWR | Good Laboratory Practices for Waived Testing Sites | Summarizes study findings and provides recommendations developed by the Clinical Laboratory Improvement Advisory Committee for conducting quality waived testing. | These recommendations include considerations before introducing waived testing, such as management responsibility for testing, regulatory requirements, safety, physical and environmental requirements, benefits and costs, staffing, and documentation, and good laboratory practices throughout the testing process. | 2005 | 161
CDC/MMWR | Guidelines for Laboratory Test Result Reporting of Human Immunodeficiency Virus Type 1 Ribonucleic Acid Determination | Provides guidelines for standardized reporting of viral load test results by licensed laboratories to healthcare providers and facilities for public health case reporting of HIV infection and AIDS | Topics addressed include available viral load tests, laboratory practices for HIV viral load testing, variation among laboratory viral load test reports, and recommendations for reports and documentation. Recommended standards were developed through data review, input from physicians and laboratories, and an assessment of laboratory practices. | 2001 | 160
CLSI | Molecular Diagnostic Methods for Infectious Disease; Approved Guideline 2nd Edition | This guideline describes general principles for the development, evaluation, and application of tests designed for direct detection of microorganisms in clinical specimens and for identification of microorganisms grown in culture. | Addresses topics relating to clinical applications, amplified and non-amplified nucleic acid methods, selection and qualification of nucleic acid sequences, establishment and evaluation of test performance characteristics, inhibitors, and interfering substances, controlling false-positive reactions, reporting and interpretation of results, quality assurance, regulatory issues, and recommendations for manufacturers and clinical laboratories. | 2006 | 149
CLSI | Molecular Diagnostic Methods for Genetic Diseases; Approved Guideline 2nd Edition | Provides guidance for the use of molecular biological techniques for clinical detection of heritable mutations associated with genetic disease. | Recommendations cover nomenclature for human pedigrees and the designation of mutations; laboratory safety; and “front-end” activities, such as intake information, specimen identification and accessioning, and sample preparation. Other topics addressed are molecular analytical techniques, test validation and characterization, quality assurance, results reporting, and selection of referral laboratories. | 2006 | 13
CLSI | Genotyping for Infectious Diseases: Identification and Characterization; Approved Guideline | Provides guidance for the development and use of genotyping methods (DNA sequencing, single nucleotide polymorphism-SNP detection, real-time target amplification techniques of target sequences specific to particular microorganisms to identify the clinically important genetic characteristics responsible for disease manifestation, outcome, and response to therapy in the infectious disease setting. | An update on technologies used for molecular genotyping; preparation; standards, calibrators, and reference materials; analytical and clinical verification/validation; reporting and interpreting results; and the determination of clinical utility of such testing. | 2006 | 150
CLSI | Proficiency Testing (External Quality Assessment) for Molecular Methods; Approved Guideline | This guideline complements currently available regulatory guidance documents regarding the management and operation of proficiency testing programs. | This document addresses people who produce, distribute, and administer proficiency testing materials. A guide for laboratories in best practices; serve as a benchmark for evaluation of new programs, and discuss assignment of target result; distribution, receipt, and evaluation of data; and reporting responsibilities. | 2005 | 157
CLSI | Collection, Transport, Preparation, and Storage of Specimens for Molecular Methods; Approved Guideline | This document provides guidance related to proper and safe biological specimen collection and nucleic acid isolation and purification. | Topics include methods of collection, recommended storage and transport conditions, and available nucleic acid purification technologies for each specimen/nucleic acid type. | 2005 | 158
CLSI | Use of External RNA Controls in Gene Expression Assays; Approved Guideline | Provides protocols supporting the use of external RNA controls in microarray and QRT-PCR-based gene expression experiments. | This guideline addresses important issues associated with the use of external RNA controls as a tool for verification of technical performance, and in support of the evaluation of qualitative results for a specific clinical analyte including preparation of control transcripts, design of primers and amplicons, quality control, use in final experimental or clinical test application, and the analysis and interpretation of data obtained. | 2006 | 159
CLSI | Verification and Validation of Multiplex Nucleic Acid Assays; Proposed Guideline | This guideline provides recommendations for analytic verification and validation of multiplex assays, as well as a review of different types of biologic and synthetic reference materials. | Topics covered include sample preparation, a general discussion of multiplex methods and technologies, reference and quality control materials, analytic verification and validation, data analysis, and reporting of results. | 2007 | 15
CLSI | Immunoglobulin and T-cell Receptor Gene Rearrangement Assays; Approved Guideline | Helps laboratorians perform and interpret gene rearrangement assays. | This document includes indications for gene rearrangement analysis and acceptable methods for specimen collection, transport, and processing. Recommendations for assessing specimen adequacy, as well as technical methods for conducting gene rearrangement assays, information on sensitivity, specificity, controls, and test interpretation. Quality assurance procedures are included throughout the document. | 2002 | 170
CLSI | Nucleic Acid Amplification Assays for Molecular Hematopathology; Approved Guideline | This guideline addresses the performance and application of assays for gene rearrangement and translocations by both polymerase chain reaction (PCR) and reverse transcriptase (RT) PCR techniques. | The topics covered include indications for molecular biologic testing, specimen collection, transport, and processing; assessment of specimen adequacy; conduct of amplification-based molecular hematology assays; sensitivity, specificity; controls; and artifacts; quality assurance; and interpretation of results. | 2003 | 12
CLSI | Fluorescence In Situ Hybridization (FISH) Methods for Medical Genetics; Approved Guideline | This guideline has been developed to ensure appropriate and reliable use of FISH technology in medical genetics laboratories. | Provides useful recommendations for FISH assay developers, manufacturers, diagnostic genetic laboratories, and regulatory agencies. | 2004 | 14
CLSI | Nucleic Acid Sequencing Methods in Diagnostic Laboratory Medicine; Approved Guideline | This guideline addresses automated, PCR-based, dideoxy-terminator, and primer extension sequencing done on gel- or capillary-based sequencers. | This guideline specifies recommendations for all aspects of the sequencing process including specimen collection and handling, isolation of nucleic acid, amplification and sequencing of nucleic acids, and general interpretation and reporting of genotyping results. | 2004 | 171
CLSI | Diagnostic Nucleic Acid Microarrays; Approved Guideline | This guideline provides recommendations for many aspects of the array process including: method overview; nucleic acid extraction; the preparation, handling, and assessment of genetic material; quality control; analytic validation; and interpretation and reporting of results. | The guideline addresses array-based detection variations in DNA sequence and gene expression analysis as it relates to: heritable variations, somatic changes, methylation profiling, pathogen profiling including antibiotic resistance analysis, expression profiling, and gene dosage/comparative genomic hybridization. | 2006 | 11
CMGS | Practice Guidelines for Internal Quality Control within the Molecular Genetics Laboratory | This guideline provides recommendations for the internal quality control of testing samples. | The specific areas discussed in sample reception, recording sample data (e.g., arrival time, labeling), and DNA extraction. | 2004 | 152
DynCorp Health Research Services | General Recommendations for Quality Assurance Programs for Laboratory Molecular Genetic Tests | To characterize the focus of quality assurance and proficiency testing methods in molecular genetic testing for human heritable disease, and to develop recommendations as to how molecular genetic testing can be enhanced, so that laboratory practice may more closely approximate performance goals. | Topics addressed include descriptions of technologies and current quality assurance and proficiency testing programs. Recommendations to improve the quality of laboratory practices for the benefit of public health are detailed within this report. | 1999 | 168
EMQN | Draft Best Practice Guidelines for Laboratory Internal Quality Control | Provides information regarding laboratory internal quality control. | Topics covered include sample reception/storage, DNA extraction, sample handling, controls, results, reporting, documentation, audit, validation, and staff training. | 2002 | 34
European Commission | Guidance Document on the Use of Reference Materials in Genetic Testing | The aim of this guidance document is to provide a short and user-friendly support to genetic testing laboratories | Topics covered include metrological context and terminology, availability of reference materials, patent issues related to reference materials, selection criteria for reference materials according to their use, and application guidance. | 2008 | 164
European Commission | 25 Recommendations on the ethical, legal, and social implications of genetic testing | Recommendations developed by experts from various backgrounds relevant to the ethical, legal, and social implications of genetic testing | The recommendations are organized into three categories: general framework, implementation of genetic testing in healthcare systems, and genetic testing as a research tool | 2004 | 166
European co-operation for Accreditation | Use of Proficiency Testing as a Tool for Accreditation testing | The objective of this document is to ensure a consistent good practice for Accreditation Bodies (Abs) and laboratories in the cost-effective use of proficiency testing in accreditation. | This document is to help and unify accreditation bodies’ and testing laboratories’ understanding concerning the use of proficiency testing in accreditation. It also provides guidance in the use of different types of proficiency testing to support evidence of testing laboratories’ competence within their scope of accreditation. | 2001 | 165
FDA | Guidance for Industry and FDA Staff Commercially Distributed Analyte Specific Reagents (ASRs): Frequently Asked Questions | This guidance document is intended to clarify the regulations regarding commercially distributed analyte specific reagents (ASRs) and the role and responsibilities of ASR manufacturers. | This guidance addresses some frequently asked questions about how ASRs may be marketed, and provides FDA’s Office of In Vitro Diagnostic Device Evaluation and Safety’s (OVID’s) and the Center for Biologics Evaluation and Research’s (CBER’s) responses to those questions. | 2007 | 33
FDA | Draft Guidance for Industry, Clinical Laboratories, and FDA Staff - In Vitro Diagnostic Multivariate Index Assays (IVDMIAs) | Guidance addresses the definition and regulatory status of a class of In Vitro Diagnostic Devices referred to as In Vitro Diagnostic Multivariate Index Assays (IVDMIAs) | FDA seeks to dispel the existing confusion about the regulation of IVDMIAs that are developed by, and used in, a laboratory, and clarify its approach to regulating IVDMIAs. | 2006 | 93
MIAME | The MIAME Checklist | Guide authors, journal editors and referees in helping them to ensure that the data supporting published results based on microarray experiments are made publicly available in a format that enables unambiguous interpretation of the data and potential verification of the conclusions. | The topics covered include experiment design; samples used, extract preparation, and labeling; hybridization procedures and parameters; measurement data and specifications; and array design. | 2005 | 153
NACB | Guidelines and Recommendations for Laboratory Analysis and Application of Pharmacogenetics to Clinical Practice | To provide a systematic rigorous assessment of the discipline of pharmacogenetics as it applies to clinical laboratory testing and its application to clinical practice. | Issues addressed include methodological (pre-analytical and analytical) considerations, standardization and quality assurance of testing; selection of appropriate pharmacogenetics testing profiles; recommended reporting of test results and interpretation; standards needed for demonstration of clinical utility and efficacy; and, regulatory and other recommendations for effective use of pharmacogenetic information in a clinical setting. | 2006 | 148
New York State Department of Health - Wadsworth Center | Clinical Laboratory Evaluation Program (CLEP) - Guide to Program Requirements and Services | CLEP has three objectives: 1) to monitor, improve, and broaden the clinical capabilities of participating laboratories and blood banks; 2) to provide guidelines, quality control standards and procedures to be used by permit-holding clinical facilities; 3) to provide continuing education opportunities for technical personnel involved in the operation of clinical laboratories through training and remediation programs. | This guide provides information for application procedures, personnel requirements, laboratory surveys, and proficiency testing. | 2005 | 154
NHGRI | Promoting Safe and Effective Genetic Testing in the United States | The goal of this report is to recommend policies that will reduce the likelihood of damaging effects of genetic testing so the benefits of testing can be fully realized by undiluted harm. | This report suggests a framework for ensuring that new tests meet criteria for safety and effectiveness before they are unconditionally released, thereby reducing the likelihood of premature clinical use. | 1997 | 172
NSW Department of Health | Genetic Testing - Guidelines for Prioritizing Genetic Tests | Developed to assist clinicians and health services to prioritize genetic test requests based on clinical need, equity of access and within available funding levels. | This guideline provides information on the NSW Department of Health priority system as a guide to appropriate genetic testing. The areas covered are prenatal, diagnostic, carrier, and presymptomatic and predictive testing. | 2007 | 155
OECD | Guidelines for Quality Assurance in Molecular Genetic Testing | Guidelines comprise principles and best practices for quality assurance in molecular genetic testing for clinical purposes. | The guidelines seek to assist both OECD and non-OECD member countries in the development and introduction of appropriate quality assurance procedures. | 2007 | 169
Standards Unit, Evaluations and Standards Laboratory | Good Laboratory Practice When Performing Molecular Amplification Assays | This guidance note describes key elements of how to organize facilities for polymerase chain reaction (PCR) testing including workflow, reagents, consumables, and staff. | This document describes procedures that will help minimize the carry-over of amplified DNA, and are most relevant where “in-house” assays are in use. | 2006 | 35
Swiss Society of Medical Genetics | Best Practice Guidelines on Reporting in Molecular Genetic Diagnostic Laboratories in Switzerland | The aim of the guidelines is to improve the quality of reporting in Switzerland and to help laboratories to provide the most understandable and complete reports of their analyses. | This text presents best practice guidelines for Swiss laboratories reporting molecular genetic diagnostic testing of constitutional mutations. | 2003 | 167

ACMG American College of Medical Genetics

ACTG AIDS Clinical Trials Group

CAP College of American Pathologists

CDC/ MMWR Centers for Disease Control and Prevention – Morbidity and Mortality Weekly Report

CLSI Clinical Laboratory Standards Institute

CMGS Clinical Molecular Genetics Society

EMQN European Molecular Genetics Quality Network

FDA Food and Drug Administration

MIAME Minimum information about a microarray experiment

NACB National Academy of Clinical Biochemistry

NHGRI National Human Genome Research Institute

NSW Department of Health New South Wales Department of Health

OECD Organisation for Economic Co-Operation and Development