# Evidence Tables for Chapter 3: Clinical Validity and Utility

Table 29 Quality of Systematic Reviews

Checkpoint | Was an ‘a priori’ design provided? | Was there duplicate study selection and abstraction? | Was a comprehensive literature search performed? | Was the status of publication (i.e., English only) used as inclusion criterion? | Was a list of studies (included and excluded) provided? | Were the characteristics of the included studies assessed and documented? | Was the scientific quality of the included studies assessed and documented? | Was the scientific quality of the included studies used appropriately in formulating the conclusions? | Were methods used to combine the findings of studies appropriate? | Was the likelihood of publication bias assessed? | Was any conflict of interest stated? | Overall Rating
Blue Cross and Blue Shield Association 2008^80^ | Yes | CA | Yes | CA | No | Yes | Yes | Yes | Yes | CA | Yes | Moderate
Blue Cross and Blue Shield Association 2008^81^ | Yes | CA | Yes | CA | No | Yes | Yes | Yes | Yes | CA | Yes | Moderate
Blue Cross and Blue Shield Association 2008^82^ | Yes | CA | Yes | Yes | No | Yes | Yes | Yes | Yes | CA | Yes | High
Marchionni et al. 2008^38^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | High
National Institute for Health Research 2007^69^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes | High
Dendukuri et al. 2007^72^ | CA | CA | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | High
Mocellin et al. 2007^71^ | CA | CA | Yes | CA | No | Yes | Yes | Yes | Yes | Yes | Yes | Moderate
Greco et al. 2006^64^ | CA | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | High
Lyman & Kuderer 2006^43^ | CA | Yes | Yes | No | No | Yes | CA | CA | Yes | Yes | No | Moderate
Matcher et al. 2006^37^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | CA | CA | Yes | High
Flores et al. 2005^66^ | CA | Yes | Yes | No | No | Yes | Yes | Yes | Yes | Yes | Yes | High
Morgan et al. 2005^65^ | Yes | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | High
Sanderson et al. 2005^83^ | CA | Yes | Yes | CA | No | Yes | Yes | Yes | Yes | No | No | Moderate
Pakos et al. 2004^73^ | CA | Yes | Yes | No | No | Yes | Yes | Yes | Yes | Yes | No | Moderate
Pai et al. 2004^56^ | CA | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | High
Paraskevaidis et al. 2004^75^ | No | CA | Yes | Yes | No | Yes | Yes | Yes | Yes | No | No | Moderate
Zielinski et al. 2004^74^ | CA | CA | No^*^ | Yes | Yes | Yes | No | No | Yes | No | No | Low
Medical Service Advisory Committee (MSAC) 2004^76^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | High
Pai et al. 2003^57^ | CA | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | High
Medical Service Advisory Committee (MSAC) 2003^77^ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | High
Sarmiento et al. 2003^67^ | CA | Yes | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | No | High
Tsao et al. 2001^78^ | CA | Yes | Yes | Yes | No | Yes | Yes | Yes | Yes | No | No | Moderate
Dumler 2001^68^ | No | CA | No | CA | No | No | No | No | Yes | No | No | Low

Source: Shea et al. 2007, AMSTAR: a measurement tool to assess the quality of systematic reviews.52

ECRI Institute applied overall assessment ratings using the following criteria: “High” if a study had mostly yes’s (at least 8), “Moderate” if a mix of yes, no’s, and can’t answer, and “Low” if a study had mostly no’s (at least 8)

CA Can’t answer

NA Not applicable

* The authors of the review only reported searching MEDLINE.

Table 30 Systematic Reviews of Test Properties of Molecular Tests for Infectious Diseases

Review | Purpose | Quality of Review | Outcome | Number of Included Studies | Type of Molecular Test | Reference Standard | Reported Results | Authors’ Conclusions
National Institute for Health Research, 2007^69^ | To evaluate the accuracy of the following tests in patients with suspected TB: NATs tests, amplification molecular probes tests, serodiagnostic and biochemical assays, and phage-based tests^1^ | High | Diagnostic accuracy | 207 (106 used commercial tests and 101 used in-house tests) | PCR | Standard tests (mostly culture) | NAT accuracy was far superior when applied to respiratory samples as opposed to other body fluids. The specificity of NATs was high when applied to body fluids, for example TB meningitis and pleural TB, but sensitivity was poor, indicating that these tests cannot be used reliably to rule out TB. | The NATs provide a reliable way of increasing the specificity of diagnosis, but sensitivity is too poor to rule out disease, especially in smear-negative (paucibacillary) disease where clinical diagnosis is equivocal and where the clinical need is greatest. For extra-pulmonary TB, NATs have high specificity and could be used alongside adenosine deaminase (ADA).
Greco et al. 2006^64^ | To analyze the accuracy of commercially-based NATs used for the diagnosis of TB in smear positive and negative respiratory samples | High | Diagnostic accuracy | 63 | PCR, SDA, TMA, LCR | Culture | Pooled sensitivity and specificity were 96% and 85% among smear positive samples, and 66% and 98% among smear negative samples. Test type had no effect on the DOR, but seemed to be correlated with sensitivity and specificity, probably via threshold effect. | Commercial NATs can be confidently used to exclude TB in patients with smear positive samples, and to confirm TB in a proportion of smear negative cases. The methodological characteristics of primary studies have a considerable effect on reported diagnostic accuracy.
Morgan et al. 2005^65^ | To evaluate the overall accuracy of line probe assay in the detection of rifampicin (RIF)-resistant TB | High | Diagnostic accuracy | 15 | INNO-LIPA Rif. TB kit (Inn genetics, Belgium) | Culture | Twelve of the 14 studies that applied LIPA to isolates had sensitivity greater than 95%, and 12 of 14 had specificity of 100%. The four studies that applied LIPA directly to clinical specimens had 100% specificity, and sensitivity ranged between 85% and 100%. | LIPA is a highly sensitive and specific test for the detection of rifampicin resistance in culture isolates. The test appears to have relatively lower sensitivity when used directly on clinical specimens.
Flores et al. 2005^66^ | To determine factors associated with heterogeneity and higher diagnostic accuracy in studies that evaluated in-house PCR for the diagnosis of TB. | High | Diagnostic accuracy | 84 | PCR | Culture | The sensitivity and specificity estimates varied widely: sensitivity varied from 9.4% to 100%, and specificity estimates ranged from 5.6% to 100%. In meta-regression analysis, the use of IS6110 as a target, and the use of nested PCR methods appeared to be significantly associated with higher diagnostic accuracy. | Estimates of accuracy of in-house NATs for TB are highly heterogeneous, rendering any estimate of the clinical utility difficult.
Pai et al. 2004^56^ | To determine the overall accuracy of NATs used in the diagnosis of tuberculous pleuritis and to identify factors associated with heterogeneity of between-study results. | High | Diagnostic accuracy | 40 (26 used in-house tests and 14 commercial tests) | PCR | Culture | Commercial tests had a low overall sensitivity (62%) and high specificity (98%). With the in-house tests, both sensitivity and specificity estimates were significantly heterogeneous. | Commercial NATs may have a potential role in confirming TB. However, these tests have low and variable sensitivity, and may not be useful excluding disease. The accuracy of in-house tests is poorly defined because of heterogeneity in study results.
Pai et al. 2003^57^ | To determine the accuracy of NATs for tuberculous meningitis | High | Diagnostic accuracy | 49 (35 used in-house tests and 14 commercial tests) | PCR | Culture | The summary estimates in 14 studies with commercial NAA tests were: sensitivity 56% (95% CI: 46% to 66%), specificity 98% (97% to 99%), positive likelihood ratio 35.1 (19.0 to 64.6), negative likelihood ratio 0.44 (0.33 to 0.60), and diagnostic odds ratio 96.4 (42.8 to 217.3). In the 35 studies with in-house tests, the summary accuracy could not be established with confidence because of wide variability in test accuracy. | Commercial kits show a potential role in confirming tuberculous meningitis diagnosis. However, their overall low sensitivity precludes the use of these tests to rule out tuberculous meningitis with certainty.
Sarmiento et al. 2003^67^ | To summarize diagnostic accuracy of PCR methods for the diagnosis of smear-negative TB, identify factors that account for differences in diagnostic accuracy of PCR, and describe characteristics that should be emphasized in future studies | High | Diagnostic accuracy | 50 | PCR | Culture | Sensitivity and specificity of PCR ranged from 9.0% to 100% and from 25 to 100%, respectively. | PCR is not consistently accurate enough to be routinely recommended for the diagnosis of smear-negative TB. Future studies of PCR should be conducted by patient and type of respiratory specimen, blindly, by using a reference standard that combines culture and clinical criteria.
Dumler 2001^68^ | To inform laboratory staff and practitioners about the applications and limitations of molecular microbiological methods for diagnosis of Lyme disease. | Low | Diagnostic accuracy | 36 | PCR | Culture | Median sensitivity ranged from 24% to 76% depending on specimen. Higher sensitivity levels were found in studies using either skin or urine specimens, lowest was in studies using cerebrospinal fluid. The overall median specificity ranged from 99% to 100%. | Molecular assays for Lyme disease are best used with other diagnostic methods, and only in situations in which the clinical probability of Lyme disease is high.

1 The results reported in the table are specific to NATs and other molecular tests.

DOR Diagnostic odds ratio

LCR Ligase chain reaction

LIPA Line probe assay

NATs Nucleic acid amplification tests

NR Not reported

PCR Polymerase chain reaction

SDA Strand displacement amplification

TB Pulmonary tuberculosis

TMA Transcription medical amplification

Table 31 Systematic Reviews of Tests Properties of Molecular Tests for Cancers

Review | Purpose | Quality of Review | Outcome | Number of Included Studies | Type of Molecular Test | Reference Standard | Reported Results | Authors Conclusions
Blue Cross Blue Shield, 2008^80^ | To examine whether the use of gene expression profiling improves outcomes when used to decide whether risk of recurrence is low enough to do without adjuvant chemotherapy for early stage breast cancer. | Moderate | Breast cancer recurrence | Four studies on OncotypeDX met inclusion criteria | OncotypeDX, MammaPrint, and Breast Gene Expression Ratio | Conventional risk assessment tools | Insufficient evidence to determine if MammaPrint and the Breast Gene Expression Ratio is better than conventional risk assessment tools in predicting recurrence. Women classified as high risk by conventional methods and reclassified as low risk by OncotypeDX have a recurrence rate of 10% to 14%. | The authors concluded that “OncotypeDX provides information about the risk of recurrence that is incremental to conventional classifiers used to predict risk.”
Seidenfield et al. 2008^79^ | A systematic review of the evidence on using HER2 testing to manage cancer patients in terms of potential response to trastuzumab among breast cancer patients who have negative, equivocal, or discordant HER2 assay results, guide to selection of breast cancer treatments other than trastuzumab (e.g., chemotherapy), the use of serum HER2 to monitor treatment response or disease progression in breast cancer, and the use of HER2 testing to manage patients with ovarian, lung, prostate, or head or neck tumors. | High | Time to event, tumor response, quality of life | 3 articles plus 1 abstract on use of trastuzumab among HER2-negative or discordant breast cancer patients; 26 articles on chemotherapy or hormonal therapy for breast cancer; 15 articles on plasma or serum HER2 in patients treated for breast cancer; and 26 articles on serum or tissue HER2 in patients with lung cancer, ovarian cancer, head and neck cancer, and prostate cancer. | PathVysion HER2 DNA Probe Kit (fluorescence in situ hybridization, FISH), INFORM HER2/neu Probe (FISH), HER2 FISH pharmDx Kit, Spot-Light (CISH), EnzMet GenePro (SISH), Hercep Test (immunohistochemistry, IHC), PATHWAY (IHC) | NR | The evidence is weak on outcomes of trastuzumab added to chemotherapy for HER2-equivocal, discordant, or negative patients and when comparing chemotherapy outcomes in HER2 positive and negative patient subgroups. Evidence is also weak regarding differences by HER2 status for outcomes of chemotherapy for advanced or metastatic disease and for testing malignancies of lung, ovary, head and neck, or prostate. | Overall, the authors concluded that few studies directly investigated the questions of interest and that future cancer therapy trial protocols should incorporate elements to facilitate robust analyses of the use of HER2 status and other biomarkers for managing treatment.
Marchionni et al. 2008^38^ | To evaluate the evidence about the use of gene expression profiling in breast cancer | High | Diagnostic accuracy | 21 | Oncotype Dx (uses RT-PCR); MammaPrint (uses microarray technology); and Breast Cancer Profiling (BCP, uses RT-PCR) | Standard prognostic approaches (e.g., tumor type, HER-2 status) | Based on their review of the evidence, the authors determined that the Oncotype DX® assay had the strongest evidence for its ability to improve assessment of prognosis than standard risk stratification, at least in ER positive, lymph node negative, tamoxifen-treated women considering adjuvant chemotherapy. | The authors point out that there is still uncertainty about how best to incorporate the results of genetic profiling into clinical decision-making and how best to use the conventional predictors to which results are compared.
Mocellin et al. 2007^71^ | To evaluate published studies on PCR-based detection of melanoma cells in sentinel lymph nodes (SLN) for the purpose of assessing the prognostic value. | Moderate | TMN stage, disease recurrence, and/or survival (either overall [OS] or disease free [DFS]) | 22 | PCR | HE staining combined with IHC | PCR status correlated with both TNM stage and disease recurrence. PCR positivity was also associated with worse overall (hazard ratio, 5.08, p = 0.002) and disease-free survival (hazard ratio, 3.41, p <0.001) | The available evidence is somewhat conflicting and probably is not sufficient to conclude that PCR status is a prognostic indicator reliable enough to be implemented clinically in the therapeutic decision-making process.
Dendukuri et al. 2007^72^ | To evaluate the concordance and cost-effectiveness of using various test strategies involving immunohistochemistry (IHC) and fluorescence in situ hybridization (FISH) to test HER2 status. | High | Diagnostic accuracy of FISH when IHC is positive and cost-effectiveness | 18 | FISH and IHC | NR | Confirmation of the HER2 status by FISH in cases that received a score of 3+ reduced the percentage of false-positive to 0% and increased the percentage of accurately determined HER2 results to 97.6%. The test strategy of performing FISH testing in all cases of breast cancer was associated with a median incremental cost-effectiveness ratio of $8,401 per case. | The testing strategy with the lowest cost-effectiveness ratio involved screening all newly diagnosed cases of breast cancer with IHC and confirming scores of 2+ and 3+ with FISH.
Lyman et al. 2006^43^ | To systematically review the test performance of various classes of gene expression signatures in women with early stage breast cancer (ESBC) | Moderate | Distance recurrence-free survival | 17 | Microarray assays | NR | The overall sensitivity for distant recurrence-free survival was 80.6%, specificity was 53.6%, positive likelihood ratio was 1.78, negative likelihood ratio was 0.38, diagnostic odds ratio was 5.53%, positive predictive value was 37.7, and negative predictive value was 92%. | Gene expression profiles based on microarray analysis show early promise for predicting survival in patients with breast cancer. However, the use of these assays in therapeutic decision-making must consider the limitations of assay test performance and the specific patient population being tested.
Pakos et al. 2004^73^ | To evaluate the relation of TP53 status with response to chemotherapy and/or clinical outcome in osteosarcoma | Moderate | Response to chemotherapy (a cut off of 90% necrosis was used to separate responders from non-responders) and mortality | 16 | 9 studies used IHC, 4 PCR, and 3 PCR+IHC | NR | TP53 status had no discriminating ability to identify poor versus good responders to chemotherapy. Sensitivity and specificity of all studies was 50% and 56%, respectively. Separate analyses with studies using IHC or PCR were similar. In studies using RT-PCR there was a statistically significant association between TP53 alterations and worse 2-year survival. | TP53 status is not associated with the histologic response to chemotherapy in patients with osteosarcoma, whereas TP53 gene alterations may be associated with decreased survival.
Paraskevaidis et al. 2004^75^ | To systematically review and critically appraise the current evidence of the reliability of HPV DNA testing during the post-treatment surveillance of cervical intraepithelial neoplasia (CIN). | Moderate | Recurrent or residual disease | 11 | PCR or HC II | Hysterectomy and pathological examination, cytology and/or colposcopy, biopsy, or combined methods. | The sensitivity of HPV DNA testing detecting treatment failures reached 100% in four studies and reached a modest performance, ranging from 47% to 67% in two studies. The specificity of the test differed across studies, ranging from 44% to 95%. | A positive HPV test, even in the presence of normal cytology, may pick up a treatment failure early and accurately. However, cytology and colposcopy may still be needed in order to rule out false positive and false negatives.
Zielinski, G. 2004^74^ | To evaluate the utility of hrHPV testing in monitoring women after treatment for cervical intraepithelial neoplasia grade 3 (CIN-3) | Low | Recurrent or residual disease | 20 | PCR or HC I or II | hrHPV test compared to margin resection or cervical cytology | The negative predictive value for recurrent/residual disease of hrHPV testing was 98%, of resection margins 91%, and that of cervical cytology 93%. When hrHPV testing was performed in conjunction with cytology, the sensitivity was 96%, specificity was 81%, the associated positive predictive value was 46%, and the negative predictive value was 99%. | The authors propose to include hrHPV testing in conjunction with cytology for monitoring women treated for CIN 3. Some follow-up visits for women testing negative with both hrHPV and cytology can be skipped. In Western countries, this could mean that for women, double negative at 6-months, retesting at 12-months should be skipped while keeping the 24-month follow-up visit.
Medical Service Advisory Committee (MSAC) 2004^76^ | To evaluate the evidence to answer the following questions: Do targeted RT-PCR assays increase the proportion of patients who are recognized to have BCR-ABL positive acute lymphocytic leukemia (ALL), which defines a specific therapeutic strategy?; Does repeated qualitative or quantitative PCR testing post-treatment influence management and prediction of relapse? | High | Diagnostic accuracy | 33 | PCR | For the assessment of validity of PCR for the detection of BCR-ABL-ALL at diagnosis was a combination of cytogenetic testing, FISH testing, and prognosis. For monitoring the reference was relapse. | Diagnostic accuracy in diagnosis: Based on pooled analysis of 27 studies, PCR was estimated to have a sensitivity of 94.8% (95%CI: 92.6 to 96.5) and specificity of 97.3% (95%CI: 92.4 to 99.4). Diagnostic accuracy in monitoring: Based on pooled analysis of 6 studies, the pooled diagnostic odds ratio was 4.7 (95%CI: 2.2 to 10.3). | The use of PCR, with improved sensitivity compared with cytogenetic testing, could be expected to produce improved patient outcomes. PCR may also predict hematological relapse early, although with imperfect sensitivity and specificity compared with other diagnostic modalities.
Medical Service Advisory Committee (MSAC) 2003^77^ | To evaluate the evidence on the use of PCR in the diagnosis of patients with BCR-ABL gene rearrangement in chronic myeloid leukemia. | High | Diagnostic accuracy | 55 | PCR | Not clearly reported in all included studies (cytogenetic testing in most studies). | Based on pooled analysis of 17 studies, PCR was 100% (95%CI: 99 to 100) sensitive in patients BCR-ABL positive and 79% (95%CI: 49 to 95) sensitive in patients BCR-ABL negative. Combined PCR and cytogenetic testing was 99% (95%CI: 98 to 100) sensitive at diagnosis. | The use of PCR testing in both diagnosis and monitoring of CML provided both clinicians and patients with earlier and/or more accurate information, which was of benefit.
Tsao et al. 2001^78^ | To systematically review the use of RT-PCR for tyrosinase messenger RNA as a molecular serum marker for metastatic melanoma. | Moderate | Diagnostic accuracy | 23 | RT-PCR | History, physical examination, chest radiography, and complete blood cell count | Results of RT-PCR for tyrosine messenger RNA were positive in 18% of patients for stage I, 28% for stage II, and 45% for stage IV disease. Specificities were 100% in all but 1 study. Results of RT-PCR were positive in only 0.4% of healthy controls with nonmelanoma cancer. | The lack of data on the outcome of stage I, II, and II patients who were RT-PCR positive and the low prevalence of RT-PCR positivity in patients with known stage IV disease limits the applicability of RT-PCR as a prognostic indicator.

HC I or II Hybrid Capture I or II. This test is based on direct HPV DNA detection by hybridization of HPV target DNA with a cocktail of full-length HPV type specific RNAs, followed by capturing the hybrids to a solid phase. The HC II test contains more HPV types than the preceding HC I test.

IHC Immunohistochemistry

PCR Polymerase chain reaction

RT-PCR Reverse transcriptase-polymerase chain reaction

Table 32 Systematic Reviews of Test Properties of Molecular Tests for Predicting Drug Reactions

Review | Purpose | Quality of Review | Outcome | Number of Included Studies | Type of Molecular Test | Reference Standard | Reported Results | Authors’ Conclusions
Blue Cross and Blue Shield Association 2008^81^ | CYP2D6 testing and consequent alteration of treatment regimen in CYP2D6 poor metabolizers compared to no testing and no alteration of decision to treat with tamoxifen for patients with high risk for or with breast cancer. | Moderate | Disease prevention, improved time to recurrence, recurrence-free, and/or overall survival | 4 prospective cohort studies addressed the association of genotype with plasma levels of active tamoxifen metabolite 7 retrospective cohort studies addressed the association of genotype with clinical outcomes | Roche AmpliChip CYP450 Test | DNA sequencing (gold standard) or methods comparison (e.g., PCR) | Three prospective studies provided consistent evidence that CYP2D6 nonfunctional variant alleles that determine patient’s tamoxifen metabolism status (poor, intermediate, or high) are associated with significantly reduced plasma levels of endoxifen, the most bioavailable of tamoxifen active metabolites. However, endoxifen levels overlap across all genotypes, suggesting that CYP2D6 genetic variability does not explain all variability in endoxifen levels. The relationship between endoxifen plasma concentration and clinical outcomes was not established by the evidence. There was no direct evidence of clinical utility (whether use of CYP2D6 genotype testing for endocrine therapy regimen selection improves recurrence and survival outcomes. | Overall, the authors concluded that the evidence was insufficient to permit conclusions regarding the use of CYP2D6 genotyping for directing endocrine therapy regimen selection for women at high risk for or with breast cancer.
Blue Cross and Blue Shield of Massachusetts 2008^206^ | To determine whether a pharmacogenomics-based treatment regimen is superior to a standard regimen for the eradication of H. pylori, and whether the use of a pharmacogenomics-based treatment regimen improves health outcomes compared to standard treatment. | High | Successful eradication of H. pylori (which has been proven to reduce the recurrence of gastritis and peptic ulcer disease. | 1 randomized trial | Roche AmpliChip CYP450 Test | DNA sequencing (gold standard) or methods comparison (e.g., PCR) | The single study that met the inclusion criteria for this report compared a pharmacogenomics-based treatment regimen for H. pylori with a standard treatment regimen. Genetic testing was performed on H. pylori isolates to determine sensitivity to clarithromycin. Treatment for the pharmacogenomics group was determined based on sensitivity status (extensive metabolizer to poor metabolizer). Overall, the results of the study indicated that H. pylori eradication rates at 1 month were 96% in the pharmacogenomics-based treatment group versus 70% in the standard care group (a statistically significant difference, p <0.001). Eradication rates were greater for extensive metabolizers than poor metabolizers. | Because only one study met the inclusion criteria for this review, the authors concluded that the evidence did not permit conclusions on whether the use of a pharmacogenomics-based treatment regimen for H. pylori improves eradication rates or net health outcomes.
Matcher et. al. 2006^37^ | To determine if testing for CYP450 polymorphisms in adults entering SSRI treatment for non-psychotic depression leads to improvement in outcomes, or if testing results are useful in medical, personal, or public-health decision-making. | High | Analytic validity (sensitivity and specificity), drug metabolism, predicting SSRI efficacy, improved patient outcomes, adverse events, management decision-making. | 37 | Most studies used Roche Amplichip ® CYP450 Test | DNA sequencing (gold standard) or methods comparison (e.g., PCR) | Three of the five studies on drug metabolism showed that CYP2C19 PMs have significantly higher area under the curve (AUC, which is an assessment of bioavailability), longer half-life, and reduced oral clearance of the parent drug, and lower maximum plasma concentration of the metabolite of each drug. Similar findings were found in a study of CYP2D6 in healthy volunteers after a single dose of paroxetine, while another study of CYP2D6 using multiple doses of paroxetine found no significant difference between PMs and EMs. The remaining 11 studies showed mixed results because of heterogeneity and small sample sizes. The findings from studies on CYP450 testing and efficacy of SSRIs were mixed with most finding either no difference in the proportion of responders among CYP2D6 EMs, IMs, and PMs, or that plasma blood levels did not predict treatment response. Of the nine studies that addressed CYP450 testing and adverse drug reactions, three reported adverse effects in CYP PMs only as a secondary finding. Of the remaining six studies, three reported no difference in adverse effects between CYP2D^ PMs and EMs, while a fourth study reported no difference in adverse effects between the combined PM+IM and EM+UM groups. The remaining two studies found a greater prevalence of gastrointestinal adverse effects in PMs compared to EMs. | A paucity of good-quality data addressing the questions of whether testing for CYP450 polymorphism in adults entering SSRI treatment for non-psychotic depression leads to improvement in outcomes, or whether testing results are useful in medical, personal, or public health decision-making.
Morgan et al. 2005^65^ | To evaluate the overall accuracy of line probe assay in the detection of rifampicin (RIF)-resistant TB | High | Diagnostic accuracy | 15 | INNO-LIPA Rif. TB kit (Inn genetics, Belgium) | Culture | Twelve of the 14 studies that applied LIPA to isolates had sensitivity greater than 95%, and 12 of 14 had specificity of 100%. The four studies that applied LIPA directly to clinical specimens had 100% specificity, and sensitivity ranged between 85% and 100%. | LIPA is a highly sensitive and specific test for the detection of rifampicin resistance in culture isolates. The test appears to have relatively lower sensitivity when used directly on clinical specimens.
Sanderson et al. 2005^83^ | To examine the strength and quality of existing evidence about CYP2C9 gene variants and clinical outcomes in warfarin-treated patients. | Moderate | Drug dose, bleeding events | 11 | PCR | NR | Mean difference in daily warfarin dose: for CYP2C9*2, the reduction was 0.85 mg (0.60 to 1.11 mg), a 17% reduction. For CYP2C9*3, the reduction was 1.92 mg (1.37 to 2.47 mg, a 37% reduction. For CYP2C9*2 or *3, the reduction was 1.47 mg (1.24 to 1.71 mg), a 27% reduction. The relative bleeding risk for CYP2C9*2 was 1.91 (1.16 to 3.17) and for CYP2C9*3, 1.77 (1.07 to 2.91). For either variant, the relative risk was 2.26 (1.36 to 3.75). | Patients with CYP2C9*2 and CYP2C9*3 alleles have lower mean daily warfarin doses and a greater risk of bleeding. Testing for gene variants could potentially alter clinical management in patients commencing warfarin. Evidence for the clinical utility and cost-effectiveness of genotyping is needed before routine testing can be recommended.

NR Not reported

PCR Polymerase chain reaction

Table 33 Published Studies of Proficiency Testing for FISH Assays

Study | Design | Organization | Reference Materials | Number of Participating Laboratories | Number of Laboratories Returning Results | Results | Factors that Contributed to Variability
Bartlett et al. 2007^111^ | Present results of a pilot proficiency testing survey for HER-2/neu. | National External Quality Assessment Scheme (NEQUAS), United Kingdom (UK) | Five breast cancer cell lines, two with amplification and three without. Laboratories tested each line three times. Samples were distributed fixed on slides. | 6 reference centers and 31 laboratories | The laboratories returned 78 sets of data (out of 93 possible sets) and the reference centers returned 29 complete sets of results. | 60% of all results were “acceptable,” however 22.4% of results returned were “inappropriate,” including 13 cases (4.2%) where a misdiagnosis would have been made had these been clinical specimens. | Most of the incorrect diagnoses were from one cell line that has low-level HER2 amplification.
Persons et al. 2006^112^ | Present the results of proficiency testing surveys from 2000 to 2004 for HER-2/Neu; years 2000 and 2001 were previously reported in 2002, and are thus not tabled here | College of American Pathologists (CAP) | Nine breast cancer cases with known HER-2/neu status, 4 with high levels of amplification, 4 without amplification, and a case with low-level amplification. Samples were distributed as fixed paraffin-embedded tissue blocks. | 2002 survey 90 | 90 (100%) returned results for the HER-2/neu positive specimen and 89 (99%) returned results for the low-level sample | All results for the high-level amplification sample were correct, but only 56% of laboratories correctly identified the low-level sample as amplified | All of the incorrect diagnoses were from one sample with low-level HER2 amplification.
Persons et al. 2006^112^ | Present the results of proficiency testing surveys from 2000 to 2004 for HER-2/Neu; years 2000 and 2001 were previously reported in 2002, and are thus not tabled here | College of American Pathologists (CAP) | | 2003 survey 127 | 127 (100%) returned results for the HER-2/neu negative specimen, and 124 (98%) returned results for the HER-2/neu positive specimen | 97% correctly identified the negative specimen as negative; 76% correctly identified the low-level specimen as positive | Most of the variability was from one sample with low-level HER2 amplification.
Persons et al. 2006^112^ | Present the results of proficiency testing surveys from 2000 to 2004 for HER-2/Neu; years 2000 and 2001 were previously reported in 2002, and are thus not tabled here | College of American Pathologists (CAP) | | 2004 survey 139 | 139 (100%) returned results for the HER-2/neu positive specimen and 136 (98%) returned results for the HER-2/neu negative specimen. | 94% correctly identified the positive specimen as positive, and 97% correctly identified the negative specimen as negative | Little variability was observed.
Cell Markers and Cytogenetic Committees, CAP 2002^113^ | Present the results of proficiency testing surveys from 2000 and 2001 for HER-2/neu | College of American Pathologists (CAP) | Two breast cancer cases with known HER-2/neu status one with amplification and one without amplification. Samples were distributed fixed on slides. | 2000 survey 35 | 35 (100%) | All returned results were correct. | No variability was reported.
Cell Markers and Cytogenetic Committees, CAP 2002^113^ | Present the results of proficiency testing surveys from 2000 and 2001 for HER-2/neu | College of American Pathologists (CAP) | Two breast cancer cases with known HER-2/neu status one with amplification and one without amplification. Samples were distributed fixed on slides. | 2001 survey 63 | 49 (78%) returned results for the HER-2/neu negative specimen and 58 (92%) returned results for the HER-2/neu positive specimen. | All returned results were correct. | No variability was reported.
Mascarello et al. 2002^114^ | Present the results of FISH proficiency testing surveys from 1997 to 2000. | College of American Pathologists (CAP) and American College of Medical Genetics (CAP-ACMG) | 1997 survey Microdeletion of chromosome 22 in blood and a normal sample, both fixed to slides | 131 | 116 (88.5%) | 93.1% correctly identified the deletion and 85.1% correctly identified the normal sample | All laboratories used commercially available probes. There was no correlation between a laboratory’s experience with a particular test and the laboratory’s proficiency test performance. Laboratories with all correct interpretations on the proficiency tests were more likely to have written quality control plans.
Mascarello et al. 2002^114^ | Present the results of FISH proficiency testing surveys from 1997 to 2000. | College of American Pathologists (CAP) and American College of Medical Genetics (CAP-ACMG) | 1998 survey 1 BCR-ABL gene fusion in blood fixed to slides with varying proportions of cells carrying the fusion | 134 | 117 (87.3%) | 97.4% correctly identified the fusion in a sample that was 98% neoplastic and 93.2% correctly identified the fusion in a sample that was 28% neoplastic
Mascarello et al. 2002^114^ | Present the results of FISH proficiency testing surveys from 1997 to 2000. | College of American Pathologists (CAP) and American College of Medical Genetics (CAP-ACMG) | 1998 survey 2 Microdeletion of chromosome 7 in blood and a normal sample fixed to slides | 121 | 109 (90.1%) | 97.2% correctly identified the deletion and 94.5% correctly identified the normal sample
Mascarello et al. 2002^114^ | Present the results of FISH proficiency testing surveys from 1997 to 2000. | College of American Pathologists (CAP) and American College of Medical Genetics (CAP-ACMG) | 1999 survey 1 PML-RARA gene fusion in blood and a normal sample fixed to slides | 136 | 108 (79.4%) | 99.1% correctly identified the fusion in a sample that was 92% neoplastic and 98.1% correctly identified the normal sample
Mascarello et al. 2002^114^ | Present the results of FISH proficiency testing surveys from 1997 to 2000. | College of American Pathologists (CAP) and American College of Medical Genetics (CAP-ACMG) | 1999 survey 2 Prenatal detection of aneuploidy in cultured amniocytes fixed to slides | 124 | 107 (86.3%) | 100% correctly identified the trisomy 21 sample and 97.2% correctly identified the triploidy sample
Mascarello et al. 2002^114^ | Present the results of FISH proficiency testing surveys from 1997 to 2000. | College of American Pathologists (CAP) and American College of Medical Genetics (CAP-ACMG) | 2000 survey 1 TEL-AML1 gene fusion in blood and a normal sample fixed to slides | 113 | 103 (91.2%) | 100% correctly identified the fusion in a sample that was 50% neoplastic, 96.1% correctly identified the fusion in a sample that was 20% neoplastic, and 99.0% correctly identified the normal sample
Mascarello et al. 2002^114^ | Present the results of FISH proficiency testing surveys from 1997 to 2000. | College of American Pathologists (CAP) and American College of Medical Genetics (CAP-ACMG) | 2000 survey 2 A microdeletion and a duplication of chromosome 15 in blood fixed to slides | 151 | 146 (96.7%) | 100% correctly identified the deletion, but only 4.1% correctly identified the duplication

Table 34 Published Proficiency Studies of PCR-based Tests: PCR, General Aspects

Study | Design | Test(s) | Organization | Reference Materials | Number of Participating Laboratories | Number of Laboratories Returning Results | Results | Factors that Contributed to Variability
Orlando et al. 2007^115^ | Present the results of a proficiency testing survey. | DNA extraction and PCR amplification | European Union Quality Control Concerted Action (EQUAL) | Blood samples as well as purified DNA. | 213 | 175 (82%) | 27% of laboratories had poor-quality DNA preparation. 3% of laboratories had a consistently low rate of amplification, and 10% did not identify the expected number of bands of amplified targets. | The reagents and PCR methods used by each laboratory were speculated to be the cause of the variability.
Ramsden et al. 2006^116^ | Present the results of a proficiency testing survey. | Real-time quantitative PCR using Taqman probes, including extraction of RNA and preparation of cDNA. | European Union Quality Control Concerted Action (EQUAL) | Cell lines suspended in RNAlater. Reference standards and primers were provided. The target gene was ABL. | 137 | 130 (94.9%) | Data from ten laboratories were excluded (results suggested the assays were contaminated or the data reported were incomplete). 20% of the remaining laboratories reported results that were lacking in precision and/or accuracy. | No differences in performance were observed for the >10 different PCR platforms used by the study participants.
Raggi et al. 2005^117^ | Present results of a proficiency testing survey | real-time PCR using Taqman probes | Italian Network for Quality Assurance of Tumor Biomarkers (INQAT) | cDNA prepared from three pools of RNA extracted from human cancers. Laboratories were provided with the same PCR probes and with a standard sample for reference curve preparation. The target was levels of human telomerase expression. | 48 | 42 (87.5%) | Two laboratories reported results suggesting contamination of samples. Of the remaining 40 laboratories, only 12 correctly assayed all three samples. 17 reported imprecise results for at least one sample, 12 laboratories were unable to amplify anything from the third sample, 3 laboratories reported incorrect results for all three samples, and six laboratories were unable to correctly amplify the provided standards. | One particular PCR platform seemed to be over-represented in the group of laboratories that returned very poor results.
Birch et al. 2004^118^ | Present results of a proficiency testing survey | DNA extraction, amplification by PCR, and analysis of products by electrophoresis. | Organized by the participating laboratories | Killed bacteria diluted into saline. | 15 | 15 (100%) | Overall laboratories performed the analysis successfully. | Experience with bacteria did not affect the accuracy of the results. The laboratory itself was the most important factor, with some laboratories performing well on most of the tests and others not.
Raggi et al. 2003^119^ | Present results of a proficiency testing survey | DNA extraction, amplification by PCR, and analysis of products by electrophoresis. | Italian Network for Quality Assurance of Tumor Biomarkers (INQAT) | Pooled blood samples collected from healthy volunteers. Three samples and a reference standard were supplied to each laboratory. Laboratories were provided with probes to amplify three target DNA sequences, and amplification parameters for the probes were provided. | 39 | 39 (100%) | Only 4 laboratories were rated “excellent”. 13 were rated “good”, 15 were “sufficient”, 3 were “poor”, and 4 were “unacceptable”. | Poor quality DNA extraction contributed significantly to the variability. Efficiency of PCR amplification varied dramatically across laboratories as well.
Braun et al. 1998^120^ | Present the results of a pilot proficiency testing survey | DNA preparation from whole blood, PCR amplification, and agarose gel electrophoresis of PCR products. | Reference Institute of Bioanalysis of the German Society of Clinical Chemistry | Blood from a volunteer and DNA prepared from the blood of a volunteer. PCR primers directed to two different targets were provided. | 50 | 45 (90.0%) | Most of the participants obtained comparable results. The mean quality of DNA prepared using commercial kits was much lower than the DNA prepared using laboratory-developed methods. The majority of participants over-estimated the exact size of the PCR products. | Nonoptimal PCR reagents and parameters were speculated to be the major source of variability.

Table 34a Published Proficiency Studies of PCR-based Tests: PCR-based Detection and Typing of Viruses

Study | Design | Test(s) | Organization | Reference Materials | Number of Participating Laboratories | Number of Laboratories Returning Results | Results | Factors that Contributed to Variability
Stelzer-Braid et al. 2008^136^ | Present the results of a proficiency testing program. | PCR tests to detect avian influenza viruses. | Consortium of academics | Three panels of viruses grown in culture, inactivated, and diluted in saline. | 29 | 29 (100%) | 80 to 88% of the laboratories returned correct results. Very dilute samples were often reported as false-negatives. | Samples with low viral titers produced the greatest variability in results. The sensitivity of the tests did, however, improve slightly between panels 2 and 3.
Wang et al. 2008^135^ | Present the results of five years of a proficiency testing program. | PCR tests to detect hepatitis C virus. | National Center for Clinical Laboratories (China) | Ten different panels of plasmids carrying viral DNA diluted in plasma and freeze-dried. | 153 to 233, depending on which panel. | Not reported | Overall, 98.6% of negative samples and 96.7% of positive samples were correctly identified. The most concentrated samples had a 99.4% detection rate, and the most dilute samples had an 87.7% detection rate. In 2003, only 30.5% of the laboratories correctly identified the amount of virus in the samples, compared to 2007 when 91.2% correctly identified the amount of virus in the sample. | Samples with low viral titers produced the greatest variability in results. The improvement in results over time was attributed to the development of higher-quality commercial kits.
Chalker et al. 2007^121^ | Present the results of a proficiency testing program. | PCR tests to detect hepatitis C virus. | National External Quality Assessment Scheme (NEQAS) | Nine different panels of hepatitis virus diluted in plasma and freeze-dried. | 52 to 159, depending on which panel | Not reported | The accurate detection of hepatitis C and its genotype varied from 86.9% to 100%. | Samples with low viral titers produced the greatest variability in results. False-positives of negative samples were very rare.
Niedrig et al. 2006^122^ | Test whether laboratories have improved since they participated in a previous proficiency testing survey. | PCR-based tests to identify and genotype orthopoxviruses (monkeypox, cowpox, vaccinia virus) | European Network for Diagnostics of Imported Viral Diseases (ENIVD) | Viral cultures irradiated to inactivate the viruses and diluted to various levels. | 33 | 33 (100%) | Results were not significantly improved since the first survey. Laboratories had a greater than 80% detection rate above 56,234 copies per ml. 23 out of 27 laboratories were able to correctly genotype, and 9 were able to correctly quantitate the viruses. 22 false-positive results were returned, but 18 of these were from five laboratories. | Laboratories that used either real-time PCR or a commercial assay kit had more accurate results than laboratories that used conventional PCR or nested PCR. The use of commercial sample preparation kits did not influence the accuracy of the results.
Templeton et al. 2006^123^ | Present the results of a proficiency testing survey. | PCR tests to detect respiratory viruses. | Quality Control for Molecular Diagnostics (QCMD) | Stocks of viruses prepared at reference laboratories were diluted into media. Viruses included influenza, rhinovirus, adenovirus, and coronavirus. | 17 | 17 (100%) | 93.75% of high-titer samples were correctly identified; 76.5% of mediumtiter and 47.0% of low-titer samples were correctly identified. | The overall performance was not dependent on the methodology chosen by the laboratory; high-quality results instead seem to be dependent on the laboratory’s internal quality control and optimization of the assay used.
Drosten et al. 2004^124^ | Present the results of a proficiency testing survey | PCR-based methods of detecting the presence of viruses that cause severe acute respiratory syndrome (SARS). | World Health Organization SARS Reference and Verification Network | Inactivated viral RNA material extracted from viral cultures and diluted into plasma. | 58 | 58 (100%) | Of 58 participants, 51 correctly detected virus in all samples >9,400 RNA copies per milliliter and none in negative samples. | The 14 of the 58 laboratories that used commercial kits had significantly more accurate results.
Mancini et al. 2004^125^ | Present the results of a proficiency testing survey. | PCR tests to detect hepatitis C. | Italian Society of Clinical Microbiology (AMCLI) | Dilutions of hepatitis C in plasma. | 17 | 17 (100%) | 15 of the 17 laboratories used commercial kits, and 2 used homebrew assays. Only 1.4% of results were incorrect. | Little variability was observed. Errors were generally made only on low-titer samples.
Schloss et al. 2003^126^ | Present the results of a proficiency testing survey. | PCR-based detection of herpes simplex virus. | European Union Quality Control Concerted Action (EQUAL) | Panels of virus diluted to various degrees. | 66 panel 1, 77 panel 2 | 76 data sets were reported for panel 1, 78 data sets were reported for panel 2 | 30% of data sets were correct for the entire panel 1; 28% of data sets were correct for the entire panel 2. | Lack of sensitivity of tests caused the most errors.
Schirm et al. 2002^127^ | Present results of a proficiency testing survey | PCR-based tests to detect hepatitis C virus | European Union Quality Control Concerted Action (EQUAL) | Hepatitis C virus diluted into plasma | Panel 1–57 Panel 2–81 | [underlined: Panel 1]: 45 qualitative and 35 quantitative data sets [underlined: Panel 2]: 75 qualitative and 48 quantitative data sets | [underlined: Panel 1]: 1.3% false-positive rate. Adequate or better scores on qualitative results were achieved in 84% of samples. [underlined: Panel 2]: 0.8% false-positive rate. Adequate or better scores on qualitative results were achieved on 80% of samples. | Detection of low-titer samples was often inadequate.
Valentine-Thon et al. 2001^128^ | Report and compare the results of two different proficiency panels | PCR detection and quantitation of hepatitis B virus | European Union Quality Control Concerted Action (EQUAL) | Hepatitis B virus diluted in human plasma. Each panel had 2 negative samples and 6 positive samples with a range of viral copies per ml. | Panel 1, 42 Panel 2, 51 | [underlined: Panel 1]: 20 qualitative data sets and 37 quantitative data sets [underlined: Panel 2]: 25 qualitative data sets and 47 quantitative data sets | [underlined: Panel 1]: an adequate or better score was obtained on 77.2% of the data sets [underlined: Panel 2]: an adequate or better score was obtained on 68.1% of the data sets. Home-brew qualitative PCR assays performed better than commercial quantitative assays because many of the assays were not sensitive enough to detect clinically relevant but low viral copy levels. | False-positive rates were extremely low. Most variability came from varying sensitivity of assays to detect low viral copy levels.
Van Vliet et al. 2001^129^ | Present results of a proficiency testing survey. | PCR-based methods of detecting enteroviruses | European Union Quality Control Concerted Action (EQUAL) | Panel of 12 samples of various enteroviruses at various titers. | 63 | 59 (93.7%) laboratories returned 71 data sets; one set was excluded from analysis. | 66% of the 70 data sets were correctly interpreted. | Nested PCRs were associated with better results than other methods; but all methods achieved a maximum score at least once. Staff proficiency and laboratory facilities were speculated to account for much of the variability.
van Loon et al. 1999^130^ | Present the results of a proficiency testing survey. | PCR-based methods of isolating, detecting and typing enteroviruses. | European Union Quality Control Concerted Action (EQUAL) | Cell lines infected with virus. | 12 | 11 (91.7%) on isolating virus; 4 (33.3%) on PCR for detecting virus | Correct virus isolation results were obtained for 105 of 110 samples (95.5%, four false-negatives, one false-positive), and correct PCR results for 39 of 40 (97.5%, one false-negative). | Laboratories were more successful in isolating virus from monkey cells than from human cells. Major problems were seen with samples containing mixtures of enteroviruses and with enterovirus 71 or echovirus 4, with 9%, 50%, and 55% correct results, respectively.
Read et al. 1998^131^ | Present results of a specimen exchange/quality control program | PCR detection of various viruses | Laboratory initiated by virology sections of Oxford and Cambridge PHL | Either original clinical specimens or cerebrospinal fluid spiked with diluted virus infected cell culture. Sixty specimens in nine batches were exchanged over six months. | 2 | 2 (100%) | Discrepant results were obtained for only 2 of the specimens | Sensitivity differences due to different primer designs were observed. Transport of samples at ambient temperature was observed to reduce the sensitivity of tests to detect RNA.

Table 34b Published Proficiency Studies of PCR-based Tests: PCR-based Methods of Detecting and Typing Bacteria

Study | Design | Test(s) | Organization | Reference Materials | Number of Participating Laboratories | Number of Laboratories Returning Results | Results | Factors that Contributed to Variability
Deplano et al. 2006^132^ | Present results of a proficiency testing survey. | Genotyping of staphylococcus aureus | The reference laboratory for MRSA-staphocci, Brussels, Belgium | Panels of staphylococcus selected from the collection at the reference laboratory. | 2 surveys were conducted, and 10 laboratories participated per survey | 10 (100%) | 100% of the laboratories correctly typed the samples, and all but one laboratory demonstrated 100% reproducibility. | No variability in the results was observed despite the wide range of methods used to perform the tests.
Muyldermans et al. 2005^133^ | Present results of two proficiency testing surveys | Detection of B. pertussis | Belgian Centres for Molecular Diagnostics (CMD) | Panel 1 was a series of dilutions of three strains of B. pertussis collected in 2000; Panel 2 consisted of 5 species of Bordetella. Samples were prepared in saline and provided frozen on dry ice. | 6 laboratories participated in the first survey and 9 participated in the second survey. | 100% for both surveys | [underlined: First panel]: No false-positives were reported. Laboratories reported varying ability to detect low-copy-number samples. [underlined: Second panel]: There was one false-positive and varying ability to detect low-copy-number samples and varying ability to identify the other strains of Bordetella. | There was no apparent correlation between methods used and accuracy of results, except that choice of target sequence was critical for distinguishing B. pertussis from other Bordetella species.
CTLTN 2004^134^ | Present results of three years of a proficiency testing program. | Typing and detection of M. tuberculosis by RFLP and PCR | Canadian Tuberculosis Laboratories Technical Network (CTLTN) | Samples of different strains of M. tuberculosis prepared by the National Reference Center | [underlined: 2000]: 5 RFLP, 5 for PCR [underlined: 2001]: 5 RFLP, 13 for PCR [underlined: 2002]: 3 RFLP, 12 for PCR | 100% for all years | [underlined: 2000]: consensus for RFLP typing ranged from 60 to 100%; 5 of 9 positive samples correctly identified, and 2 of 5 negative samples correctly identified by PCR [underlined: 2001]: 100% consensus for RFLP typing; 25 of 26 positive samples correctly identified and 12 of 13 negative samples correctly identified by PCR. [underlined: 2002]: 100% consensus for RFLP typing; 22 of 24 positive samples correctly identified; 12 of 12 negative samples correctly identified | There was little variability and laboratory proficiency improved over time.

Table 34c Published Proficiency Studies of PCR-based Tests: PCR-based Methods of Detecting Genetic Alterations Related to Cancer

Study | Design | Test(s) | Organization | Reference Materials | Number of Participating Laboratories | Number of Laboratories Returning Results | Results | Factors that Contributed to Variability
Hsi et al. 2002^137^ | Retrospective review of data collected from a proficiency testing program over four years. | PCR methods of detecting bcl-2/JH translocation (t(14;18)(q32;q21)) | College of American Pathologists (CAP) | 24 specimens which included six samples containing the target translocation. Specimens were either cell lines or human tissue. Some specimens were frozen, and some were fixed and embedded in paraffin. | 25 to 61 depending on which panel. Panels were sent out twice a year for four years. | Not reported. | 819 major breakpoint region and 323 minor cluster region determinations were performed, with an overall correct response rate of 91% and 94%, respectively. No significant difference in correct response could be found for frozen versus paraffin-embedded tissues. | Despite great variability in methods and primer choice, there was little variability observed. Few laboratories used an internal control, and few laboratories reported knowledge of the sensitivity of their chosen assay method.
Bolufer et al. 2001^138^ | Present the results of a proficiency testing survey | RT-PCR based methods of detecting PML-RAR | Spanish External Quality Assessment Program (EQAP) | RNA samples extracted from cell lines; cell lines; and plasmids. | 18 | Panel 1, 15 (83.3%); Panel 2, 15 (83.3%); Panel 3, 13 (72.2%); Panel 4, 8 (44.4%); Panel 5, 16 (88.9%). | Although the laboratories used diverse methods, most were able to correctly analyze samples with high levels of the target. | Many of the assays used were not sensitive enough to detect low levels of the target. A high level of contamination of reactions was observed.
Bolufer et al. 1998^139^ | Present results of a proficiency testing survey | RT-PCR detection of PML-RAR alpha | Spanish External Quality Assessment Program (EQAP) | cDNA samples prepared by the reference laboratory from bone marrow samples obtained from patients with acute promyelocytic leukemia (APL) | 7 in the first round, 12 in the second round | A total of 69 data sets were returned out of 88 expected. | Amplification of the control gene was satisfactory in 90% of samples. There was an 83% concordance between laboratories for PML/RARa detection with similar results for the type of PML/RRa rearrangements. However, 17% disagreement still remained. | Lack of sensitivity of assays and inappropriate use of primers contributed to some of the errors. Most of the discrepant results occurred with a single sample out of the 9 samples provided.

Table 34d Published Proficiency Studies of PCR-based Tests: DNA Sequencing

Study | Design | Test(s) | Organization | Reference Materials | Number of Participating Laboratories | Number of Laboratories Returning Results | Results | Factors that Contributed to Variability
Afshar et al. 2007^143^ and Fry et al. 2007^207,a^ | Present results of a proficiency testing program. | DNA sequencing method of typing Legionella bacteria | European Working Group for Legionella Infections | Bacterial isolates grown in the laboratory. | 16 first panel, 18 second panel, 29 third panel. | 11 (69%) first panel; 18 (95%) second panel; 27 (93%) third panel | First panel, only 50% of results were correct; second panel, 56% were correct; third panel, 76% were correct. | Laboratories that routinely performed many sequencing assays per year performed significantly better.
Dorn-Beineke et al. 2006^140^ | Report impact of a training program on laboratory perform-ance on a proficiency testing survey. | DNA sequencing | European Union Quality Control Concerted Action (EQUAL) | PCR products or plasmids. Primers were provided. | 8 | 6 (75%) | The laboratories demonstrated a significant improvement in proficiency. | Not relevant
Ahmad-Nejad et al. 2006^141^ | Present results of a proficiency testing survey. | DNA sequencing | European Union Quality Control Concerted Action (EQUAL) | Plasmid DNA, an amplified PCR product, and a finished sequencing reaction to be analyzed. | 60 | 43 (71.7%) | There was considerable variation in both the quality of the sequencing data and in the interpretation of the data. | There was a correlation between quality of data and interpretation and the number of sequencing assays the laboratory performed each year.
Patton et al. 2006^142^ | Present results of a proficiency testing survey. | DNA sequencing | European Molecular Genetics Quality Network (EMQN) | PCR-amplified segments of cystic fibrosis (CFTR) gene. Wild type and common mutations were used. Primers were provided. | 64 | 61 (95%) | 36 (59%) of laboratories scored the maximum number of marks for genotyping. 53% of errors made were false-negatives (missed mutations)and 47% were false-positives (reported mutations that were not present). 27 errors of nomenclature were made. | There appears to be no correlation between the quality of the sequencing data and the likelihood of a laboratory making a genotyping mistake. Often the mutations were correctly identified in the electronic data but were not correctly identified by the interpretive software or individuals interpreting the data.

a Fry et al.207 reported details on one of the three panels; Afshar et al.143 reported details of all three panels.