# Catalogue of Molecular Tests Relevant to Medicare Over-65-year Population

Table 11 Molecular Test Information Available from the AMP Test Directory

Condition | Information
Infectious disease | - Type of infectious agent (e.g., bacterial, viral, fungal, or parasitic); - Infectious agent group (e.g., staphylococcus, enterovirus, etc.); - Infectious agent (e.g., methicillin resistance, echovirus, etc.); - Disorder/use of test (e.g., diagnosis, typing, etc.); - Assay type (e.g., qualitative, quantitative, etc.); - Availability (e.g., clinical, research, or both); - Laboratory name and location; - Link to laboratory Web site and specific information about test
Solid Tumor | - Test category (e.g., amplification, mutation analysis, etc.); - Gene (e.g., HER2/neu/ERBB2); - Chromosome; - Tumor type (e.g., breast cancer); - Assay type (e.g., qualitative, quantitative); - Availability (e.g., clinical, research, or both); - Laboratory name and location; - Link to laboratory Web site and specific information about test
Hematopathology | - WHO category (e.g., acute myeloid leukemia, B and T cell neoplasms); - WHO abnormality (e.g., t(14;18)(q32;q21) or variant); - Gene (e.g., BCL-2); - Chromosome (e.g., t(14;18)(q32;q21)); - Test use (e.g., classification, diagnosis, prognosis); - Assay type (e.g., qualitative, quantitative); - Availability (e.g., clinical, research, or both); - Laboratory name and location; - Link to laboratory Web site and specific information about test

WHO World Health Organization

## Guide to Molecular Test Tables

As noted previously, the primary source for the molecular tests included in the following tables was the Web site of the AMP. Laboratories voluntarily submit information regarding tests they perform; consequently, not all laboratories or all molecular tests are represented. Overall, we created nine tables of which five include only laboratory-developed tests and four include tests performed using commercial kits or commercially available products (e.g., ASRs). Each table is specific to the following clinical conditions: infectious diseases, solid tumors, and hematopathology. For infectious diseases, separate tables were created for diseases caused by bacterial agents, viral agents, or fungal or parasitic agents. The exact organization of the tables varies depending on the clinical condition. All tables include information about the type of test method used (e.g., polymerase chain reaction [PCR], fluorescence in situ hybridization [FISH]), the primary use of the test (e.g., diagnosis, prognosis, monitoring, or treatment decisions), the assay type (e.g., qualitative or quantitative), and the laboratory identification number. In an effort to conserve space and aid the reader, we assigned identification numbers to the laboratories, instead of listing each laboratory that performed a test by name. The name and identification number of each laboratory for which we obtained testing information are presented in Table 12. Common abbreviations used to describe the testing methods are listed in Table 13.^6^

6 Some tests were excluded because they were not performed using a molecular method (e.g., immunohistology).

The tables are further organized by condition using the following categories:

### Infectious Disease

The infectious disease tables are organized using the following seven column headings: infectious agent, test use, test method, assay type, source (only for tests performed using commercial kits or products), laboratory identification, and total number of laboratories that perform test.

### Solid Tumors

The solid tumor tables are organized using the following seven column headings: gene, tumor type/subtype, test use, test method, assay type, laboratory identification, and total number of laboratories that perform tests.

### Hematopathology

The hematopathology tables are organized using the following seven column headings: gene, gene specifics, disorder/test use, test method, assay type, laboratory, and number of laboratories. Each table is further organized by World Health Organization (WHO) categories. The following WHO categories are included: mastocytosis & myelodysplastic, acute myeloid leukemia‘s, B and T cell neoplasms, chronic myeloproliferative diseases, histiocytic and dendritic-cell neoplasms, and Hodgkin lymphoma.

## List of Laboratories

Table 12 Laboratory Name and Identification Number

Laboratory Name | Identification Number
Advocate Lutheran General Hospital | 1
Albany Medical Center | 2
Ambry Genetics Corp | 3
Ameripath Center For Advanced Diagnostics | 4
Armed Forces Institute of Pathology | 5
ARUP Laboratories | 6
Association for Molecular Pathology Corporate Laboratory | 7
Athena Diagnostics Inc. | 8
Barnes-Jewish Hospital | 9
BayCare Laboratories | 10
Baylor College of Medicine | 11
Baylor University Medical Center | 12
Berkshire Medical Center | 13
Cenetron Diagnostics | 14
Center for Human Genetics | 15
Children’s Hospital (Akron) | 16
Children’s Hospital Medical Center (Columbus) | 17
Children’s Hospital (Denver) | 18
Children’s Hospital (Philadelphia) | 19
Christiana Care Health Services | 20
Clinical Molecular Diagnostic Laboratory | 21
Columbia Presbyterian Medical Center | 22
Comprehensive Genetic Services | 23
Cook Children’s Medical Center | 24
Correlagen Diagnostics Inc. | 25
Creighton University Medical Center | 26
Dana Farber Cancer Center | 27
Dartmouth-Hitchcock Medical Center | 28
Duke University Medical Center | 29
Emory Medical Laboratory | 30
Evanston Northwestern Healthcare | 31
Florida Hospital | 32
Focus Technologies | 33
Fox Chase Cancer Center | 34
GeneDx | 35
Genomic Health, Inc. | 36
Huntington Medical Research Institute | 37
Investigen | 38
Johns Hopkins Hospital | 39
LabCorp | 40
LDS Hospital / Intermountain Healthcare | 41
Louisiana State University Health Sciences Center | 42
Mayo Clinic -Cytogenetic Lab | 43
Mayo Clinic-Molecular Genetics Lab | 44
MD Anderson Cancer Center | 45
Medical University of South Carolina | 46
Molecular Pathology Laboratory Network, Inc | 47
Myriad Genetic Laboratories | 48
New York Presbyterian Hospital | 49
North Shore Long Island Jewish Health System | 50
Ohio State University | 51
Oregon Health & Sciences University | 52
Pathology Associates Medical Laboratories | 53
PhenoPath Laboratories | 54
Quest Diagnostics | 55
RedPath Integrated Pathology, Inc. | 56
Regional Medical Laboratory | 57
Reliagene Technologies | 58
Rhode Island Hospital | 59
Roche Diagnostic | 60
Rush Presbyterian St. Luke’s Medical Center | 61
Sacred Heart Medical Center | 62
Saint Barnabus Medical Center | 63
Saint Louis University School of Medicine | 64
Specialty Laboratory | 65
Southern Arizona VA Health Care System | 66
Targeted Diagnostics & Therapeutics, Inc. | 67
Targeted Molecular | 68
Texas Children’s Hospital | 69
The Methodist Hospital | 70
Thomas Jefferson University | 71
UCLA Medical Center | 72
UMDNJ / NJ Medical School | 73
UNC Hospitals | 74
University of Alabama Hospital | 75
University of California Irvine Medical Center | 76
University of Colorado Hospital | 77
University of Iowa Hospital & Clinics | 78
University of Nebraska Medical Center | 79
University of Oklahoma Health Sciences Center | 80
University of Pennsylvania Health System | 81
University of Pittsburgh Medical Center | 82
University of South Alabama | 83
University of Texas Medical Branch | 84
University of Utah School of Medicine | 85
University of Washington Medical Center | 86
University of Texas Southwestern Medical Center | 87
Upstate Medical University | 88
Vanderbilt University Medical Center | 89
VCU Medical Center | 90
Washington Hospital Center | 91
William Beaumont Hospital | 92
Yale New Haven Hospital | 93
Yale University of Medicine | 94
York Hospital | 95
Total Number of Laboratories | 95

## Abbreviations Used in Molecular Test Tables

Table 13 Abbreviations for Testing Methods

Abbreviation | Description
ASPE | Allele Specific Primer
bDNA | Branched-chain DNA
BLA | Biological License Application
FISH | Fluorescence In Situ Hybridization
QC | Quality Control
Qual | Qualitative
Quant | Quantitative
HPA | Hybridization Protection
HYB | Hybridization
LCR | Ligase Chain Reaction
LIPA | Lipase A
LOH | Loss of Allele
NASBA | Nucleic Acid Sequence Based Amplification
PCR | Polymerase Chain Reaction
PCR-ASO blot | Polymerase Chain Reaction Allele-Specific Oligonucleotide
PCR-SSCP | Polymerase Chain Reaction-Single Strand Conformation Polymorphism
PFGE | Pulsed Field Gel Electrophoresis
Rep-PCR | Repetitive extragenic palindromic-PCR
RFLP | Restriction Fragment Length Polymorphism
RT-PCR | Reverse Transcriptase Polymerase Chain Reaction
SDA | Strand Displacement Amplification
TC | Target Capture
TMA | Transcription Mediated Amplification

## Laboratory-Developed Molecular Tests

Table 14 Laboratory-Developed Molecular Tests: Bacterial Infectious Diseases

Infectious Agent | Test Use | Method | Assay Type | Laboratory^*^ | Number of Laboratories
Bacteria, identification | Diagnosis | PCR, sequencing | Genotype | 69, 86 | 2
Bacteria, unspecified | Diagnosis (for bacteria identification) | PCR, sequencing | Genotype | 69, 86, 55, 40, 65 | 5
Bacteria, unspecified | Diagnosis (for molecular typing) | PCR, sequencing, ribotyping, rep-PCR | Quant | 20, 39 | 2
Bartonella henselae | Diagnosis | PCR, real-time PCR, HYB, sequencing | Qual, genotype | 17, 33, 86, 89, 40, 55, 65 | 7
Bartonella quintana | Diagnosis | PCR, real-time PCR, sequencing | Qual, genotype | 33, 86, 40, 65 | 4
Bartonella species | Diagnosis | PCR | Qual | 39, 55 | 2
Bordetella pertussis | Diagnosis | PCR, real-time PCR, RFLP, HYB | Qual | 2, 16, 17, 18, 24, 28, 87, 40, 55, 65 | 10
Bordetella pertussis | Diagnosis | PCR, gel | Qual | 39 | 1
Bordetella pertussis and Bordetella parapertussis | Diagnosis | Real-time PCR | Qual | 6, 33, 62, 73, 40, 55, 65 | 7
Borrelia burgdorferi | Diagnosis | PCR, HYB | Qual | 6, 13, 33, 39, 40, 55, 65 | 7
Chlamydia pneumoniae | Diagnosis | PCR, real-time PCR, HYB | Qual | 2, 17, 33, 39, 41, 77, 89, 40, 55, 65 | 10
Clostridium difficile | Diagnosis | PCR | Genotype | 86, 40, 55, 65 | 4
Clostridium difficile | Diagnosis | Real-time PCR | Qual | 33 | 1
Ehrlichia chaffeensis (HME) and anaplasma phagocytophilium (HE) | Diagnosis | PCR, real-time PCR | Qual | 33, 39, 89, 40, 55, 65 | 6
Enterococcus, vancomycin resistance VRE vanA, vanB | Treatment decisions, prognosis | PCR, real-time PCR | Qual | 17, 24, 39, 78, 40, 55, 65 | 7
Escherichia coli, EHEC E coli VTI/VTII Enterohemorrhagic E coli O157:H7 | Diagnosis | Real-time PCR | Qual | 69, 40, 55, 65 | 4
Helicobacter pylori | Diagnosis | PCR | Qual | 69, 40, 55, 65, 71 | 5
Legionella pneumophila | Diagnosis | PCR, real-time PCR, HYB | Qual | 33, 39, 41, 40, 55, 65 | 6
Legionella species | Diagnosis | PCR, HYB | Qual | 2, 6, 40, 55, 65 | 5
Legionella species | Diagnosis | Real-time PCR | Qual | 33 | 1
Methicillin resistance mecA | Treatment decisions, prognosis | PCR | Not specified | 1, 40, 55, 65 | 4
Mycobacterium avium | Diagnosis | PCR, RFLP | Qual | 10, 55, 65 | 3
Mycobacterium avium complex MAC | Diagnosis | PCR, RFLP | Qual | 10, 65 | 2
Mycobacterium gordonae | Diagnosis | PCR, RFLP | Qual | 10 | 1
Mycobacterium kansasii | Diagnosis | PCR, RFLP | Qual | 10 | 1
Mycobacterium tuberculosis MTB | Diagnosis | PCR, real-time PCR, RFLP | Qual | 10, 30, 31, 89, 40, 55, 65 | 7
Mycobacterium tuberculosis, drug resistance | Treatment decisions, prognosis | PCR, sequencing | Genotype | 33, 40, 55, 65 | 4
Mycobacterium, rapidly growing | Diagnosis | PCR, sequencing | Qual, Genotype | 6, 86, 65 | 3
Mycoplasma genitalium | Diagnosis | PCR, HYB | Qual | 2 | 1
Mycoplasma hominus | Diagnosis | PCR, HYB | Qual | 2 | 1
Mycoplasma pneumoniae | Diagnosis | PCR, real-time, HYB | Qual | 2, 6, 16, 17, 33, 39, 77, 40, 55, 65 | 10
Mycoplasma species/culture confirmation | Diagnosis | PCR, sequencing | Qual | 6, 39, 40, 55, 65 | 5
Rickettsia | Diagnosis | Real-time PCR | Qual | 33 | 1
Shiga like toxins 1 & 2 SLT1 and SLT2 Stx1 and Stx2 | Diagnosis | PCR | Qual | 79, 40, 55, 65 | 4
Staphylococcus aureus, methicillin resistance MRSA mecA | Treatment decisions, prognosis | PCR | Qual | 2, 6, 17, 22, 24, 31, 41, 58, 77, 40, 55, 65 | 12
Tropheryma whippelii | Diagnosis | Real-time PCR | Qual | 33, 55, 65 | 3
Ureaplasma urealyticum mycoplasma hominis mycoplasma genitalium | Diagnosis | PCR, HYB | Qual | 2, 40, 55, 65 | 4

* Refer to Table 12 for Identification Number of Laboratory.

Table 15 Laboratory Developed Molecular Tests: Viral Infectious Diseases

Infectious Agent | Test Use | Method | Assay Type | Laboratory^*^ | Number
Acute viral hepatitis panel, HAV, HBC, HCV | Diagnosis | RT, PCR | Qual | 38, 65 | 2
Adenovirus respiratory virus | Diagnosis | PCR, sequencing | Genotype | 39, 65 | 2
Adenovirus respiratory virus | Diagnosis | PRC, real-time PCR, HYB | Quant, Qual | 5, 33, 55, 39, 77, 79, 82 | 7
BK virus | Treatment decisions, prognosis | Real-time PCR | Quant | 2, 30, 31, 33, 55, 39, 65, 77, 79, 82 | 10
C-C-chemokine receptor type 2, 64I variant CCR2-64I | Diagnosis, prognosis | PCR, NASBA | Qual | 50 | 1
Cytomegalovirus (CMV) | Treatment decisions, prognosis | PCR, real-time PCR, HYB, RT, in situ | Qual, Quant | 1, 2, 6, 12, 17, 33, 39, 40, 41, 52, 58, 59, 64, 65, 71, 74, 77, 79, 80, 82, 87, 89, 90, 91 | 24
Cytomegalovirus, foscarnet resistance CMV | Treatment decisions, prognosis | PCR, sequencing | Genotype | 77 | 1
Cytomegalovirus, ganciclovir, foscarnet and cidofovir resistance CMV | Treatment decisions, prognosis | PCR, sequencing | Genotype | 33, 39, 77 | 3
Dengue virus | Diagnosis | Real-time RT, PCR | Qual | 33, 65 | 2
Enterovirus echovirus coxsackievirus | Diagnosis | Real-time RT, PCR, real-time PCR, sequencing, HYB | Qual | 2, 5, 14, 16, 17, 24, 30, 31, 33, 39, 40, 41, 64, 65, 73, 77, 78, 79, 87, 89 | 20
Epstein-Barr virus (EBV) | Treatment decisions, prognosis | PCR, real-time PCR, HYB, in situ | Qual, Quant | 6, 12, 14, 17, 30, 31, 33, 55, 39, 41, 49, 58, 59, 65, 71, 73, 74, 75, 77, 79, 80, 82, 87, 89, 90, 91, 93 | 27
Hepatitis A virus (HAV) | Diagnosis | RT, PCR, PFGE | Qual | 38, 65 | 2
Hepatitis B virus (HBV) | Diagnosis, prognosis | PCR, real-time PCR, RFLP, sequencing, HYB | Qual, Quant | 2, 33, 55, 38, 65, 71, 82 | 7
Hepatitis C virus (HCV) | Diagnosis | PCR, real-time PCR, HYB, RT | Qual, Quant | 55, 38, 58, 65, 71, 87 | 6
Hepatitis C virus, genotyping HCV | Diagnosis, prognosis, treatment decisions | RT, PCR, sequencing | Genotype | 39, 82 | 2
Hepatitis D virus (HDV) | Diagnosis | Real-time RT, PCR | Qual | 33, 65 | 2
Hepatitis G virus (HGV) | Diagnosis | RT, PCR, HYB | Qual | 33 | 1
Herpes simplex virus (1 & 2) HSV1; HSV2 | Diagnosis, prognosis | PCR, real-time PCR, HYB, in situ | Qual, Quant | 1, 2, 5, 6, 12, 14, 16, 17, 24, 28, 30, 31, 33, 39, 40, 41, 58, 59, 64, 65, 73, 74, 77, 78, 79, 82, 83, 87, 89, 90, 91, 93 | 32
Herpes virus panel CMV, HSV1, HSV2, EBV, VZV, HHV6 | Diagnosis | PCR | Qual | 79 | 1
HTLV I/II | Diagnosis | PCR, real-time PCR, HYB | Qual | 33, 49, 50, 82 | 4
Human herpes virus 6 (HHV-6) | Diagnosis, prognosis | PCR, real-time PCR, HYB | Qual, Quant | 12, 71, 33, 55, 58, 77, 87, 89 | 8
Human herpes virus 7 (HHV-7) | Diagnosis, prognosis | PCR, real-time PCR, HYB | Qual, Quant | 12, 33, 58, 77, 89 | 5
Human herpes virus 8 (HHV-8) KSHV | Diagnosis, prognosis | RT, PCR, real-time PCR, HYB | Qual, Quant | 5, 12, 33, 55, 49, 50, 58, 87, 89, 64, 71, 77, 79 | 13
Human immunodeficiency virus 1 (HIV-1) | Diagnosis | PCR, HYB, RT-PCR, sequencing | Qual, Quant | 6, 14, 17, 30, 55, 58, 65 | 7
Human immunodeficiency virus 2 (HIV-2) | Diagnosis | PCR, HYB | Qual | 33, 65 | 2
Human metapneumovirus | Diagnosis | Real-time RT-PCR | Qual | 33, 65 | 2
Human papillomavirus (HPV) | Diagnosis, prognosis | PCR, HYB, in situ | Qual | 6, 50, 58, 65, 80, 87 | 6
Influenza A & B respiratory virus | Diagnosis | Real-time RT-PCR, real-time PCR, HYB | Qual | 5, 33, 65, 89 | 4
JC virus | Diagnosis, prognosis | PCR, real-time PCR, HYB | Qual, Quant | 2, 33, 55, 39, 40, 59, 65, 77, 79, 82 | 10
Morbillivirus | Diagnosis | Real-time RT, PCR | Qual | 5 | 1
Norwalk virus | Diagnosis | Real-time RT, PCR | Qual | 33, 40 | 2
Parechovirus | Diagnosis | Real-time RT, PCR, HYB | Qual | 33, 39 | 2
Parvovirus | Diagnosis | PCR, real-time PCR, HYB, in situ, southern blot | Qual | 6, 16, 17, 31, 33, 39, 40, 75, 77, 79, 87, 89 | 12
Respiratory virus, panel | Diagnosis | RT, PCR, HYB | Qual | 6 | 1
RSV, influ A, parainflu123 Influenza A Respiratory virus | Diagnosis | Real-time RT, PCR | Qual | 33, 65, 77, 89 | 4
SARS coronavirus | Diagnosis | Real-time RT, PCR | Qual | 33, 65, 74 | 3
Stromal cell-derived factor 1, mutation analysis SDF-1 | Prognosis, treatment decisions | PCR | Qual | 50 | 1
Varicella zoster virus (VZV) | Diagnosis | PCR, real-time PCR, real-time RT, gel, HYB | Qual, Quant | 2, 6, 12, 17, 31, 33, 39, 41, 58, 77, 79, 82, 87, 89, 93 | 15
West Nile virus | Diagnosis | Real-time PCR | Qual | 14, 33, 40, 65, 79 | 5

* Refer to Table 12 for Identification Number of Laboratory.

Table 16 Laboratory-Developed Molecular Tests: Parasitic or Fungal Infectious Diseases

Infectious Agent | Test Use | Method | Assay Type | Laboratory^*^ | Number
Aspergillis, screening | Diagnosis | Real-time PCR | Qual | 33 | 1
Babesia microti | Diagnosis | Real-time PCR | Qual | 33, 55, 40, 65 | 4
Blastomyces dermatitidis | Diagnosis, prognosis | Probe hybridization | Qual | 65 | 1
Coccidioides immitis | Diagnosis, prognosis | Probe hybridization | Qual | 65 | 1
Encephalitozoon species microsporidia | Diagnosis | Real-time PCR | Qual | 66 | 1
Histoplasma capsulatum | Diagnosis, prognosis | Real-time PCR | Qual | 33, 65 | 2
Mold, identification | | PCR, sequencing | Genotype | 86 | 1
Pneumocystis carinii | Diagnosis, prognosis | PCR | Qual | 58, 64, 71 | 3
Toxoplasma gondii | Diagnosis | PCR, HYB | Qual | 5, 6, 31, 33, 40, 58 | 6
Trichomonas vaginalis | Diagnosis | Real-time PCR | Qual | 31, 55, 40, 65 | 4
Yeast, identification | Diagnosis | PCR, sequencing | Genotype | 60, 86 | 2

* Refer to Table 12 for Identification Number of Laboratory.

Table 17 Laboratory-Developed Molecular Tests: Solid Tumors

Gene | Tumor Type/Subtype | Test Use | Test Method | Assay Type | Laboratory^*^ | Number of Laboratories
APC | Colorectal cancer, FAP | Diagnosis | PCR-sequencing, Other | Qual | 44, 63, 85 | 3
APC-specific mutation I1307K | Colorectal cancer, Ashkenzai Jewish | Diagnosis | Other | Qual | 39, 63 | 2
BRCA1/BRCA2 | Breast cancer | Diagnosis | PCR-sequencing, PCR-allele specific, Other | Qual | 34, 74, 85 | 3
BRAF | Colon cancer | Diagnosis | Real-time PCR | Qual | 6, 45, 82 | 3
C-kit | Gastrointestinal stromal tumor | Diagnosis | PCR-sequencing, real-time PCR, other | Qual | 5, 6, 34, 55, 40, 42, 52 | 7
Cyclin D1/CCND1/PRAD1 | Head & neck cancer, squamous cell cancer | Diagnosis, prognosis | Real-time PCR | Quant | 5, 45 | 2
DCC | Colorectal cancer | Prognosis | Other | Qual | 27, 63 | 2
DCC/SMAD4 | Colorectal cancer | Diagnosis | PCR capillary gel electrophoresis | Qual | 82 | 1
DPC4 | Colorectal cancer | Prognosis | Other | Qual | 63 | 1
EGFR | Lung cancer, non-small cell lung, glioblastoma, colon cancer | Diagnosis | PCR-sequencing, FISH | Qual | 34, 55, 40, 43, 65, 88 | 6
EWS | Ewing’s sarcoma, clear cell sarcoma | Diagnosis | FISH | Qual | 94 | 1
EWS-ATF1 | Sarcomas, clear cell sarcoma | Diagnosis | PCR-sequencing, PCR-ASO blot | Qual | 79, 81 | 2
EWS-EIAF | Sarcomas, Ewing’s sarcoma | Diagnosis | PCR-sequencing | Qual | 9 | 1
EWS-ERG | Sarcomas, Ewing’s sarcoma | Diagnosis, Prognosis | Real-time PCR, PCR-sequencing, PCR-allele specific, PCR-ASO blot, Other | Qual, Quant | 6, 9, 69, 18, 79, 81, 88 | 7
EWS-ETV1 | Sarcomas, Ewing’s sarcoma | Diagnosis | PCR-sequencing | Qual | 9 | 1
EWS-FEV | Sarcomas, Ewing’s sarcoma | Diagnosis | PCR-sequencing | Qual | 9 | 1
EWSR1 | Sarcomas, Ewing’s/PNET, clear cell sarcoma | Diagnosis | FISH | Qual | 88 | 1
EWS-WT1 | Sarcomas, desmoplastic small round cell tumor | Diagnosis | Other, PCR-sequencing, PCR-allele specific, PCR-ASO blot | Qual | 5, 9, 69, 81 | 4
FKHR | Sarcomas, alveolar rhabdomyosarcoma | Diagnosis | FISH | Qual | 88 | 1
FUS-CHOP | Sarcomas, myxoid liposarcoma | Diagnosis | PCR-allele specific | Quant | 69 | 1
GCC mRNA | Colorectal cancer, metastatic disease | Prognosis, monitoring, treatment decisions | Other | Quant | 67 | 1
HER2/neu/ERBB2 | Breast cancer | Diagnosis, prognosis | Real-time PCR, FISH | Qual, Quant | 6, 55, 40, 65, 74, 74, 88 | 7
HRAS, codon 61 | Thyroid cancer | Diagnosis | Real-time PCR | Qual | 82 | 1
Human androgen receptor (HUMARA) | All tumors | Diagnosis | PCR-restriction digest | Qual | 94 | 1
KIT | Sarcomas, GIST | Diagnosis | Real-time PCR | Quant | 5, 45 | 2
KRAS, codon 12/13 | Colorectal cancer, thyroid cancer, lung cancer, pancreatic cancer | Diagnosis | PCR-sequencing | Qual | 82 | 1
KRAS/Ki-Ras | Lung cancer, non-small cell, endometrial cancer, pancreatic cancer, colorectal cancer | Diagnosis | PCR-sequencing, PCR-SSCP | Qual | 27, 45, 94 | 3
KRAS2/Ki-Ras | Colorectal cancer, pancreatic cancer | Diagnosis | PCR-SSCP | Qual | 63, 94, 45, 27 | 4
MGMT | Glioblastoma | Diagnosis | Real-time PCR | Quant | 82 | 1
Mismatch repair genes | Endometrial cancer, colorectal cancer, HNPCC/Lynch syndrome | Diagnosis | Other, PCR-allele specific, PCR-sequencing | Qual | 5, 27, 34, 39, 40, 42, 61, 94, 44, 72, 82 | 11
MLH1 | Colorectal cancer, HNPCC/Lynch syndrome, endometrial cancer | Diagnosis | Real-time PCR, other | Quant, Qual | 27, 55, 44, 45, 65, 11, 26, 51, 64, 72, 6, 82, 94 | 13
MSH2 | Ovarian cancer, colorectal cancer, HNPCC/Lynch syndrome, endometrial cancer | Diagnosis | Southern blot, other | Qual | 55, 40, 44, 65, 11, 26, 51, 64, 72, 6, 82, 94 | 12
MSH6/GTBP | Colorectal cancer, HNPCC/Lynch syndrome, endometrial cancer | Monitoring | Other | Qual | 55, 40, 44, 65, 11, 26, 51, 64, 72, 6, 82, 94 | 12
NBL1 | Sarcomas, GIST | Diagnosis | Real-time PCR | Quant | 5 | 1
N-myc/MYCN | Neuroblastoma | Diagnosis, Prognosis | FISH, Southern blot, Other | Qual, Quant | 44, 74, 88 | 3
NRAS, codon 61 | Thyroid cancer | Diagnosis | Real-time PCR | Qual | 82 | 1
p15, p16/CDKN2A/MTS1 | Glioblastoma, astrocytoma | Diagnosis | FISH | Quant | 43, 26 | 2
p53/TP53 | Astrocytoma | Prognosis | Other | Qual | 55, 40, 65, 89, 4, 27 | 6
PAX3-FKHR | Sarcomas, alveolar rhabdomyosarcoma | Diagnosis | Real-time PCR, PCR-sequencing, PCR-allele specific, PCR-restriction digest, PCR-ASO blot | Qual, Quant | 5, 6, 9, 18, 69, 79, 81 | 7
PAX7-FKHR | Sarcomas, alveolar rhabdomyosarcoma | Diagnosis | Real-time PCR, PCR-sequencing, PCR-allele specific, PCR-restriction digest, PCR-ASO blot | Qual, Quant | 5, 6, 9, 69, 79, 81 | 6
PDGFB-COL1A1 | Sarcomas, dermatofibrosarcoma protuberans | Diagnosis | PCR-allele specific | Quant | 69 | 1
PDGFRa | Gastrointestinal stromal tumor | Diagnosis | Other | Qual | 6 | 1
PMS2 | Colorectal cancer, HNPCC/Lynch syndrome, endometrial cancer | Diagnosis | Other | Quant | 44, 11, 26, 51, 64, 72, 94 | 7
PRSS1 | Pancreatic cancer, hereditary pancreatitis | Diagnosis | PCR-sequencing | Qual | 44 | 1
PTEN | Astrocytoma | Diagnosis | FISH | Quant | 43, 51 | 2
RET proto-oncogene | MEN 2A, MEN 2B | Diagnosis | PCR-sequencing, PCR-restriction digest | Qual | 5, 9, 55, 40, 44, 65, 85, 51, 19, 82 | 10
RET/PTC1 and RET/PTC3 | Thyroid cancer, thyroid papillary carcinoma | Diagnosis | Real-time PCR | Qual | 82 | 1
SYT | Sarcomas, synovial sarcoma | Diagnosis | FISH | Qual | 88 | 1
SYT-SSX1 | Sarcomas, synovial sarcoma | Diagnosis | Real-time PCR, PCR-sequencing, PCR-allele specific, PCR-ASO blot, FISH | Qual, Quant | 5, 6, 9, 69, 79, 81, 94, 54 | 8
SYT-SSX2 | Sarcomas, synovial sarcoma | Diagnosis | Real-time PCR, PCR-sequencing, PCR-allele specific, PCR-ASO blot | Qual | 5, 6, 9, 69, 79, 81, 94, 54 | 8
Unknown | Oligodendroglioma, glioblastoma, astrocytoma | Diagnosis | Other, FISH | Qual, Quant | 29, 39, 43, 88, 89, 82, 87, 94 | 8
VHL | Various | Diagnosis | Southern blot, PCR-sequencing | Qual | 5, 19 | 2
DBC1 | Bladder cancer | Prognosis | Not specified | Not specified | 42 | 1
L-myc | Lung cancer, small cell carcinoma, breast cancer | Diagnosis, prognosis | Not specified | Not specified | 42 | 1
p15/CDKN2B | Pancreatic cancer | Diagnosis | Not specified | Not specified | 42 | 1

* Refer to Table 12 for Identification Number of Laboratory.

Table 18 Laboratory-Developed Molecular Tests: Hematopathology

WHO Category | Gene | Gene Specifics | Test Use | Test Method | Assay Type | Laboratory^*^ | Number of Laboratories
Mastocytosis & Myelodysplastic | BCR-ABL | BCR-ABL micro/mu-bcr/P230, BCR-ABL minor/m-bcr/P190, BCR-ABL major/m-bcr/P210, unspecified | Diagnosis, prognosis, monitoring | RT-PCR, real-time PCR, FISH | Qual, Quant | 81, 9, 5, 46, 61, 40, 55, 65, 39, 18, 74, 86, 90 | 13
Mastocytosis & Myelodysplastic | KIT (SCFR) | Unspecified | Diagnosis, Prognosis | PCR for specific mutation detection | Qual | 42, 44 | 2
Mastocytosis & Myelodysplastic | MLL(HRX) | Unspecified | Diagnosis, prognosis | FISH | Quant | 46, 40, 55, 65, 42 | 5
Mastocytosis & Myelodysplastic | Not specified | Unspecified | Diagnosis, prognosis | Conventional cytogenetics/karyotype, FISH | Quant, Qual | 42, 46 | 2
Mastocytosis & Myelodysplastic | PDGFRB-TEL (ETV6) | Unspecified | Diagnosis, prognosis | Conventional cytogenetics/karyotype | Quant | 44 | 1
Acute Myeloid Leukemias | AF9-MLL(HRX) | Unspecified | Diagnosis, prognosis | Conventional cytogenetics/karyotype, FISH | Qual, Quant | 42, 46, 40, 55, 65 | 5
Acute Myeloid Leukemias | AML 1(RUN1)(CBFa)/ETO | Unspecified | Diagnosis, prognosis | FISH | Quant | 46, 18 | 2
Acute Myeloid Leukemias | BCR-ABL | Unspecified, BCR-ABL, BCR-ABL major/M-bcr/P210, BCR-ABL minor/M-bcr/P190 | Diagnosis, prognosis, monitoring | RT-PCR, real-time PCR, FISH, PCR | Qual, Quant | 9, 29, 46, 47, 61, 79, 5, 81, 90, 40, 55, 65, 6, 39, 74, 18, 86 | 17
Acute Myeloid Leukemias | CBFb/MYH11 | Unspecified | Diagnosis, prognosis | FISH, RT-PCR | Quant, Qual | 46, 55, 18 | 3
Acute Myeloid Leukemias | DEK-CAN | Unspecified | Prognosis | Conventional cytogenetics/karyotype | Qual, Quant | 42, 43 | 2
Acute Myeloid Leukemias | ETO (CBFA2T1)-AML1 (RUNX1orCBFA2) | Unspecified | Diagnosis, prognosis | FISH | Quant | 46, 18 | 2
Acute Myeloid Leukemias | Ig Heavy/Light | Ig heavy chain/IgH/14q32, unspecified | Diagnosis, prognosis, monitoring | PCR, FISH | Qual, Quant | 47, 46, 5, 80, 81, 40, 6, 39, 63, 74, 18, 78, 86 | 13
Acute Myeloid Leukemias | MLL(HRX) | Unspecified | Diagnosis, prognosis | Conventional cytogenetics/karyotype, FISH | Qual, Quant | 42, 46, 47, 40, 55, 65 | 6
Acute Myeloid Leukemias | MLL(HRX)-ELL | Unspecified | Prognosis | Conventional cytogenetics/karyotype, FISH | Qual, Quant | 42, 46, 40, 55, 65 | 5
Acute Myeloid Leukemias | MLL(HRX)-ENL | Unspecified | Diagnosis, prognosis | Conventional cytogenetics/karyotype, FISH | Qual, Quant | 42, 46, 40, 55, 65 | 5
Acute Myeloid Leukemias | MOV-CBP(CREBBP) | Unspecified | Diagnosis, prognosis | Conventional cytogenetics/karyotype, FISH | Qual, Quant | 42, 46 | 2
Acute Myeloid Leukemias | Not specified | Unspecified | Diagnosis, prognosis | Conventional cytogenetics/karyotype, FISH | Qual, Quant | 42, 46, 47 | 3
Acute Myeloid Leukemias | NPM-RARa | Unspecified | Diagnosis, prognosis | Conventional cytogenetics/karyotype, FISH | Qual, Quant | 42, 46 | 2
Acute Myeloid Leukemias | NUMA-RARa | Unspecified | Diagnosis, prognosis | Conventional cytogenetics/karyotype, FISH | Qual, Quant | 42, 46 | 2
Acute Myeloid Leukemias | PLZF-RARa | Unspecified | Prognosis | Conventional cytogenetics/karyotype, FISH | Qual, Quant | 42, 46 | 2
Acute Myeloid Leukemias | PML-RARa | Unspecified | Diagnosis, prognosis, monitoring | RT-PCR, real-time PCR, FISH | Qual, Quant | 9, 30, 46, 47, 81, 40, 55, 6, 44, 18 | 10
Acute Myeloid Leukemias | STAT5B-RARa | Unspecified | Diagnosis, prognosis | Conventional cytogenetics/karyotype, FISH | Qual, Quant | 42, 46 | 2
Acute Myeloid Leukemias | TCR genes | TCR gamma/7p15, unspecified | Prognosis | PCR | Qual | 47, 5, 81, 40, 55, 65, 6, 39, 44, 63, 74, 18, 78 | 13
Acute Myeloid Leukemias | TEL(ETV6) | Unspecified | Diagnosis, prognosis | FISH | Quant | 46, 65, 55 | 3
B and T Cell Neoplasms | ATM | Unspecified | Diagnosis, prognosis | FISH | Quant | 46 | 1
B and T Cell Neoplasms | BCL-1 | Unspecified, BCL-1 MTC region, BCL-1 unspecified breaking point | Diagnosis, prognosis | FISH, PCR | Quant, Qual | 46, 40, 55, 65, 6, 86 | 6
B and T Cell Neoplasms | BCL-1 (PRAD1 or CCND1 or cyclin D1) | BCL-1 MTC and outside of MTC, BCL-1 unspecified breakpoint, unspecified, BCL-1 MTC region | Diagnosis, prognosis | RT-PCR, real-time PCR, PCR | Quant, Qual | 5, 46, 94, 40, 55, 65, 6, 86 | 8
B and T Cell Neoplasms | BCL-1-Igh | BCL-1 MTC and outside of MTC, BCL-1 unspecified breakpoint, BCL-1 MTC region, unspecified | Diagnosis, prognosis, monitoring | RT-PCR, real-time PCR, PCR | Quant, Qual | 5, 46, 40, 55, 65, 6, 86 | 7
B and T Cell Neoplasms | BCL-2 | BCL-2 MBR, BCL-2 mcr, unspecified, BCL-2 unspecified breaking point | Diagnosis, prognosis, monitoring | RT-PCR, PCR, real-time PCR, FISH | Qual, Quant | 5, 9, 30, 46, 47, 61, 81, 89, 90, 94, 40, 55, 65, 6, 72, 78, 86 | 17
B and T Cell Neoplasms | BCL-3 | BCL-2 MBR, BCL-2 mcr | Prognosis | Real-time PCR | Qual | 30 | 1
B and T Cell Neoplasms | BCL-6(LAZ3) | Unspecified | Diagnosis, prognosis | FISH | Quant | 46, 65 | 2
B and T Cell Neoplasms | BCR-ABL | Unspecified, BCR-ABL major/M-bcr/P210, BCR-ABL minor/m-bcr/P190, BCR-ABL breaking point not specified | Diagnosis, prognosis, monitoring | RT-PCR, FISH, real-time PCR | Qual, Quant | 5, 9, 46, 81, 90, 40, 39, 6, 74, 80, 86 | 11
B and T Cell Neoplasms | BIRC3(API2)-MALT1(MLT) | Unspecified | Diagnosis, prognosis | FISH, PCR, PCR for specific mutation detection | Quant, Qual | 46, 40, 55, 65, 6, 43 | 6
B and T Cell Neoplasms | EBV | Unspecified | Diagnosis, prognosis, monitoring | PCR, RT-PCR, FISH, real-time PCR, Southern | Qual, Quant | 5, 46, 94, 40, 55, 65, 43, 74, 18, 78 | 10
B and T Cell Neoplasms | HHV-8/KSHV viral | Unspecified | Diagnosis, prognosis, monitoring | RT-PCR, PCR | Qual | 5, 94, 65 | 3
B and T Cell Neoplasms | Ig Heavy/Light | Ig heavy chain/IgH/14q32, unspecified, Ig light chain/IgK/2p12, Ig light chain/IgL/22q11.2, Ig(unspecified gene) | Diagnosis, prognosis, monitoring | PCR, FISH, RT-PCR, Southern | Qual, Quant | 5, 9, 46, 47, 61, 80, 81, 89, 94, 40, 39, 6, 74, 18, 78, 86, 47 | 17
B and T Cell Neoplasms | MLL(HRX) | Unspecified | Diagnosis, prognosis | FISH | Quant | 46, 40, 55, 65 | 4
B and T Cell Neoplasms | MYC | Unspecified | Diagnosis, prognosis | FISH | Quant | 46, 40, 55, 65 | 4
B and T Cell Neoplasms | MYC-IgH and variants | Unspecified | Diagnosis, prognosis | FISH | Qual, Quant | 94, 46, 40, 55, 65 | 5
B and T Cell Neoplasms | not specified | Unspecified | Diagnosis, prognosis | FISH, PCR | Quant, Qual | 46, 81, 89 | 3
B and T Cell Neoplasms | NPM1-ALK or other ALK | Unspecified | Diagnosis, prognosis, monitoring | RT-PCR, real-time PCR | Qual, Quant | 5, 46, 40, 55, 65, 18 | 6
B and T Cell Neoplasms | NPM-ALK | Unspecified | Diagnosis, Prognosis, monitoring | PCR, FISH, real-time PCR, RT-PCR | Qual, Quant | 5, 46, 40, 55, 65, 18 | 6
B and T Cell Neoplasms | P53 | Unspecified | Diagnosis, prognosis | FISH | Quant | 46, 40, 55, 65 | 4
B and T Cell Neoplasms | PBX-E2A | Unspecified | Diagnosis, prognosis | Conventional cytogenetics/karyotype, FISH, RT-PCR, real-time PCR | Qual, Quant | 42, 46, 6, 43, 18 | 5
B and T Cell Neoplasms | TCR genes | Unspecified, TCR gamma/7p15 | Diagnosis, prognosis, monitoring | PCR | Qual, Quant | 5, 47, 61, 81, 89, 94, 40, 55, 65, 39, 6, 43, 74, 18, 78, 86 | 16
B and T Cell Neoplasms | TEL(ETV6)/AML1 | Unspecified | Diagnosis, prognosis | Real-time PCR, RT-PCR | Qual | 6, 18 | 2
Chronic Myeloproliferative Diseases | BCR-ABL | BCR-ABL major/M-bcr/P210, unspecified, BCR-ABL minor/m-bcr/P190, BCL-ABL, BCR-ABL micro/mu-bcr/P230, BCR-ABL breaking point not specified | Diagnosis, prognosis, monitoring | RT-PCR, real-time PCR | Qual, Quant | 5, 9, 29, 52, 61, 80, 81, 90, 40, 55, 65, 39, 6, 42, 72, 74, 18, 86 | 18
Chronic Myeloproliferative Diseases | Ig Heavy/Light | Ig heavy chain/IgH/14q32, unspecified | Diagnosis, prognosis | PCR | Qual | 80, 40 | 2
Chronic Myeloproliferative Diseases | JAK2 | Unspecified | Diagnosis, prognosis | PCR | Qual | 52, 55, 65 | 3
Chronic Myeloproliferative Diseases | PDGFRB-TEL(ETV6) | Unspecified | Prognosis | Conventional cytogenetics/karyotype | Qual, Quant | 42, 43 | 2
Histiocytic and Dendritic-Cell Neoplasms | HUMARA | Unspecified | Diagnosis, prognosis, monitoring | PCR | Qual | 89 | 1
Histiocytic and Dendritic-Cell Neoplasms | Ig Heavy/Light | Ig heavy chain/IgH/14q32, unspecified | Diagnosis, prognosis | PCR, RT-PCR, FISH, Southern | Qual | 5, 46, 81, 40, 39, 6, 74, 18, 78, 86 | 10
Histiocytic and Dendritic-Cell Neoplasms | TCR genes | Unspecified | Diagnosis, prognosis | PCR, Southern | Qual, Quant | 5, 81, 89, 40, 55, 65, 39, 6, 74, 18, 78, 86 | 12
Hodgkin Lymphoma | Ig Heavy/Light | Ig heavy chain/IgH/14q32, unspecified | Diagnosis, prognosis | PCR, FISH, PCR and mutation scanning | Qual, Quant | 5, 46, 81, 40, 39, 6, 74, 18, 78, 80, 86, 90, 30 | 13

* Refer to Table 12 for Identification Number of Laboratory.

## Molecular Tests Offered by Laboratories Using Commercial ASRs or Kits

Table 19 Tests Using Commercial Kits: Bacterial Infectious Diseases

Infectious Agent | Test Use | Method | Assay Type | Source of Kits | Laboratory^*^ | Number
Bacteria, identification | Diagnosis | PCR, LiPA | Quant | Chemicon | 7 | 1
Bacteria, molecular typing | Prognosis, treatment decisions | rep-PCR | Genotype | Bacterial Barcodes | 69 | 1
Bacteria, molecular typing | Prognosis, treatment decisions | Probe hybridization | Semi-quant | Bayer (Innogenetics), 5’ nc (UTR) region genotyping | 7 | 1
Bacteria, molecular typing | Prognosis, treatment decisions | PFGE | Qual | Bio-Rad | 2 | 1
Bacteria, molecular typing | Prognosis, treatment decisions | PFGE | Quant | Bio-Rad | 20 | 1
Bacteria, molecular typing | Prognosis, treatment decisions | PFGE | Genotype | Epidemiologic Investigations | 6, 22, 29, 31, 39, 77, 86, 93 | 8
Bacteria, molecular typing | Diagnosis | Rep-PCR | Genotype | bioMerieux | 66 | 1
Bartonella quintana | Diagnosis | PCR | Quant | Epidemiologic Investigations | 7 | 1
Bordetella pertussis | Diagnosis | Real-time PCR | Qual | Cepheid | 79 | 1
Bordetella pertussis | Diagnosis | Real-time PCR | Qual | Pordessa | 10 | 1
Chlamydia pneumonia/psittaci, legionella pneumophila and mycoplasma pneumoniae | Diagnosis | LCR | Quant | Biosource | 7 | 1
Chlamydia trachomatis (CT) | Diagnosis | LCR | Qual | Abbott | 6, 13, 53, 64, 74, 77, 83 | 7
Chlamydia trachomatis (CT) | Diagnosis | SDA | Qual | Becton-Dickinson | 1, 2, 10, 16, 22, 30, 50, 75, 79 | 9
Chlamydia trachomatis (CT) | Diagnosis | Direct probe | Qual | Genprobe | 6, 50, 53, 58, 86, 93 | 6
Chlamydia trachomatis (CT) | Diagnosis | PCR, HYB | Qual | Roche | 4, 18, 29, 31, 39, 41, 46, 66, 73, 74, 76, 77, 78, 91, 92 | 15
Escherichia coli, EHEC E coli VTI/VTII enterohemorrhagic E coli O157:H7 | Diagnosis | Hybrid capture | Qual | Commercial | 7 | 1
Methicillin resistance mecA | Treatment decisions | PCR, PFGE | Not specified | Bio-Rad | 22 | 1
Mycobacterium avium | Diagnosis | PFGE | Quant | Bio-Rad | 20 | 1
Mycobacterium avium complex MAC | Diagnosis | Direct probe | Qual | Genprobe | 6, 29, 39, 50, 62, 66, 76, 77, 86, 73, 75, 93, 73 | 13
Mycobacterium avium complex MAC | Diagnosis | SDA | Qual | Becton Dickinson | 75 | 1
Mycobacterium gordonae | Diagnosis | PFGE | Quant | Bio-Rad | 20 | 1
Mycobacterium gordonae | Diagnosis | Direct probe | Qual | Genprobe | 29, 39, 50, 62, 75, 76, 77, 86, 93 | 9
Mycobacterium kansasii | Diagnosis | Direct probe | Qual | Genprobe | 29, 39, 50, 76 | 4
Mycobacterium tuberculosis MTB | Diagnosis | Direct probe, TMA | Qual | Genprobe | 6, 22, 29, 39, 50, 62, 73, 76, 92, 93 | 10
Mycobacterium tuberculosis MTB | Diagnosis | PCR, HYB | Qual | Roche | 33, 66, 86, 87 | 4
Mycobacterium tuberculosis, culture confirmation | Diagnosis | PCR | Qual | Genprobe | 73 | 1
Mycobacterium tuberculosis, culture confirmation | Diagnosis | Direct Probe | Qual | Genprobe | 1, 6, 29, 31, 39, 50, 66, 79, 86, 94, 73, 75, 76, 77, 93 | 15
Mycobacterium tuberculosis, molecular typing MTB | Diagnosis | RFLP | Genotype | Epidemiologic Investigations | 39 | 1
Mycobacterium, rapidly growing | Diagnosis | PFGE | Quant | Bio-Rad | 20 | 1
Neisseria gonorrhoeae | Diagnosis | PCR, LCR | Qual | Abbott | 6, 13, 53, 64, 77, 83, 86 | 7
Neisseria gonorrhoeae | Diagnosis | SDA | Qual | Becton-Dickinson | 1, 2, 10, 16, 22, 30, 50 75, 79 | 9
Neisseria gonorrhoeae | Diagnosis | Direct probe | Qual | Genprobe | 6, 50, 53, 58, 94, 93 | 6
Neisseria gonorrhoeae | Diagnosis | PCR, HYB | Qual | Roche | 4, 18, 29, 31, 39, 41, 46, 66, 73, 74, 76, 91, 92 | 13
Staphylococcus aureus, methicillin resistance MRSA mecA | Treatment decisions | Real-time PCR | Qual | Infection Diagnostic | 10 | 1
Staphylococcus aureus, methicillin resistance MRSA mecA | Diagnosis | PCR | Qual | Other | 50 | 1
Staphylococcus aureus, methicillin resistance MRSA mecA | Treatment decisions | Real-time PCR | Qual | Roche | 39, 69 | 2

* Refer to Table 12 for Identification Number of Laboratory.

Table 20 Tests Using Commercial Kits: Viral Infectious Diseases

Infectious Agent | Test Use | Method | Assay Type | Source of Kits | Laboratory^*^ | Number
BK virus | Prognosis | Real-time PCR | Qual, Quant | Nanogen | 32 | 1
Cytomegalovirus CMV | Prognosis | Real-time PCR | Quant | Abbott, In house | 24 | 1
Cytomegalovirus CMV | Prognosis | PCR | Qual | Argene Biosoft | 50 | 1
Cytomegalovirus CMV | Prognosis | NASBA | Qual | bioMerieux | 50 | 1
Cytomegalovirus CMV | Prognosis | HYB | Semi-quant | Digene | 16, 29, 53, 77 | 4
Cytomegalovirus CMV | Prognosis | Real-time RT, PCR | Quant | Nanogen | 32 | 1
Cytomegalovirus CMV | Prognosis | PCR, real-time PCR, HYB | Qual, Quant | Roche | 6, 14, 22, 30, 39, 66, 70, 73, 91 | 9
Enterovirus Echovirus Coxsackievirus | Diagnosis | NASBA | Qual | bioMerieux | 50, 92 | 2
Enterovirus Echovirus Coxsackievirus | Diagnosis | NASBA | Qual | Organon-Teknika | 93 | 1
Enterovirus Echovirus Coxsackievirus | Diagnosis | RT, PCR, HYB | Qual | Synthetic Genetics | 1, 7, 18 | 3
Epstein-Barr virus EBV | Prognosis | Real-time PCR | Qual | Abbott, In house | 24 | 1
Epstein-Barr virus EBV | Prognosis | PCR, HYB | Qual, Quant | Argene Biosoft | 50 | 1
Epstein-Barr virus EBV | Prognosis | Real-time PCR | Qual | Nanogen | 32 | 1
Epstein-Barr virus EBV | Prognosis | Real-time PCR | Quant | Roche | 70 | 1
Hepatitis B virus HBV | Diagnosis, prognosis | HYB | Quant | Digene | 73, 81 | 2
Hepatitis B virus HBV | Diagnosis, prognosis | PCR, real-time PCR, HYB | Quant | Roche | 6, 14, 33, 39, 50, 66, 70, 76, 90, 92 | 10
Hepatitis B virus, drug resistance | Diagnosis, prognosis | PCR, LiPA | Genotype | Bayer | 14 | 1
Hepatitis B Virus, drug resistance | Diagnosis, prognosis, treatment decisions | PCR, sequencing | Genotype | Visible Genetics | 14 | 1
Hepatitis C virus (HCV) | Diagnosis | PCR, real time, PCR, RT, real-time RT | Genotype, Qual, Quant | Abbott | 78. 79, 84 | 3
Hepatitis C virus (HCV) | Diagnosis | bDNA, RT, PCR, HYB, TMA, LiPA | Qual, Quant | Bayer | 6, 12, 32, 58, 73, 82, 92, 95 | 8
Hepatitis C virus (HCV) | Diagnosis | bDNA | Quant | Chiron | 22, 53 | 2
Hepatitis C virus (HCV) | Diagnosis | RT, real-time RT, PCR, real-time PCR, HYB | Qual, Quant | Roche | 1, 5, 6, 14, 29, 30, 31, 32, 33, 39, 41, 46, 50, 52, 62, 64, 66, 70, 73, 75, 76, 77, 81, 82, 83, 90, 91, 92, 93 | 29
Hepatitis C virus (HCV) | Diagnosis, prognosis, treatment decisions | Real-time PCR | Genotype | Third Wave | 10 | 1
Hepatitis C virus, genotyping HCV | Diagnosis, prognosis, treatment decisions | PCR, RT, LiPA, RFLP, sequencing | Genotype | Bayer (Innogenetics), 5’ nc (UTR) region genotyping | 1, 2, 6, 14, 30, 33, 46, 52, 62, 73, 74, 75, 77, 79, 92, 93 | 16
Hepatitis C virus, genotyping HCV | Diagnosis, prognosis, treatment decisions | PCR, HYB | Genotype | Third Wave | 90 | 1
Hepatitis C virus, genotyping HCV | Diagnosis, prognosis, treatment decisions | RT, PCR, sequencing | Genotype | Visible Genetics | 50 | 1
Hepatitis C virus, ultrasensitive HCV | Diagnosis, prognosis, treatment decisions | Real-time RT, PCR | Quant | Abbott | 10 | 1
Hepatitis C virus, ultrasensitive HCV | Diagnosis, prognosis | RT, PCR, real-time PCR | Qual, Quant | Roche | 14, 33, 39, 78, 84 | 5
Herpes Simplex Virus (1 & 2) HSV1; HSV2 | Diagnosis | PCR, HYB | Qual | Argene Biosoft | 50 | 1
Herpes Simplex Virus (1 & 2) HSV1; HSV2 | Diagnosis | Real-time PCR | Qual | Roche | 18, 70, 87 | 3
Human Herpes Virus 6 HHV-6 | Diagnosis | PCR, HYB | Qual | Argene Biosoft | 50 | 1
Human Immunodeficiency Virus 1 HIV-1 | Diagnosis, prognosis | RT, PCR, real-time PCR, HYB, sequencing, bDNA | Qual, Quant | Roche | 1, 6, 10, 14, 22, 29, 30, 31, 32, 33, 39, 50, 52, 58, 66, 70, 73, 74, 75, 76, 77, 78, 79, 87, 89, 90, 91, 92, 93 | 29
Human Immunodeficiency Virus 1 HIV-1 | Diagnosis, prognosis | bDNA | Quant | Bayer | 6, 32, 81, 84 | 4
Human Immunodeficiency Virus 1 HIV-1 | Diagnosis, prognosis | NASBA | Quant | bioMerieux | 2 | 1
Human Immunodeficiency Virus 1 HIV-1 | Diagnosis, prognosis | bDNA | Quant | Chiron | 53 | 1
Human Immunodeficiency Virus 1 HIV-1 | Diagnosis, prognosis | NASBA | Quant | Organon-Teknika | 50, 83 | 2
Human Immunodeficiency Virus 1 HIV-1, genotyping | Diagnosis, prognosis | PCR, sequencing | Genotype | Visible Genetics | 1, 14, 30, 50, 73, 77, 87, 89, 90 | 9
Human Immunodeficiency Virus 1, HIV-1 | Diagnosis, prognosis, treatment decisions | RT, PCR, sequencing | Genotype | Abbott | 84 | 1
Human Immunodeficiency Virus 1, Ultrasensitive | Diagnosis, prognosis | RT, PCR, HYB | Quant | Roche | 1, 6, 10, 14, 17, 22, 29, 30, 31, 33, 39, 46, 50, 52, 58, 66, 70, 73, 74, 75, 76, 77, 78, 82, 87, 90, 91, 92, 93 | 29
Human Immunodeficiency Virus, drug resistance | Diagnosis, prognosis, treatment decisions | RT, PCR, sequencing | Genotype | Bayer | 33 | 1
Human Papillomavirus (HPV) | Diagnosis, prognosis | PCR, LiPA | Genotype | Bayer | 58 | 1
Human Papillomavirus (HPV) | Diagnosis, prognosis | Direct Probe | Qual | Chemicon | 1, 31, 92 | 3
Human Papillomavirus (HPV) | Diagnosis, prognosis | PCR, HYB | Qual | Digene | 2, 4, 5, 6, 13, 28, 39, 53, 66, 73, 77, 80, 84 | 13
Human Papillomavirus (HPV) | Diagnosis, prognosis | PCR, LiPA | Qual | Roche | 28 | 1
Human papillomavirus, High Risk Only HPV | Diagnosis | Real-time PCR | Genotype | Third Wave | 57 | 1
Influenza A & B Respiratory Virus | Diagnosis | PCR, HYB | Qual | Flu Vision | 77 | 1
Norwalk virus | Diagnosis | Real-time PCR | Genotype | Cepheid | 79 | 1
RSV, influ A, parainflu123 Influenza A Respiratory virus | Diagnosis | PCR | Qual | Prodessa | 6 | 1
Varicella zoster virus VZV | Diagnosis | PCR, HYB | Qual | Argene Biosoft | 50 | 1

* Refer to Table 12 for Identification Number of Laboratory.

Table 21 Tests Using Commercial Kits: Parasitic or Fungal Infectious Diseases

Infectious Agent | Test Use | Method | Assay Type | Source | Laboratory^*^ | Number
Aspergillis, screening | Diagnosis | NASBA | Qual | bioMerieux | 50 | 1
Blastomyces dermatitidis | Diagnosis, prognosis | Probe hybridization | Qual | Genprobe | 6, 77 | 2
Coccidioides immitis | Diagnosis, prognosis | Probe hybridization | Qual | Genprobe | 6, 39, 66, 77 | 4
Histoplasma capsulatum | Diagnosis, prognosis | Probe hybridization | Qual | Genprobe | 6, 39, 77 | 3
Yeast, molecular typing | Diagnosis, prognosis | PFGE | Qual, Quant | Bio-Rad | 20, 39 | 2

* Refer to Table 12 for Identification Number of Laboratory.

Table 22 Tests Using Commercial Kits: Solid Tumors

Gene | Tumor Type/Subtype | Test Use | Test Method | Assay Type | Laboratory^*^ | Number of Laboratories
ALK | Inflammatory myofibroblastic tumor | Monitoring | FISH | Qual | 55, 40, 45, 65, 79 | 5
Bcl-2 | All tumor types | Diagnosis, Prognosis | Immunohistochemistry | Quant | 68 | 1
Beta-catenin | All tumor types | Prognosis | Immunohistochemistry | Quant | 68 | 1
BRAF | Colon cancer | Diagnosis | Real-time PCR | Qual | 35 | 1
Carbonic Anyhydrase | All tumor types | Diagnosis, Prognosis | Immunohistochemistry | Quant | 68 | 1
Caveolin-1 | All tumor types | Diagnosis, Prognosis | Immunohistochemistry | Quant | 68 | 1
CD24/CD31/CD44 | All tumor types | Diagnosis, Prognosis | Immunohistochemistry | Quant | 68 | 1
Cleaved Caspase 3 | All tumor types | Diagnosis, Prognosis | Immunohistochemistry | Quant | 68 | 1
C-kit | Gastrointestinal stromal tumor | Diagnosis | PCR-sequencing, real-time PCR, other | Qual | 68, 4 | 2
c-MET | All tumor types | Diagnosis, Prognosis | Immunohistochemistry | Quant | 68 | 1
C-MYC | Lung cancer, small cell carcinoma, breast cancer, Burkitt/Burkitt-like lymphoma | Monitoring | FISH | Quant, Qual | 40, 42, 43, 65, 79, 68 | 6
COX-2 | All tumor types | Diagnosis, Prognosis | Immunohistochemistry | Qual | 68 | 1
cyclin D1/CCND1/PRAD1 | Head and neck cancer, squamous cell cancer, breast cancer | Diagnosis, prognosis | FISH | Quant | 42, 45 | 2
DCC | Colorectal cancer | Prognosis | PCR-Allele specific | Quant | 42 | 1
E-cadherin | Prostate cancer, breast cancer, endometrial cancer, gastric cancer | Diagnosis | Immunohistochemistry | Qual | 4 | 1
EGFR | Head and neck cancer, squamous cell cancer, glioblastoma, all tumor types | Diagnosis, treatment decisions | FISH | Quant, Qual | 55, 40, 42, 65, 67, 21, 68, 4 | 8
EpCAM | All tumor types | Diagnosis, Prognosis | Immunohistochemistry | Quant | 68 | 1
ER | Breast cancer | Diagnosis, Prognosis | Immunohistochemistry | Quant | 68 | 1
EWS-ATF1 | Sarcomas, clear cell sarcoma | Diagnosis | FISH | Quant, Qual | 43, 54 | 2
EWS-CHN/TEC/PSCTK4 | Sarcomas, extraskeletal myxoid chondrosarcoma | Diagnosis | FISH | Quant, Qual | 43, 54 | 2
EWS-CHOP | Sarcomas, myxoid liposarcoma | Diagnosis | FISH | Quant | 43 | 1
EWS-EIAF | Sarcomas, Ewing’s sarcoma | Diagnosis | PCR-sequencing | Qual | 9 | 1
EWS-ERG | Sarcomas, Ewing’s sarcoma | Diagnosis | FISH | Quant | 43 | 1
EWS-ETV1 | Sarcomas, Ewing’s sarcoma | Diagnosis | FISH | Quant | 43 | 1
EWS-FEV | Sarcomas, Ewing’s sarcoma | Diagnosis | FISH | Quant | 43 | 1
EWS-WT1 | Sarcomas, desmoplastic small round cell tumor | Diagnosis | FISH | Quant, Qual | 43, 54 | 2
HER2/neu/ERBB2 | Breast cancer, endometrial cancer, uterine serous type | Diagnosis, prognosis | FISH, Immunohistochemistry | Quant, Qual | 4, 32, 55, 40, 42, 43, 54, 57, 63, 65, 67, 79, 94, 68 | 14
IGH/BCL2 | Lymphoma | Monitoring | FISH | Qual | 40, 45, 65, 79 | 4
IGH/CCND1 | Mantle cell lymphoma | Monitoring | FISH | Qual | 79 | 1
IGH/MYC | Burkitt/Burkitt-like lymphoma | Monitoring | FISH | Qual | 79 | 1
Ki-67 | Breast cancer | Diagnosis, Prognosis | Immunohistochemistry | Quant | 68 | 1
KRAS/Ki-Ras | Lung cancer, non-small cell, endometrial cancer, pancreatic cancer, colorectal cancer | Diagnosis | PCR-sequencing, PCR-SSCP | Qual | 35 | 1
KRAS2/Ki-Ras | Colorectal cancer, pancreatic cancer | Diagnosis, treatment decisions | PCR-SSCP | Qual | 56 | 1
MALT | MALT lymphomas | Monitoring | FISH | Qual | 55, 40, 65, 79 | 4
mismatch repair genes | Endometrial cancer, colorectal cancer, HNPCC/Lynch syndrome | Diagnosis | FISH, Other | Qual | 6, 7, 40 | 3
MLH1 | Colorectal cancer, HNPCC/Lynch syndrome, endometrial cancer | Diagnosis | Real-time PCR, Other | Quant, Qual | 4, 37, 48, 15, 21 | 5
MSH2 | Ovarian cancer, colorectal cancer, HNPCC/Lynch syndrome, endometrial cancer | Diagnosis | Southern Blot, Other | Qual | 4, 37, 48, 15, 21 | 5
MSH6/GTBP | Colorectal cancer, HNPCC/Lynch syndrome, endometrial Cancer | Monitoring | Other | Qual | 37, 48, 15, 21 | 4
N-myc/MYCN | Neuroblastoma | Diagnosis, Prognosis | FISH | Qual, Quant | 42, 79 | 2
Not specified | Bladder cancer | Monitoring | FISH | Quant, Qual | 42, 79 | 2
PAX3-FKHR | Sarcomas, alveolar rhabdomyosarcoma | Diagnosis | Real-time PCR, PCR sequencing, PCR-Allele specific, PCR-restriction digest, PCR-ASO blot | Qual, Quant | 15 | 1
PMS2 | Colorectal cancer, HNPCC/Lynch syndrome, endometrial Cancer | Diagnosis | Other | Quant | 37, 48 | 2
PRSS1 | Pancreatic cancer, hereditary pancreatitis | Diagnosis | PCR sequencing | Qual | 3 | 1
PTEN | Astrocytoma | Diagnosis | FISH | Quant | 35 | 1
p16/CDKN2A/MTS1 | Melanoma, bladder cancer, pancreatic cancer | Diagnosis | FISH | Quant, Qual | 42, 79, 48, 15, 68 | 5
p16, 3cen, 7cen | Urothelial cancer | Diagnosis | FISH | Qual | 43 | 1
p53 | All tumor types | Diagnosis, Prognosis | Immunohistochemistry | Quant | 68 | 1
Phospho AKT | All tumor types | Diagnosis, Prognosis | Immunohistochemistry | Quant | 68 | 1
PR | Breast cancer | Diagnosis, Prognosis | Immunohistochemistry | Quant | 68 | 1
PSA | Prostate Cancer | Diagnosis | Immunohistochemistry | Qual | 4 | 1
RB1 | Retinoblastoma | Diagnosis | FISH | Qual | 79 | 1
RET proto-oncogene | MEN 2A, MEN 2B | Diagnosis | PCR sequencing, PCR-restriction digest | Qual | 35, 8, 23, 37 | 4
Thyroglobulin | Thyroid cancer | Diagnosis | Immunohistochemistry | Qual | 4 | 1
Topo II alpha | Breast cancer | Diagnosis, prognosis | FISH | Quant | 68 | 1
21 genes (unspecified) | Breast cancer | Monitoring, prognosis, treatment decisions | Real-time PCR | Quant | 36 | 1
Unknown | Oligodendroglioma, testicular germ cell tumors, seminomas & nonseminomas, glioblastoma, astrocytoma, neuroblastoma | Monitoring | FISH | Quant, Qual | 42, 43, 54, 79 | 4
UGT1A1 | Colorectal cancer | Treatment decisions | PCR | Quant | 55, 40, 65, 6, 47, 57 | 6
Various | All tumor types | Monitoring, diagnosis | PCR-allele specific | Qual | 42, 4, 44, 79 | 4
VHL | Various | Diagnosis | Southern blot, PCR sequencing | Qual | 8, 25 | 2

Note: The manufacturer of the commercial kits used in hematology tests were not listed in the AMP database.

* Refer to Table 12 for Identification Number of Laboratory.

Table 23 Tests Using Commercial Kits: Hematopathology

WHO Category | Gene | Gene Specifics | Test Use | Test Method | Assay Type | Laboratory^*^ | Number of Laboratories
Mastocytosis & Myelodysplastic | BCR-ABL | Unspecified, BCR-ABL major/M-bcr/P210, BCR-ABL minor/m-bcr/P190, BCR-ABL micro/mu-bcr/P230 | Diagnosis, prognosis | RT-PCR, FISH | Qual, Quant | 80, 30, 40, 55, 65, 15, 44, 46, 54, 72 | 10
Mastocytosis & Myelodysplastic | MLL(HRX) | Unspecified | Diagnosis, prognosis | RT-PCR, FISH | Qual, Quant | 80, 40, 55, 65, 15, 44, 46 | 7
Mastocytosis & Myelodysplastic | not specified | Unspecified | Diagnosis, prognosis | FISH | Quant | 29, 46 | 2
Mastocytosis & Myelodysplastic | PDGFRB-TEL(ETV6) | Unspecified | Diagnosis, prognosis | RT-PCR | Qual | 80 | 1
Acute Myeloid Leukemias | AF9-MLL(HRX) | Unspecified | Diagnosis, prognosis | RT-PCR, FISH | Qual, Quant | 80, 40, 55, 65, 15, 43 | 6
Acute Myeloid Leukemias | AML 1 (RUNX1)(CBFa)/ETO | Unspecified | Diagnosis, prognosis | FISH | Quant | 43, 42, 54 | 3
Acute Myeloid Leukemias | BCR-ABL | Unspecified, BCR-ABL breakpoint not specified, BCR-ABL micro/mu-bcr/P230, BCR-ABL minor/m-bcr/P190, BCR-ABL major/M-bcr/P210 | Diagnosis, prognosis, monitoring | FISH, real-time PCR, RT-PCR, antibody, Southern | Quant, Qual | 29, 30, 42, 80, 40, 55, 65, 15, 7, 43, 44, 54, 63, 72 | 14
Acute Myeloid Leukemias | CBFb/MYH11 | Unspecified | Diagnosis, prognosis, monitoring | FISH, RT-PCR, real-time PCR | Quant, Qual | 29, 42, 80, 55, 15, 43, 54, 18 | 8
Acute Myeloid Leukemias | DEK-CAN | Unspecified | Diagnosis, prognosis | RT-PCR | Qual | 80 | 1
Acute Myeloid Leukemias | ETO(CBFA2T1)-AML1(RUNX1orCBFA2) | Unspecified | Diagnosis, prognosis | FISH, real-time PCR, RT-PCR | Quant, Qual | 29, 42, 46, 80, 55, 65, 15, 43, 42, 54 | 10
Acute Myeloid Leukemias | Ig Heavy/Light | Ig heavy chain/IgH/14q32, unspecified, Ig light chain/IgK/2p12, Ig light chain/IgL/22q11.2 | Diagnosis, prognosis, monitoring | PCR, FISH | Qual, Quant | 9, 30, 42, 90, 40, 43, 44, 63, 72 | 9
Acute Myeloid Leukemias | MLL(HRX) | Unspecified | Diagnosis, Prognosis | FISH, RT-PCR | Quant, Qual | 9, 29, 80, 81, 40, 55, 65, 15, 42, 43, 54 | 11
Acute Myeloid Leukemias | MLL(HRX)-ELL | Unspecified | Diagnosis, prognosis | RT-PCR, FISH | Qual, Quant | 80, 40, 55, 65, 15, 43 | 6
Acute Myeloid Leukemias | MLL(HRX)-ENL | Unspecified | Diagnosis, prognosis | RT-PCR, FISH | Qual, Quant | 80, 40, 55, 65, 15, 43 | 6
Acute Myeloid Leukemias | Not specified | Unspecified | Prognosis | PCR, RT-PCR, antibody | Qual | 42, 80, 7 | 3
Acute Myeloid Leukemias | NPM-RARa | Unspecified | Diagnosis, prognosis | RT-PCR, FISH | Qual, Quant | 80, 43 | 2
Acute Myeloid Leukemias | NUMA-RARa | Unspecified | Diagnosis, prognosis | FISH | Quant | 43 | 1
Acute Myeloid Leukemias | PLZF-RARa | Unspecified | Diagnosis, prognosis | RT-PCR, FISH | Qual, Quant | 80, 43 | 2
Acute Myeloid Leukemias | PML-RARa | Unspecified | Diagnosis, prognosis | FISH, RT-PCR | Quant, Qual | 29, 80, 40, 55, 15, 42, 43, 54 | 8
Acute Myeloid Leukemias | STAT5B-RARa | Unspecified | Diagnosis, prognosis | FISH | Quant | 43 | 1
Acute Myeloid Leukemias | TCR genes | TCR gamma/7p15, unspecified | Diagnosis, prognosis, monitoring | PCR | Qual | 9, 30, 43, 90, 40, 55, 65, 42, 72 | 9
Acute Myeloid Leukemias | TEL(ETV6) | Unspecified | Diagnosis, prognosis | RT-PCR, FISH | Qual | 80, 65, 55, 42 | 4
B and T Cell Neoplasms | ATM, ?other genes | Unspecified | Diagnosis, prognosis | FISH | Quant | 29, 21, 42, 43 | 4
B and T Cell Neoplasms | BCL-1 | Unspecified | Diagnosis, prognosis | FISH | Quant | 43 | 1
B and T Cell Neoplasms | BCL-1 (PRAD1 or CCND1 or cyclin D1) | BCL-1 unspecified breakpoint, unspecified | Diagnosis, prognosis | FISH | Qual, Quant | 29, 40, 55, 65, 15, 43, 54 | 7
B and T Cell Neoplasms | BCL-1-IgH | Unspecified | Diagnosis, prognosis | FISH | Quant, Qual | 29, 40, 55, 65, 43, 54 | 6
B and T Cell Neoplasms | BCL-2 | BCL-2 unspecified breakpoint, BCL-2 mcr, BCL-2 MBR, unspecified | Diagnosis, prognosis, monitoring | FISH, PCR, real-time PCR | Qual, Quant | 29, 30, 42, 61, 40, 55, 65, 43, 54 | 9
B and T Cell Neoplasms | BCL-3 | BCL-2 MBR | Prognosis | PCR | Qual | 30 | 1
B and T Cell Neoplasms | BCL-6(LAZ3) | Unspecified | Diagnosis, prognosis | FISH | Qual, Quant | 29, 65, 42, 43, 54 | 5
B and T Cell Neoplasms | BCR-ABL | Unspecified, BCR-ABL breakpoint not specified, BCR-ABL micro/mu-bcr/P230, BCR-ABL minor/m-bcr/P190, BCR-ABL major/M-bcr/P210 | Diagnosis, prognosis, monitoring | Real-time PCR, FISH, RT-PCR | Quant | 30, 80, 40, 15, 43, 44, 72 | 7
B and T Cell Neoplasms | BIRC3(API2)-MALT1(MLT) | Unspecified | Diagnosis, prognosis | FISH | Quant, Qual | 54, 43 | 2
B and T Cell Neoplasms | EBV | Unspecified | Diagnosis, prognosis | Real-time PCR | Quant | 29, 40, 55, 65 | 4
B and T Cell Neoplasms | Ig Heavy/Light | Ig heavy chain/IgH/14q32, Ig (unspecified gene), Ig light chain/IgK/2p12, Ig light chain/IgL/22q11.2, unspecified | Diagnosis, prognosis, monitoring | PCR, PCR sequencing, FISH | Qual, Quant | 9, 29, 30, 42, 90, 40, 43, 44, 54, 72 | 10
B and T Cell Neoplasms | MLL(HRX) | Unspecified | Diagnosis, prognosis | RT-PCR, FISH | Qual, Quant | 80, 40, 55, 65, 15, 43 | 6
B and T Cell Neoplasms | MYC | Unspecified | Diagnosis, prognosis | FISH | Quant, Qual | 42, 43, 54 | 3
B and T Cell Neoplasms | MYC-IgH and variants | Unspecified | Diagnosis, prognosis | FISH | Qual, Quant | 29, 40, 55, 65, 15, 43, 54 | 7
B and T Cell Neoplasms | Not specified | Unspecified | Diagnosis, prognosis | FISH | Quant | 29, 42, 43 | 3
B and T Cell Neoplasms | NPM-ALK | Unspecified | Diagnosis, prognosis | PCR, FISH | Quant, Qual | 42, 5, 43 | 3
B and T Cell Neoplasms | NPM1-ALK or other ALK | Unspecified | Diagnosis, prognosis | FISH | Qual | 29, 40, 55, 65, 15, 43 | 6
B and T Cell Neoplasms | P53 | Unspecified | Diagnosis, prognosis | FISH | Quant | 29, 40, 55, 65, 56, 21, 15, 42, 43 | 9
B and T Cell Neoplasms | P53, other genes? | Unspecified | Diagnosis, prognosis | FISH | Quant | 43 | 1
B and T Cell Neoplasms | PBX-E2A | Unspecified | Diagnosis, prognosis | RT-PCR | Qual | 80 | 1
B and T Cell Neoplasms | TAL1 | Unspecified | Diagnosis, prognosis | RT-PCR | Qual | 80 | 1
B and T Cell Neoplasms | TCR genes | TCR gamma/7p15, unspecified | Diagnosis, prognosis, monitoring | PCR | Qual | 9, 29, 30, 42, 90, 40, 55, 65, 72 | 9
B and T Cell Neoplasms | TEL(ETV6)/AML1 | Unspecified | Diagnosis, prognosis | FISH, RT-PCR | Quant, Qual | 42, 43, 80 | 3
B and T Cell Neoplasms | Various | Unspecified | Diagnosis, prognosis | Antibody | Qual | 74 | 1
Chronic Myeloproliferative Diseases | BCR-ABL | BCR-ABL breakpoint not specified, unspecified, BCR-ABL micro/mu-bcr/P230, BCR-ABL minor/m-bcr/P190, BCR-ABL major/M-bcr/P210 | Diagnosis, prognosis, monitoring | FISH, real-time PCR, RT-PCR | Quant, Qual | 29, 30, 42, 46, 80, 40, 55, 65, 15, 54, 72 | 11
Chronic Myeloproliferative Diseases | PDGFRB-TEL(ETV6) | unspecified | Diagnosis, prognosis | RT-PCR | Qual | 80 | 1
Histiocytic and Dendritic-Cell Neoplasms | Ig Heavy/Light | Ig heavy chain/IgH/14q32, unspecified | Diagnosis, prognosis | PCR | Qual | 30, 90, 40 | 3
Histiocytic and Dendritic-Cell Neoplasms | TCR genes | Unspecified | Diagnosis, prognosis | PCR, PCR and mutation scanning | Qual | 30, 90, 40, 55, 65 | 5
Hodgkin Lymphoma | Ig Heavy/Light | Ig heavy chain/IgH/14q32, unspecified, Ig light chain/Igk/2p12 | Diagnosis, prognosis | PCR | Qual | 9, 30, 90, 40, 44 | 5

Note: The manufacturer of the commercial kits used in hematology tests were not listed in the AMP database.

* Refer to Table 12 for Identification Number of Laboratory.

## FDA-approved Molecular Test Tables

Table 24 through Table 28 presents a listing of the in vitro molecular diagnostic products that are approved or cleared for diagnostic use in the United States by the Food and Drug Administration (FDA). Molecular tests are classified as “Medical Devices.” The information presented in the tables is current through December 10, 2009. Further information about the products presented in each table is available at the Web site for FDA‘s Office of In Vitro Diagnostic (OIVD) Evaluation and Safety, http://www.fda.gov/cdrh/oivd/index.html.

Table 24 FDA-approved or cleared Molecular Diagnostic Tests: Bacterial and Fungal Infectious Diseases

Test Use | Test Name | Manufacturer | Test Method
Bacillus anthracis | Joint Biological Agent Identification and Diagnostic System (JBAIDS) Anthrax Detection kit | Idaho Technology, Inc. Salt Lake City, UT | Real-time PCR
Candida albicans and Candida spp. | C. albicans PNA FISH | AdvanDx Woburn, MA | PNA FISH
Candida albicans and Candida spp. | Yeast Traffic Light PNA FISH™^1^ | AdvanDx Woburn, MA | PNA FISH
Clostridium difficile | GeneOhm Cdiff Assay | BD Diagnostics—GeneOhm San Diego, CA | Real-time PCR
Clostridium difficile | Xpert™ C. difficile Test | Cepheid Sunnyvale, CA | Real-time PCR
Clostridium difficile | ProGastro™ Cd Assay | Prodesse Waukesha, WI | Multiplex Real-time PCR
Chlamydia trachomatis detection (single organism) | BD ProbeTec™ Chlamydia trachomatis (CT) Q^x^ Amplified DNA Assay | BD Diagnostic Systems Sparks, MD | SDA
Chlamydia trachomatis detection (single organism) | HC2^®^ CT ID | Qiagen Germantown, MD | Hybrid Capture
Chlamydia trachomatis detection (single organism) | APTIMA CT^®^ Assay | Gen-Probe, Inc. San Diego, CA | TC, TMA, DKA
Chlamydia trachomatis detection (single organism) | PACE^®^ 2 CT Probe Competition Assay (Ct-confirmation test) | Gen-Probe, Inc. San Diego, CA | HPA
Chlamydia trachomatis detection (single organism) | AMPLICOR^®^ CT/NG Test for Chlamydia trachomatis | Roche Molecular Diagnostics Pleasanton, CA | PCR
Chlamydia trachomatis detection (single organism) | COBAS AMPLICOR^®^ CT/NG Test for Chlamydia trachomatis^1^ | Roche Molecular Diagnostics Pleasanton, CA | PCR
Neisseria gonorrhoeae detection (single organism) | BD ProbeTec™ Neisseria gonorrhoeae (GC) Q^x^ Amplified DNA Assay | BD Diagnostic Systems Sparks, MD | SDA
Neisseria gonorrhoeae detection (single organism) | HC2^®^ GC ID | Qiagen Germantown, MD | Hybrid Capture
Neisseria gonorrhoeae detection (single organism) | APTIMA® GC Assay | Gen-Probe, Inc. San Diego, CA | TC, TMA, DKA
Neisseria gonorrhoeae detection (single organism) | PACE^®^ 2 GC Probe Competition Assay (GC-confirmation test) | Gen-Probe, Inc. San Diego, CA | HPA
Neisseria gonorrhoeae detection (single organism) | AMPLICOR^®^ CT/NG Test for Neisseria gonorrhoeae | Roche Molecular Diagnostics Pleasanton, CA | PCR
Neisseria gonorrhoeae detection (single organism) | COBAS AMPLICOR^®^ CT/NG Test for Neisseria gonorrhoeae^1^ | Roche Molecular Diagnostics Pleasanton, CA | PCR
Chlamydia trachomatis and Neisseria gonorrhoeae detection | Abbott Molecular, Inc. Des Plaines, IL | Abbott® Real Time CT/NG | Real-time PCR
Chlamydia trachomatis and Neisseria gonorrhoeae detection | BD ProbeTec™ ET C. trachomatis and N. gonorrhoeae amplified DNA Assay | BD Diagnostics—GeneOhm San Diego, CA | SDA
Chlamydia trachomatis and Neisseria gonorrhoeae detection | HC2^®^ CT/GC Combo Test | Qiagen Germantown, MD | Hybrid Capture
Chlamydia trachomatis and Neisseria gonorrhoeae detection | APTIMA Combo 2® Assay | Gen-Probe, Inc. San Diego, CA | TC, TMA, DKA
Chlamydia trachomatis and Neisseria gonorrhoeae detection | PACE^®^ 2C CT/GC | Gen-Probe, Inc. San Diego, CA | HPA
Chlamydia trachomatis and Neisseria gonorrhoeae detection | AMPLICOR^®^ CT/NG Test | Roche Molecular Diagnostics Pleasanton, CA | PCR
Chlamydia trachomatis and Neisseria gonorrhoeae detection | COBAS AMPLICOR™ CT/NG Test^1^ | Roche Molecular Diagnostics Pleasanton, CA | PCR
Enterococcus faecalis | Enterococcus faecalis PNA FISH | AdvanDx Woburn, MA | PNA FISH
Escherichia coli and Pseudomonas aeruginosa | E. coli/P. aeruginosa PNA FISH | AdvanDx Woburn, MA | PNA FISH
Escherichia coli, Klebsiella pneumonia and Pseudomonas aeruginosa | EK/P. aeruginosa PNA FISH | AdvanDx Woburn, MA | PNA FISH
Francisella tularensis | Joint Biological Agent Identification and Diagnostic System (JBAIDS) Tularemia Detection kit | Idaho Technology, Inc. Salt Lake City, UT | Real-time PCR
Gardnerella, Trichomonas vaginalis and Candida spp. detection | BD Affirm™ VPIII Microbial Identification Test | BD Diagnostics-GeneOhm San Diego, CA | Hybridization
Group A Streptococci detection | Group A Strep direct (GASD) | Gen-Probe, Inc. San Diego, CA | HPA
Group B Streptococci detection | GBS PNA FISH | AdvanDx Woburn, MA | PNA FISH
Group B Streptococci detection | IDI-Strep B™ Assay | BD Diagnostics—GeneOhm San Diego, CA | Real-time PCR
Group B Streptococci detection | Smart GBS | Cepheid Sunnyvale, CA | Real-time PCR
Group B Streptococci detection | Xpert™ GBS | Cepheid Sunnyvale, CA | Real-time PCR
Group B Streptococci detection | Group B AccuProbe^®^ | Gen-Probe, Inc. San Diego, CA | HPA
Group B Streptococci detection | IDI-Strep B™ Assay | Becton, Dickinson & Company Sparks, MD | Real-time PCR
MRSA for Staphylococcus aureus Screening assay | IDI-MRSA™ Assay | BD Diagnostics—GeneOhm San Diego, CA | Real-time PCR
MRSA for Staphylococcus aureus Screening assay | Xpert™ MRSA | Cepheid Sunnyvale, CA | Real-time PCR
MRSA for Staphylococcus aureus Diagnostic assay for positive blood cultures | GeneOhm StaphSR | BD Diagnostics—GeneOhm San Diego, CA | Real-time PCR
MRSA for Staphylococcus aureus Diagnostic assay for positive blood cultures | Xpert™ MRSA/SA Blood Culture Assay | Cepheid Sunnyvale, CA | Real-time PCR
MRSA for Staphylococcus aureus Diagnostic assay for Skin and Soft Tissue Infection | Xpert(TM) MRSA/SA Skin and Soft Tissue Infection (SSTI) test | Cepheid Sunnyvale, CA | Real-time PCR
Mycobacterium tuberculosis detection | AMPLIFIED™ Mycobacterium tuberculosis Direct Test (MTD) | Gen-Probe, Inc. San Diego, CA | TMA
Mycobacterium tuberculosis detection | AMPLICOR™ Mycobacterium tuberculosis Test | Roche Molecular Diagnostics Pleasanton, CA | PCR
Mycobacteria spp., different fungi and bacteria culture confirmation^2^ | AccuProbe^®^ Culture Identification Tests | Gen-Probe, Inc. San Diego, CA | HPA
Staphylococcus aureus | S. aureus PNA FISH | AdvanDx Woburn, MA | PNA FISH

1 Five Candida species directly from positive blood cultures including: C. albicans and/or C. parapsilosis, C. tropicalis, and C. glabrata and/or C. krusei

2 C. trachomatis and N. gonorrhoeae detection may now be done using the Roche COBAS Amplicor system directly from Cytyc Corporation’s ThinPrep Pap test collection kit; this use is FDA Approved.

3 Campylobacter spp., Enterococcus spp., Group B Streptococcus, Haemophilus influenzae, Neisseria gonorrhoeae, Streptococcus pneumoniae, Staphylococcus aureus, Listeria monocytogenes, Group A Streptococcus, Mycobacterium avium, Mycobacterium intracellulare, Mycobacterium avium complex, Mycobacterium gordonae, Mycobacterium tuberculosis complex, Mycobacterium kansasii, Blastomyces dermatitidis, Coccidioides immitis, Crytococcus neoformans, Histoplasma capsulatum.

Table 25 FDA-approved or cleared Molecular Diagnostic Tests: Viral Infectious Disease

Test Use | Test Name | Manufacturer | Test Method
Avian Flu diagnosis | Influenza A/H5 | Centers for Disease Control and Prevention | Real-time RT-PCR
Cytomegalovirus detection | HC1^®^ CMV DNA Test | Qiagen Germantown, MD | Hybrid Capture
Cytomegalovirus detection | Hybrid Capture® CMV DNA Test | Gentech Diagnostics Pvt. Ltd. New Delhi, India | Hybrid Capture with Chemi-luminescent
Cytomegalovirus detection | CMV pp67 mRNA | bioMerieux, Inc. Durham, NC | NASBA
Enterovirus detection | NucliSENS EasyQ^®^ Enterovirus (also see under Systems below: NucliSENS EasyQ® System) | bioMérieux, Inc. Durham, NC | Real-time NASBA
Enterovirus detection | Xpert™ EV | Cepheid Sunnyvale, CA | Real-time PCR
HBV quantitation | COBAS^®^ TaqMan^®^ HBV Test, for use with the HighPure System | Roche Molecular Diagnostics Pleasanton, CA | PCR
HCV qualitative detection | VERSANT^®^ HCV RNA | Gen-Probe, Inc. San Diego, CA (distributed by Bayer HealthCare, Berkeley, CA) | TMA
HCV qualitative detection | AMPLICOR™ HCV Test, v2.0 | Roche Molecular Diagnostics Pleasanton, CA | PCR
HCV qualitative detection | COBAS AMPLICOR™ HCV Test, v2.0 | Roche Molecular Diagnostics Pleasanton, CA | PCR
HCV quantitation | VERSANT^®^ HCV RNA 3.0 Assay (bDNA) | Siemens Healthcare Diagnostics Deerfield, IL | bDNA
HCV quantitation | COBAS® AmpliPrep/COBAS® TaqMan HCV Test | Roche Molecular Diagnostics Pleasanton, CA | Real-time RT-PCR
HIV drug resistance testing | ViroSeq™ HIV-1 Genotyping System | Celera Diagnostics Alameda, CA (distributed by Abbott Laboratories, Abbott Park, Il) | Sequencing
HIV drug resistance testing | TruGene™ HIV-1 Genotyping and Open Gene DNA Sequencing System | Siemens Healthcare Diagnostics Deerfield, IL | Sequencing
HIV quantitation | Abbott Real-time HIV-1 | Abbott Molecular, Inc. Des Plaines, IL | Real-time RT-PCR
HIV quantitation | VERSANT^®^ HIV-1 RNA 3.0 Assay (bDNA) | Siemens Healthcare Diagnostics Deerfield, IL | bDNA
HIV quantitation | NucliSens^®^HIV-1 QT | bioMerieux, Inc. Durham, NC | NASBA
HIV quantitation | AMPLICOR HIV-1 MONITOR™ Test, v1.5 | Roche Molecular Diagnostics Pleasanton, CA | RT-PCR
HIV quantitation | COBAS AMPLICOR HIV-1 MONITOR™ Test, v1.5 | Roche Molecular Diagnostics Pleasanton, CA | RT-PCR
HIV quantitation | COBAS® AmpliPrep/COBAS® TaqMan HIV-1 Test | Roche Molecular Diagnostics Pleasanton, CA | RT-PCR
HBV/HCV/HIV for blood donations | Hepatitis C Virus (HCV) Reverse Transcription (RT) Polymerase Chain Reaction (PCR) assay | BioLife Plasma Services, L.P. Deerfield, IL 60015 | RT-PCR
HBV/HCV/HIV for blood donations | Human Immunodeficiency Virus, Type 1 (HIV-1) Reverse Transcription (RT) Polymerase Chain Reaction (PCR) assay | BioLife Plasma Services, L.P. Deerfield, IL 60015 | RT-PCR
HBV/HCV/HIV for blood donations | Procleix™ HIV-1/HCV Assay | Gen-Probe, Inc. San Diego, CA (distributed by Chiron) | TC, TMA, HPA
HBV/HCV/HIV for blood donations | PROCLEIX ULTRIO^®^ Assay (HIV-1, HCV and HBV) | Gen-Probe, Inc. San Diego, CA (distributed by Chiron) | TC, TMA, HPA
HBV/HCV/HIV for blood donations | UltraQual™ HCV RT-PCR Assay | National Genetics Institute Los Angeles, CA | RT-PCR
HBV/HCV/HIV for blood donations | UltraQual™ HIV-1 RT-PCR Assay | National Genetics Institute Los Angeles, CA | RT-PCR
HBV/HCV/HIV for blood donations | COBAS AmpliScreen™ HBV Test | Roche Molecular Diagnostics Pleasanton, CA | PCR
HBV/HCV/HIV for blood donations | COBAS AmpliScreen™ HCV Test, v2.0 | Roche Molecular Diagnostics Pleasanton, CA | RT-PCR
HBV/HCV/HIV for blood donations | COBAS AmpliScreen™ HIV-1 Test, v1.5 | Roche Molecular Diagnostics Pleasanton, CA | RT-PCR
HBV/HCV/HIV for blood donations | COBAS® TaqScreen MPX® | Roche Molecular Diagnostics Pleasanton, CA | Multiplex Real-time PCR and RT-PCR
Human Metapneumovirus | Pro hMPV+™ Assay | Prodesse Waukesha, WI | Multiplex Real-time PCR
Human Papillomavirus testing | Cervista™ HPV HR (high risk) | Hologic, Inc. (Third Wave Technologies) Bedford, MA | Invader® Chemistry
Human Papillomavirus testing | Cervista™ HPV 16/18 | Hologic, Inc. (Third Wave Technologies) Bedford, MA | Invader® Chemistry
Human Papillomavirus testing | HC2^®^ HR and LR | Qiagen Germantown, MD | Hybrid Capture
Human Papillomavirus testing | HC2^®^HPV HR | Qiagen Germantown, MD | Hybrid Capture
Human Papillomavirus testing | HC2^®^ DNA with Pap | Qiagen Germantown, MD | Hybrid Capture
Influenza Virus Panel | Human Influenza Virus Real-time RT-PCR Detection and Characterization Panel (also see under Systems below: ABI 7500 Fast Dx Real-Time PCR Instrument) | Centers for Disease Control Atlanta, GA | Real-time RT-PCR
Respiratory virus panel | xTAG Respiratory Viral Panel^1^ (also see under Systems below: Luminex LX 100/200) | Luminex Molecular Diagnostics Toronto, Canada | PCR, ASPE, Tag sorting
Respiratory virus panel | Verigene® Respiratory Virus Nucleic Acid Test and Verigene® Respiratory Virus Test-SP | Nanosphere, Inc. Northbrook, IL | Multiplex Gold Nanoparticle Probes
Respiratory virus panel | ProFlu+™ Assay^2^ | Prodesse Waukesha, WI | Multiplex Real-time PCR
West Nile for blood donations | Procleix WNV | Gen-Probe, Inc. San Diego, CA (distributed by Chiron) | Real-time PCR
West Nile for blood donations | Cobas TaqScreen WNV | Roche Molecular Diagnostics Pleasanton, CA | PCR

Table 26 FDA-approved or cleared Non-Infectious-Disease-Related Molecular Diagnostic Test

Test Use | Test Name | Manufacturer | Test Method
B-Cell chronic lymphocytic leukemia (B-CLL) | CEP^®^12 DNA Probe Kit | Abbott Molecular, Inc. Des Plaines, IL | FISH
Breast cancer - determination of the likelihood of metastasis | MammaPrint | Agendia, Amsterdam, The Netherlands | Microarray analysis
Breast cancer - determination of the likelihood of metastasis | GeneSearch™ BLN Test | Veridex, LLC Warren, NJ | Real-time RT-PCR
Breast Cancer - detection of amplifications and deletions of the TOP2A gene | TOP2A FISH pharmDx™ Kit | Dako Denmark A/S Glostrup, Denmark DK-2600 | FISH on FFPE breast tissue
Chromosome 8 enumeration (CML, AML, MPD, MDS) | CEP^®^8 DNA Probe Kit | Abbott Molecular, Inc. Des Plaines, IL | FISH
Drug-metabolizing enzymes | AmpliChip™ Cytochrome P450 Genotyping Test | Roche Diagnostics Pleasanton, CA | Microarray
Drug-metabolizing enzymes | Verigene® Warfarin Metabolism Nucleic Acid Test | Nanosphere, Inc. Northbrook, IL | Multiplex gold nanoparticle probes
Drug-metabolizing enzymes | INFINITI™ 2C9 & VKORC1 Multiplex Assay for Warfarin | AutoGenomics, Inc. Carlsbad, CA | PCR and Detection Primer Extension
Drug-metabolizing enzymes | eSensor Warfarin Sensitivity Test | Osmetech Molecular Diagnostics Pasadena, CA | PCR, Probe Hybridization
Drug-metabolizing enzymes | Gentris Rapid Genotyping Assay -CYP2C9 & VKORC1 | ParagonDx, LLC Morrisville, NC | Real-time PCR
Drug-metabolizing enzymes | Invader^®^ UGT1A1 Molecular Assay | Hologic, Inc. (Third Wave Technologies) Bedford, MA | Invader® Chemistry
Drug-metabolizing enzymes | eQ-PCR™ LC Warfari Genotyping Kit | TrimGen Corp Sparks, MD | Real-time PCR
Factor II (prothrombin) | INFINITI™ System Assay for Factor II | AutoGenomics, Inc. Carlsbad, CA | PCR and detection primer extension
Factor II (prothrombin) | Factor II (prothrombin) G20210A kit | Roche Diagnostics Pleasanton, CA | Real-time PCR
Factor II (prothrombin) | Verigene^®^ F2 Nucleic Acid Test | Nanosphere, Inc. Northbrook, IL | Multiplex Gold Nanoparticle Probes
Factor V Leiden | INFINITI™ System Assay for Factor V | AutoGenomics, Inc. Carlsbad, CA | PCR and detection primer extension
Factor V Leiden | Factor V Leiden kit | Roche Diagnostics Pleasanton, CA | Real-time PCR
Factor V Leiden | Verigene® F5 Nucleic Acid Test | Nanosphere, Inc. Northbrook, IL | Multiplex gold nanoparticle probes
Factor II (Prothrombin) and Factor V Leiden G | INFINITI™ System Assay for Factor II & Factor V | AutoGenomics, Inc. Carlsbad, CA | PCR and detection primer extension
Factor II (Prothrombin) and Factor V Leiden G | Verigene® F5/F2 Nucleic Acid Test | Nanosphere, Inc. Northbrook, IL | Multiplex gold nanoparticle probes
Factor II (Prothrombin), Factor V Leiden and MTHFR | Verigene® F5/F2/MTHFR Nucleic Acid Test | Nanosphere, Inc. Northbrook, IL | Multiplex gold nanoparticle probes
Factor II (Prothrombin), Factor V Leiden and MTHFR | INFINITI™ System Assay for Factor II & Factor V | AutoGenomics, Inc. Carlsbad, CA | PCR and detection primer extension
Heart Transplant Recipients - Identification of the potential risk for transplant rejection | AlloMap^®^ Molecular Expression Testing | XDx, Inc. Brisbane, CA | Quantitative Real-time PCR
HER-2 (ERBB2) Status | PathVysion^®^ HER-2 DNA Probe kit (also see under Systems below: Vysis AutoVysion™ System) | Abbott Molecular, Inc. Des Plaines, IL | FISH
HER-2 (ERBB2) Status | Her2 FISH pharmDx™ Kit | Dako Denmark A/S Glostrup, Denmark DK-2600 | FISH on FFPE breast tissue
HER-2 (ERBB2) Status | SPOT-Light HER2 CISH kit | Invitrogen Carlsbad, CA | Chromogenic in situ hybridization
Initial diagnosis of bladder cancer in patients with hematuria and monitoring for recurrence of bladder cancer | UroVysion^®^ | Abbott Molecular, Inc. Des Plaines, IL | FISH
5,10-methylenetetra hydrofolate reductase (MTHFR) | Verigene^®^ MTHFR Nucleic Acid Test | Nanosphere, Inc. Northbrook, IL | Multiplex gold nanoparticle probes

Table 27 FDA-approved Molecular Diagnostic Control Material

Type of Control | Control Name | Manufacturer | Approved Use
C. trachomatis and N. gonorrhoeae controls (positive and negative controls) | Amplichek CT/GC Controls | Bio-Rad Laboratories Irvine, CA | For diagnostic test kits that detect C trachomatis and N. gonorrhoeae from swabs or urine
C. trachomatis and N. gonorrhoeae Positive Quality controls | ACCURUN 341 Chlamydia trachomatis Neisseria gonnorrhoeae DNA Positive Control | SeraCare Life Sciences West Bridgewater, MA | For diagnostic test kits that detect C. trachomatis and N. gonorrhoeae from swabs or urine
CMV DNA controls | ACCURUN 350 CMV DNA Positive Quality Control | SeraCare Life Sciences West Bridgewater, MA | For in vitro tests that detect CMV DNA
Cytochrome P450 2D6 gene (CYP2D6) | CYP2D6 *4A/*2AxN | ParagonDx, LLC Morrisville, NC | For diagnostic testing for the Cytochrome P450 2D6 gene variant
Cytochrome P450 2D6 gene (CYP2D6) | CYP2D6 *2M/*17 | ParagonDx, LLC Morrisville, NC | For diagnostic testing for the Cytochrome P450 2D6 gene variant
Cytochrome P450 2D6 gene (CYP2D6) | CYP2D6 *29/*2AxN | ParagonDx, LLC Morrisville, NC | For diagnostic testing for the Cytochrome P450 2D6 gene variant
Cytochrome P450 2D6 gene (CYP2D6) | CYP2D6 *6B/*41 | ParagonDx, LLC Morrisville, NC | For diagnostic testing for the Cytochrome P450 2D6 gene variant
Cytochrome P450 2D6 gene (CYP2D6) | CYP2D6 *1/*5 | ParagonDx, LLC Morrisville, NC | For diagnostic testing for the Cytochrome P450 2D6 gene variant
Cytochrome P450 2D6 gene (CYP2D6) | CYP2D6 *3A/*4A | ParagonDx, LLC Morrisville, NC | For diagnostic testing for the Cytochrome P450 2D6 gene variant
HBV controls | OptiQual™ HBV DNA Positive Control | AcroMetrix Benicia, CA | For diagnostic test kits that detect HBV DNA
HBV controls | VeriSure Pro HBV | AcroMetrix Benicia, CA | Testing in donors
HCV control | OptiQual™ HCV RNA Positive Control | AcroMetrix Benicia, CA | For diagnostic test kits that detect HCV RNA
HCV control | VeriSure Pro HCV | AcroMetrix Benicia, CA | Testing in donors
HCV control | ACCURUN 305 HCV RNA Positive Control | SeraCare Life Sciences West Bridgewater, MA | For diagnostic test kits that detect HCV RNA
HIV-1 control | OptiQual™ HIV-1 RNA Positive Control | AcroMetrix Benicia, CA | Control ranges to quantitate HIV-1 RNA
HIV-1 control | ACCURUN 315 HIV-1 RNA Positive Control | SeraCare Life Science West Bridgewater, MA | Control ranges to quantitate HIV-1 RNA
HIV-1/HCV controls | VeriSure Pro HIV-1 | AcroMetrix Benicia, CA | Testing in donors
HIV-1/HCV controls | Chiron Procleix HIV-1/HCV Controls | Gen-Probe, Inc. San Diego, CA | Testing in donors
HIV-1/HCV Proficiency Panel | Chiron Procleix HIV-1/HCV Proficiency Panel | Gen-Probe, Inc. San Diego, CA | HIV-1/HCV proficiency panel
HIV-1/HCV/HBV controls | VeriSure Pro Negative | AcroMetrix Benicia, CA | Testing in donors
HIV-1/HCV/HBV controls | VeriSure Triplex HIV-1 RNA, HCV RNA, HBV DNA | AcroMetrix Benicia, CA | For diagnostic test kits that detect HIV-1 RNA, HCV RNA and HBV DNA
HIV-1/HCV/HBV controls | ACCURUN 345 HIV-1 RNA, HCV RNA, HBV DNA Positive Quality Control Series 150 | SeraCare Life Sciences West Bridgewater, MA | For diagnostic test kits that detect HIV-1 RNA, HCV RNA, and HBV DNA
HIV-1/HCV/HBV controls | ACCURUN 803 Nucleic Acid Negative Quality Control (HIV-1, HCV, HBV) | SeraCare Life Sciences West Bridgewater, MA | For diagnostic test kits that detect HIV-1 RNA, HCV RNA, and HBV DNA
HPV DNA controls | ACCURUN 370 HPV DNA Positive Quality Control | SeraCare Life Sciences West Bridgewater, MA | For in vitro tests that detect HPV DNA in human cervical samples
HPV DNA controls | ACCURUN 870 HPV DNA Negative Quality Control | SeraCare Life Sciences West Bridgewater, MA | For in vitro tests that detect HPV DNA in human cervical samples
Human genomic DNA control | Gentrisure™ Human Genomic DNA Reference Control | ParagonDx, LLC Morrisville, NC | For quality control of human DNA tests
West Nile virus RNA controls | ACCURUN 365 West Nile Virus Positive quality Control | SeraCare Life Sciences West Bridgewater, MA | For in vitro tests that detect West Nile RNA in human plasma from blood donors
West Nile virus RNA controls | ACCURUN 865 West Nile Virus Negative quality Control | SeraCare Life Sciences West Bridgewater, MA | For in vitro tests that detect West Nile RNA in human plasma from blood donors
West Nile virus RNA controls | VeriSure Pro WNV External Controls | AcroMetrix Benicia, CA | For use with the Procleix WNV Assay to detect WNV RNA in human plasma from blood donors

Table 28 FDA-approved Molecular Diagnostic Systems

Type of System | System Name | Manufacturer | Approved Use
Amplified molecular diagnostic testing instruments | NucliSENS EasyQ® System | bioMérieux, Inc. Durham, NC | NucliSENS EasyQ^®^ Enterovirus
Amplified molecular diagnostic testing instruments | BD Viper™System | Becton, Dickinson & Company Sparks, MD | Chlamydia trachomatis and Neisseria gonorrhoeae
Amplified molecular diagnostic testing instruments | TIGRIS® DTS™ System | Gen-Probe, Inc. San Diego, CA | Gen-Probe’s Combo 2® Ct/Ng Assay
Amplified molecular diagnostic testing instruments | Procleix® Semi-Automated Instrument System | Gen-Probe, Inc. San Diego, CA | For Donated Blood with the PROCLEX^®^ HIV-1/HCV Assay, the PROCLEIX ULTRIO^®^ Assay (HIV-1, HCV and HBV)
Amplified molecular diagnostic testing instruments | Procleix^®^ TIGRIS Instrument System | Gen-Probe, Inc. San Diego, CA | For Donated Blood with the PROCLEX^®^ HIV-1/HCV Assay, the PROCLEIX ULTRIO^®^ Assay (HIV-1, HCV and HBV) and Procleix^®^ WNV Assay
Amplified molecular diagnostic testing instruments | VERSANT™ 440 Molecular System | Siemens Healthcare Diagnostic Deerfield, IL | VERSANT HCV RNA 3.0 assay
Extraction Systems | QIAcube | Qiagen, Inc. Germantown, MD | PAXgene Blood RNA System
Microarray systems and high multiplex systems | Affymetrix GCS 3000Dx Instrumentation System | Affymetrix, Inc. Santa Clara, CA and Roche Diagnostics Pleasanton, CA | AmpliChip Cytochrome P450 Genotyping Test
Microarray systems and high multiplex systems | INFINITI™ Analyzer | AutoGenomics, Inc. Carlsbad, CA | Factor II (Prothrombin) G20210G and Factor V Leiden, and Warfarin G1691A
Microarray systems and high multiplex systems | Luminex LX 100/200 | Luminex Corp. Toronto, Canada | ID-Tag™ respiratory virus panel
Microarray systems and high multiplex systems | Verigene^®^ System | Nanosphere, Inc. Northbrook, IL | Verigene^®^ Factor V, Factor II, MTHFR and Warfarin
Microarray systems and high multiplex systems | eSensor^®^ XT-8 System | Osmetech Molecular Diagnostics Pasadena, CA | CFTR and Warfarin
Real-time PCR amplification systems | Abbott m2000™ (m2000sp + m2000rt) | Abbott Molecular, Inc. Des Plaines, IL | Abbott Real-time HIV-1
Real-time PCR amplification systems | 7500 Fast Dx Real-Time PCR Instrument | Applied Biosystems, Inc Foster City, CA | Human Influenza Virus Real-Time RT-PCR Detection and Characterization Panel
Real-time PCR amplification systems | LightCycler Instrument v. 1.2 | Roche Diagnostics Pleasanton, CA | Factor II (prothrombin) G20210A kit and Factor V Leiden kit
Real-time PCR amplification systems | COBAS Taqman™ Analyzer | Roche Diagnostics Pleasanton, CA | COBAS AmpliPrep™ System, HIV, HCV and HBV
Real-time PCR amplification systems | Vysis AutoVysion™ System | Abbott Molecular, Inc. Des Plaines, IL | Vysis PathVysion^®^ HER-2 DNA Probe Kit
FISH scanning platform | BioView Duet Scanning System | BioView, Ltd. Nes Ziona, Israel | Peripheral blood and bone marrow (hematological probes), amniotic fluids (x,y,18, 13, and 21 probes), urine (Vysis UroVysion probe)