# Literature Search Strategies

A variety of approaches were used to identify relevant information for this report, including searches of peer-reviewed literature, gray literature, and Federal regulations.

## Part I

This portion of the search report includes searches of bibliographic resources for key questions 2, 3, and 7. ECRI Institute‘s search strategies employ combinations of freetext keywords as well as controlled vocabulary terms including (but not limited to) the following concepts. The strategies presented below are in OVID syntax; the searches were simultaneously conducted across EMBASE, MEDLINE, and CINAHL. Parallel strategies based on MeSH headings and keywords were used to search the databases comprising the Cochrane Library.

### Medical Subject Headings (MeSH), EMTREE, CINAHL and Keywords

[underlined: Conventions]:

OVID

$ = truncation character (wildcard)

exp = “explodes” controlled vocabulary term (e.g., expands search to all more specific related terms in the vocabulary‘s hierarchy)

.de. = limit to controlled vocabulary heading

.fs. = floating subheading

.hw. = limit to heading word

.md. = type of methodology (PsycINFO)

.mp. = combined search fields (default if no fields are specified)

.pt. = publication type

.ti. = limit to title

.tw. = limit to title and abstract fields

PubMed

[mh] = MeSH heading

[majr] = MeSH heading designated as major topic

[pt] = publication type

[sb] = Subset of PubMed database (PreMEDLINE, Systematic, OldMEDLINE)

[sh] = MeSH subheading (qualifiers used in conjunction with MeSH headings)

[tiab] = keyword in title or abstract

[tw] = text word

### Topic-specific Search Terms

Many controlled vocabulary terms and keywords were considered for inclusion in the search strategies. The following table contains an alphabetical listing of terms and keywords grouped by broad concepts. These are the terms and keywords that were actually included in the final search strategies.

Concept | Controlled Vocabulary | Keywords
Accuracy | accuracy diagnostic accuracy likelihood exp prediction and forecasting/ predictive value of tests receiver operating characteristic ROC curve sensitivity and specificity | Assay linearity False negative False positive Gold standard Hook effect Sensitivity Specificity True negative True positive
Clinical validity | follow-up/ incidence/ mortality/ | Clinical relevan$ Clinical util$ Clinical valid$ Course$ Predict$ Prognos$
Diseases/targets searched for Key Question 3 | acute lymphocytic leukemia/ Acute myelomonocytic leukemia/ Acute promyelocytic leukemia B cell lymphoma/ Exp boradatella pertussis/ Chronic myeloid leukemia Cytochrome P450/ cytomegalovirus/ epidermal growth factor receptor 2 Epstein Barr virus/ hepatitis b/ and viral load hepatitis c/ and genotyp$ herpes simplex virus/ exp HIV/ exp human immunodeficiency virus/ leukemia, lymphocytic, acute/ leukemia, myeloid/ leukemia, myelomonocytic, acute/ Mantle cell lymphoma methicillin resistant staphylococcus aureus/ methicillin resistance/ mycobacterium tuberculosis/ mycoplasma infections/ mycoplasma pneumonia/ Oncogene Neu parvovirus/ parvovirus infections/ promyelocytic leukemia/ receptor, erbb-2 exp simplexvirus/ staphylococcus aureus/ T cell lymphoma/ Warfarin and genotyp$ | Acute lymphocytic leukemia Acute myelomonocytic leukemia B cell lymphoma bcl-2 translocation Bordatella pertussis Cytochrome P450 Cytomegalovirus Epstein Barr virus Hepatitis b Hepatitis c HER 2 oncogene Herpes simplex virus Human immunodeficiency virus Human parvovirus B19 Human parvo virus B19 Mantle cell lymphoma Methicillin resistant staphylococcus aureus Mycobacterium tuberculosis Mycoplasma pneumonia Myeloid leukemia Neu Oncogene Oncogene C Neu Oncogene Erb B2 Oncogene Her 2 T cell lymphoma Warfarin BCR-ABL BCRABL CBFB-MYH11 CCFBMYH11 CYP450 EBV Erbb2 Erbb 2 Erbb-2 ErbB-2 Her2 Neu Her 2 Neu HER2/neu Her-2 Neu HIV HTLV-I HTLV-II MRSA PML-RARA PMLRARA
Laboratory-developed tests | | Assembled Home brew Home-brew In house In-house Laboratory developed Laboratory-developed LDT LDTs
Molecular techniques | DNA microarray exp gene amplification/ exp genetic techniques/ exp hybridization/ exp in situ hybridization/ microarray analysis exp microarray analysis/ molecular diagnostic techniques exp molecular probe/ exp molecular probe techniques/ exp nucleic acid amplification techniques/ exp nucleic acid hybridization/
Proficiency testing | Laboratories/standards Proficiency testing laboratory | external quality assessment EQA proficiency
Repeatability | Observer variation | Interpret$ Interobserver Inter-observer Intraobserver Intra-observer Kappa Observer bias Observer variability Reader$ Reliab$ Repeatab$ Replicat$
Validity | | validity

### Electronic Database Searches

The following databases have been searched for relevant information for Key Questions 1, 2, 3, and 7.

Name | Date Limits | Platform/Provider
CINAHL | 1982 through October 31, 2008 | OVID
The Cochrane Central Register of Controlled Trials (CENTRAL) | Through 2008, Issue 4 | www.thecochranelibrary.com
The Cochrane Database of Methodology Reviews (Methodology Reviews) | Through 2008, Issue 4 | www.thecochranelibrary.com
The Cochrane Database of Systematic Reviews (Cochrane Reviews) | Through 2008, Issue 4 | www.thecochranelibrary.com
Database of Abstracts of Reviews of Effects (DARE) | Through 2008, Issue 4 | www.thecochranelibrary.com
EMBASE (Excerpta Medica) | 1980 through October 31, 2008 | OVID
MEDLINE | 1960 through October 31, 2008 | OVID

### Key Question 2 Analytic Validity

CINAHL/EMBASE/MEDLINE/PreMEDLINE

Human/English language

Set Number | Concept | Search Statement
1 | Molecular testing - EMTREE | exp molecular probe/ or exp hybridization/ or exp molecular probe/ or exp gene amplification/ or (Microarray analysis or DNA microarray).de.
2 | Molecular testing - MeSH | molecular diagnostic techniques.de. or exp molecular probe techniques/ or exp nucleic acid amplification techniques/ or exp nucleic acid hybridization/ or exp in situ hybridization/ or exp microarray analysis/
3 | Combine sets | 1 or 2
4 | Limit by publication type | 3 not ((letter or editorial or news or comment or case reports or note or conference paper or review).de. or (letter or editorial or news or comment or case reports or review).pt.)
5 | Accuracy | 4 and (exp prediction and forecasting/ or (predictive value of tests or receiver operating characteristic or ROC curve or sensitivity and specificity or accuracy or diagnostic accuracy or precision or likelihood).de. or ((false or true) adj (positive or negative)))
6 | Validity | 4 and validity.ti,ab.
7 | Repeatability | 4 and ((intraobserver or intra-observer or interobserver or inter-observer or interpret$ or kappa or observer bias or observer variability or reader$ or reader concordance or reliab$ or repeatab$ or replicat$).tw. or observer variation.de.)
8 | Combine sets | or/5–7
9 | Limit by study type | 7 and (research synthesis or (systematic review or meta analysis or meta-analysis).de. or ((evidence base$ or methodol$ or systematic or quantitative$ or studies).mp. and (review.de. or review.pt.)))
10 | Eliminate overlap | Remove duplicates from 8
11 | Assay linearity | 4 and (assay linearity or hook effect)
12 | Combine sets | 11 not 12

### Key Question 3 Clinical Validity

[underlined: Note]: In addition to terms related to clinical validity/utility, these search strategies include search statements geared to retrieve citations relevant to specific conditions and targets.

CINAHL/EMBASE/MEDLINE/PreMEDLINE

Human/English language

Set Number | Concept | Search Statement
1 | Laboratory developed tests | (((home brew or home-brew or homebrew or in-house or inhouse or assembled) and laborator$) or (laborator$ adj developed))
2 | Laboratory diagnosis | Exp laboratory diagnosis/ or (laborator$ and (diagnos$ or technique$ or procedure$))
3 | Genetics | Exp nucleotide sequence/ or nucleotide sequence or DNA or RNA
4 | | Exp genetic marker/ or exp genetic markers/ or exp biological markers/ or ((genetic or biologic$) adj marker$)
5 | Clinical validity | Clinical adj (relevan$ or util$ or valid$)
6 | Combine sets | or/1–6
7 | Diagnosis | 6 and (exp diagnostic procedure/ or exp diagnosis)
8 | Prognosis | 6 and (exp incidence/ or exp mortality/ or exp follow up/ or prognos$ or predict$ or course$)
9 | Therapy | 6 and (exp therapy/ or therap$ or treatment$)
10 | Combine sets | or/7–9
11 | Limit by publication type | 10 not ((letter or editorial or news or comment or case reports or note or conference paper or review).de. or (letter or editorial or news or comment or case reports or review).pt.)
12 | Limit by study type | 11 and (research synthesis or (systematic review or meta analysis or meta-analysis).de. or ((evidence base$ or methodol$ or systematic or quantitative$ or studies).mp. and (review.de. or review.pt.)))
13 | Her2/Neu | 12 and ((oncogene neu or epidermal growth factor receptor 2 or receptor, erbb-2).de. or (her$ adj2 neu) or erbb2 or erbb 2 or erbb-2 or (oncogene adj3 (her$ or neu$ or erb$))
14 | Leukemia & lymphoma | 12 and (exp leukemia/ or exp lymphoma/ or ((myelomonocytic or promyelocytic or myeloid or lymphocytic) adj2 (leukemia$) or ((b cell or t cell or mantle cell) adj2 lymphoma) or CBFBMYH11 or CBFB-MYH11 or PML-RARA or PMLRARA or bcl-2 translocation or HTLV-I or HTLV-II)
15 | Bordatella pertussis | 12 and (bordatella pertussis.de. or bordatella pertussis)
16 | Cytochrome p450 | 12 and (Cytochrome p450.de. or Cytochrome p450 or cyp450)
17 | Cytomegalovirus | 12 and (exp cytomegalovirus/ or cytomegalovirus or CMV)
18 | Epstein Barr virus | 12 and ((Epstein barr virus or Epstein barr virus infections).de. or EBV)
19 | Hepatitis B | 12 and (hepatitis b.de. and viral load)
20 | Hepatitis C | 12 and (hepatitis c.de. and geneotyp$)
21 | Herpes Simplex virus | 12 and (exp herpes simplex virus/ or exp simplexvirus/)
22 | Human immunodeficiency virus | 12 and (exp human immunodeficiency virus/ or exp HIV/ or HIV$ or human immunodeficiency virus)
23 | Mycobacterium tuberculosis | 12 and (mycobacterium tuberculosis).mp.
24 | Mycoplasma pneumonia | 12 and (exp mycoplasma infections/ or mycoplasma pneumonia.mp.)
25 | Methicillin-resistant staph aureus | 12 and (methicillin resistant staphylococcus aureus.de. or (exp staphylococcus aureus/ and methicillin resistance.de.) or methicillin resistant staphylococcus aureus or MRSA)
26 | Parvovirus | 12 and (parvovirus or exp parvovirus infections/ or human parvovirus B19 or human parvo virus b19)
27 | Warfarin monitoring | 12 and (warfarin.mp. and genotyp$)
28 | Combine sets | or/13–27

### Key Question 7 Proficiency Testing

CINAHL/EMBASE/MEDLINE/PreMEDLINE

Human/English language

Set Number | Concept | Search Statement
1 | Molecular testing - EMTREE | exp molecular probe/ or exp hybridization/ or exp molecular probe/ or exp gene amplification/ or (Microarray analysis or DNA microarray).de.
2 | Molecular testing - MeSH | molecular diagnostic techniques.de. or exp molecular probe techniques/ or exp nucleic acid amplification techniques/ or exp nucleic acid hybridization/ or exp in situ hybridization/ or exp microarray analysis/
3 | Combine sets | 1 or 2
4 | Limit by publication type | 3 not ((letter or editorial or news or comment or case reports or note or conference paper or review).de. or (letter or editorial or news or comment or case reports or review).pt.)
5 | Proficiency testing | 4 and (proficiency testing laboratory.de. or proficiency$.ti. or external quality assessment or EQA)
6 | Limit by publication type | 5 and (research synthesis or (systematic review or meta analysis or meta-analysis).de. or ((evidence base$ or methodol$ or systematic or quantitative$ or studies).mp. and (review.de. or review.pt.)))
7 | Eliminate overlap | Remove duplicates from 6

## Part 2

The following databases have been searched for relevant information for Key Questions 4, 5, 6 and 8.

Name | Date Limits | Platform/Provider
Federal Register | Scanned throughout project | http://www.gpoaccess.gov/fr/
Healthcare Standards | Searched November 26, 2008 | www.ecri.org
Lexis-Nexis Congressional bill tracking | Searched March 4, 2008 | www.lexis.com
Lexis-Nexis Major Newspapers | Searched March 6, 2008 | www.lexis.com
National Guideline Clearinghouse™ (NGC) | Searched November 26, 2008 | www.guideline.gov

The following Web sites have been mined for information relevant to Key Questions 4, 5, 6 and 8.

Name | URL
American Association for Laboratory Accreditation | www.a2la.org
American College of Medical Genetics (ACMG) | www.acmg.net
American Society of Clinical Oncology (ASCO) | www.asco.org
Association for Molecular Pathology | www.amp.org
CanGeneTest.org | http://www.cangenetest.org/en/index.html
Centers for Disease Control and Prevention (CDC); - CLIAC; - External Quality Assessment; - Genetic testing | www.cdc.gov http://wwwn.cdc.gov/cliac/ http://wwwn.cdc.gov/mlp/eqa.aspx wwwn.cdc.gov/dls/genetics/default.aspx
Centers for Medicare and Medicaid Services (CMS) | www.cms.gov
Clinical and Laboratory Standards Institute (CLSI) National Committee of Clinical Laboratory Standards (NCCLS) | http://www.clsi.org/
College of American Pathologists (CAP) | www.cap.org
EuroGentest | www.eurogentest.org/
Eurolab | http://www.eurolab.org/
European Molecular Genetics Quality Network | http://www.emqn.org/emqn/
Food and Drug Administration (FDA); - CFR – clinical chemistry & toxicology devices; - Genomics; - Guidance - IVDMIA; - Office of In Vitro Diagnostics; - 510(k) database | www.fda.gov http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfCFR/CFRSearch.cfm?CFRPart=862 www.fda.gov/cder/genomicss/ http://www.fda.gov/ohrms/dockets/dockets/06d0347/06d0347.htm http://www.fda.gov/cdrh/oivd/
Genetics and Public Policy Center | http://www.dnapolicy.org/
International Accreditation Forum (IAF) | www.iaf.nu
International Federation of Clinical Chemistry and Laboratory Medicine (IFCC) | www.ifcc.org
International Laboratory Accreditation Collaboration | www.ilac.org
Joint Commission; - Proficiency testing | www.jointcommission.org http://www.jointcommission.org/AccreditationPrograms/LaboratoryServices/ProficiencyTesting/default.htm
National Association of Testing Authorities (NATA) | http://www.nata.asn.au/
National Health Service | www.nhs.gov
National Human Genome Research Institute | www.genome.gov
National Institute of Standards and Technology (NIST) | www.nist.gov
New Zealand Accreditation Authority | www.ianz.govt.nz/
Organisation for Economic Co-operation and Development (OECD) | www.oecd.org
Pharmacogenetics & Pharmacogenomics Knowledgebase | http://www.pharmgkb.org/
PHG Foundation | http://www.phgfoundation.org/pages/work.htm
Standards Council of Canada (SCC) | www.scc.ca/en/
UNESCO | www.unesco.org
United Kingdom Accreditation Service (UKAS) | www.ukas.org
Wadsworth Center – NY Department of Health | http://www.wadsworth.org/labcert/clep/clep.html