# Smoking Cessation: A Systems Approach, A Guide for Health Care Administrators, Insurers, Managed Care Organizations, and Purchasers

Guideline Number 18

## Overview

Health care systems face the daily challenge of balancing quality of care and costs for every patient. As health care administrators, insurers (including managed care plans), and purchasers, you play a vital role in tackling the leading preventable cause of illness and death-smoking.

The purpose of this guide is to provide you with tools to make smoking cessation a priority in your organization. You can help eliminate the roadblocks to developing standard procedures for assessment and treatment of tobacco use in every health care setting. Substantive change can occur when systems and providers work in tandem.

The most successful smoking cessation programs are supported by institutional policies. They incorporate reimbursement practices, clinical and systems procedures, incentives for providers, and clinician education. Interventions by many kinds of health care providers are also powerful components of successful programs. Consider how the key points of this guide could be addressed from your particular vantage point in the system.

Supporting institution-wide smoking cessation programs can yield both short- and long-term cost savings for patients. Working to make institutional change impacts not only the health of your patients but also the quality and costs of care.

- Americans spend an estimated $50 billion annually on direct medical care for smoking-related illnesses. Lost productivity and forfeited earnings due to smoking-related disability account for another $47 billion per year.
- The average cost per smoker for effective cessation treatment is $165.61.
- Smoking cessation interventions are less costly than other routine medical interventions such as treatment of mild to moderate high blood pressure or high cholesterol and preventive medical practices such as periodic mammography.
- Smoking cessation interventions can save on costs by reducing health risks and complications for infants and young children.

## Strategies That Work

Effective smoking prevention interventions are readily available now and, if provided in a timely and effective manner, greatly reduce the smoker's risk of suffering from smoking-related disease. Following are five strategies that have been demonstrated to be effective in helping health care providers identify and treat tobacco users. Health care administrators, insurers, and purchasers each have an important role in promoting adoption of these strategies. For example, administrators can develop policies to be implemented at the office, clinic, and hospital levels; insurers, including managed care plans, can promote implementation through contract specifications, incentives, and performance expectations; and purchasers can tailor their agreements with insurers and delivery organizations to ensure that smoking cessation interventions are addressed at the delivery system level. Costs for implementing these strategies will vary among individual health plans depending on a plan's population mix, location, personnel conducting the intervention, intervention preferences of its members, and other variables such as costs for screening, advice, motivation, and counseling.

### Strategy 1. Implement a tobacco-user identification system in every clinic

#### Evidence

Screening systems that systematically identify and document smoking status result in higher rates of smoking cessation interventions by clinicians and in higher quit rates among patients who smoke. This approach increases the probability that tobacco use is consistently assessed and documented. Studies show that smoking cessation interventions involving minimal contact with health care providers-physicians, nurses, social workers, counselors, and others-even in sessions lasting as few as 3 minutes, are more effective at increasing cessation rates than no contact at all. Intensive interventions are more effective and should be used when resources permit. Health care report cards such as the Health Plan Employer Data and Information Set (HEDIS) are now mandating that managed care organizations include information documenting delivery of effective smoking cessation services.

#### Action

Implement an office-wide system that ensures that, for every patient at every clinic visit, tobacco-use status is queried and documented.

#### Strategies for Implementation

Office system change: Expand vital signs data to include tobacco use (see sample diagram below).

Responsible staff: Nurse, medical assistant, receptionist, or other individual already responsible for measuring the vital signs-no additional staff requirements. These staff must be instructed regarding the frequency and importance of this activity.

Frequency of utilization: Every visit for every patient regardless of the reason that brought the individual to the clinic. In other words, whenever health care staff collect the traditional vital signs data, they should query and document tobacco use. Repeated assessment is not necessary in the case of the adult who has never smoked or not smoked for many years, and for whom this information is clearly documented in the medical record.

System implementation steps: Preprint note paper or preprogram computer record for every patient visit to include tobacco use along with the traditional vital signs. A vital sign stamp can also be effective. Alternatives to the vital sign stamp are to place tobacco-use status stickers on all patient charts or to indicate smoking status using computer reminder systems.

Vital Signs Blood Pressure:________________________________ Pulse:________________ Weight:_________________ Temperature:__________________________________ Respiratory Rate:_______________________________ Tobacco Use: (circle one) Current Former Never

### Strategy 2. Provide education, resources, and feedback to promote provider intervention

#### Evidence

Smoking cessation interventions delivered by multiple types of health care providers (e.g., nurses, dentists, psychologists, social workers) markedly increase cessation rates compared with interventions where no provider intervenes (e.g., self-administered interventions). Results are consistent across diverse provider groups, with no clear advantage to any single provider type. To encourage provider interventions, health care administrators, insurers, and purchasers should provide both training and incentives, such as reimbursement for clinicians (see strategy 5). It is important to dedicate staff both to provide smoking cessation treatment and to assess the delivery of this treatment in staff performance evaluations.

National data suggest that, in a given visit with a clinician, most smokers are not advised to quit smoking and are not assisted with cessation. Factors that contribute to this problem include failure to (a) include smoking assessment and cessation in the performance expectations of clinicians and (b) provide clinicians with an environment that supports systematic intervention with smokers. Without supportive systems, policies, and environmental prompts, the individual clinician cannot be counted on to assess and treat tobacco use reliably.

#### Action

- Health care systems should ensure that clinicians have the knowledge and training to treat smoking, that clinicians and patients have cessation resources, and that clinicians are given feedback about their cessation practices.
- Clinical sites should communicate to staff the importance of intervening with smokers and should designate one staff person (e.g., nurse, medical assistant, or other clinician) to coordinate and deliver smoking cessation treatments.

#### Strategies for Implementation

Educate: On a regular basis, offer lectures/seminars/in-services with CME and other credit for smoking cessation treatment.

Resources: Have patient self-help materials, as well as nicotine replacement "starter kits," readily available in every exam room.

Provide feedback: Drawing on data from chart audits, electronic medical records, or computerized patient databases, evaluate the degree to which clinicians are identifying, documenting, and treating patients who smoke, and provide feedback to clinicians about their level of intervention.

Communicate to each staff member (e.g., nurse, medical assistant, or other clinician) his or her responsibilities in the delivery of smoking cessation services.

Designate a smoking cessation treatment coordinator for every clinical site.

Delineate the responsibilities of the smoking cessation coordinator, including instructing patients on the effective use of cessation treatments (e.g., nicotine replacement therapy, telephone calls to and from prospective quitters, and scheduled followup visits, especially in the immediate post-quit period).

### Strategy 3. Promote hospital policies that support and provide smoking cessation services

#### Evidence

Every hospital in the United States must now be smoke free if it is to be accredited by the Joint Commission on Accreditation of Healthcare Organizations (JCAHO). Implementing inpatient smoking cessation programs increases the rate at which hospitalized patients successfully quit. It is vital that hospitalized patients attempt to quit smoking because smoking may interfere with their recovery. Hospitalized patients may be particularly motivated to make a quit attempt for two reasons. First, the illness that resulted in their hospitalization may have been caused or exacerbated by smoking. Second, the hospital's smoke-free environment may enhance their motivation to quit. In addition, systematic, institutionalized mechanisms to identify exsmokers is a necessary first step in delivering relapse prevention messages. Furthermore, all clinicians have an important role as nonsmoking models for their patients.

#### Action

Provide smoking cessation inpatient consultation services to all smokers admitted to a hospital and to all health care personnel who smoke.

#### Strategies for Implementation

Implement a system to identify and document the tobacco-use status of all hospitalized patients.

Offer cessation treatment to all hospitalized patients who use tobacco.

Identify a clinician(s) to deliver smoking cessation inpatient consultation services for every hospital.

Reimburse providers for smoking cessation inpatient consultation services.

Expand hospital formularies to include effective smoking cessation pharmaco-therapy such as the nicotine patch and nicotine gum.

Ensure compliance with JCAHO regulations mandating that all sections of the hospital be entirely smoke free.

Educate all hospital staff regarding nicotine withdrawal, including effective treatments such as nicotine replacement therapy and counseling.

### Strategy 4. Include smoking cessation treatments as paid services in all health benefits packages

#### Evidence

Smoking cessation treatments (both pharmacotherapy and counseling) are not consistently provided as paid services for subscribers of health insurance packages. The level of coverage is particularly surprising given that studies show that physician counseling against smoking is at least as cost-effective as several other preventive medical practices, including the treatment of mild or moderate hypertension or high cholesterol.

The national health promotion and disease prevention objectives for the year 2000 as set forth in Healthy People 2000 propose to increase to 100 percent the proportion of health plans that offer treatment of nicotine addiction, such as tobacco- use cessation counseling by health care providers, tobacco-use cessation classes, prescriptions for nicotine replacement therapies, and/or other cessation services.

#### Action

Provide coverage to all insurance subscribers for effective smoking cessation treatments, including pharmaco-therapy (nicotine replacement therapy) and counseling.

#### Strategies for Implementation

Coverage: Include effective smoking cessation treatments (both pharmacotherapy and counseling) as part of the basic benefits package for all individual, group, and HMO insurance packages.

Evaluate: Include the provision of smoking cessation treatment as part of "report cards" for managed care organizations and other insurers (e.g., Health Plan Employer Data and Information Set [HEDIS]).

Educate: Inform subscribers of the availability of covered smoking cessation services and encourage patients to use these services.

### Strategy 5. Address effective smoking cessation treatment in clinician compensation agreements

#### Evidence

Primary care clinicians frequently cite insufficient insurance reimbursement as a barrier to providing preventive services such as smoking cessation treatment. Insurance coverage has been shown to increase rates of cessation services utilization and therefore increase rates of quitting. Even the presence of prepaid or discounted prescription drug benefits increases patients' receipt of prescribed nicotine gum, the duration of gum use, and smoking cessation rates. Furthermore, an 8-year insurance industry study found that reimbursing physicians for providing preventive care resulted in reported increases in exercise, seat belt use, and weight loss, as well as decreased alcohol use and a trend toward decreased smoking.

Smoking cessation treatments (both pharmaco-therapy and counseling) should be provided as paid services for subscribers of health insurance/managed care. Clinicians should be reimbursed for delivering effective smoking cessation treatments. Even if a smoker does not want to quit, clinicians are encouraged to ask questions at each visit that help the patient identify reasons to quit and barriers to quitting. Clinicians should pledge to assist the patient when he or she is ready to quit. For patients willing to attend such programs, insurers should encourage referral to intensive programs through education and incentives to primary care providers.

#### Action

Reimburse fee-for-service clinicians for delivery of effective smoking cessation treatments; include smoking cessation treatments in the defined duties of salaried clinicians.

#### Strategies for Implementation

Include smoking cessation treatment as a reimbursable activity for fee-for-service providers.

Inform fee-for-service clinicians that they will be reimbursed for using effective smoking cessation treatments with every patient who uses tobacco.

Include smoking cessation intervention in the job description and performance evaluation of salaried clinicians.

## Costs of Smoking Cessation Interventions

The following table shows the average cost for each smoking cessation intervention, assuming that the entire U.S. population over the age of 18 years would be willing to undergo anintervention to quit smoking. The cost is the total average cost per smoker and includes the costs of screening, advising, motivation, and direct intervention with and without nicotine replacement for the interventions indicated. Across all types of interventions, the estimated cost per smoker is $165.61. The cost of each intervention varies according to the amount of provider counseling, the provision of nicotine replacement therapy, and the effectiveness of the intervention.

Total cost per smoker of smoking cessation interventions with and without nicotine replacement

Intervention | Without nicotine replacement | | With transdermal nicotine | | With nicotine gum
Minimal counseling (< 3 min in duration) | | $33.20 | | $167.11 | | $172.18
Brief counseling (> 3 min to < 10 min) | | $56.48 | | $185.57 | | $192.40
Full counseling | | $94.24 | | $231.30 | | $246.34
Individual intensive counseling | | $123.19 | | $255.01 | | $271.01
Group intensive counseling (7 1-hour sessions) | | $71.83 | | $203.65 | | $219.65

Source: Cromwell J, Bartosch W, Mitchell J. The cost effectiveness of AHCPR's smoking cessation guideline. Health Economics Research, Inc. Waltham, MA. December 1996 (contract analysis under direction of AHCPR).

## For More Information

For printed copies of this guide, the complete Clinical Practice Guideline (http://text.nlm.nih.gov/ftrs/dbaccess/smkc), a Quick Reference Guide for Smoking Cessation Specialists (http://text.nlm.nih.gov/ftrs/dbaccess/smksq), a Consumer Version (available in English (http://text.nlm.nih.gov/ftrs/dbaccess/smkp) and Spanish (http://text.nlm.nih.gov/ftrs/dbaccess/smks)), or a list of other AHCPR guidelines, call toll free 800-358-9295 or write: AHCPR Publications Clearinghouse P.O. Box 8547 Silver Spring, MD 20907

These and other guidelines are available through the Internet (http://www.ahcpr.gov/clinic/). Copies of this and other brochures are free through InstantFAX, which operates all day every day. Using a fax machine equipped with a touchtone telephone, dial (301) 594-2800, push 1, and then press the start button for instructions and a list of publications.

Internet Citation: Smoking Cessation: A Systems Approach. Clinical Practice Guideline, Number 18. AHCPR Publication No. 97-0698, April 1997. Agency for Health Care Policy and Research, Rockville, MD. http://www.ahcpr.gov/clinic/smokesys.htm