# Post-Stroke Rehabilitation: Assessment, Referral, and Patient Management

Quick Reference Guide Number 16

## Attention Clinicians

The Clinical Practice Guideline on which this Quick Reference Guide for Clinicians is based was developed by a multidisciplinary, private-sector panel comprising health care professionals and a consumer representative sponsored by the Agency for Health Care Policy and Research (AHCPR). Panel members were:

- Glen E. Gresham, MD (Chair)
- Pamela W. Duncan, PT, PhD (Co-chair)
- William B. Stason, MD (Project Director)
- Harold P. Adams, Jr., MD
- Alan M. Adelman, MD, MS
- David N. Alexander, MD
- Duane S. Bishop, MD
- Leonard Diller, PhD
- Nancy E. Donaldson, RN, DNSc
- Carl V. Granger, MD
- Audrey L. Holland, PhD
- Margaret Kelly-Hayes, EdD, RN, CRRN, FAAN
- Fletcher H. McDowell, MD
- Larry Myers, MD
- Marion A. Phipps, RN, MS, CRRN
- Elliot J. Roth, MD
- Hilary C. Siebens, MD
- Gloria A. Tarvin, MSW, LSW
- Catherine Anne Trombly, ScD, OTR/L, FAOTA

An explicit, science-based methodology was employed along with expert clinical judgment to develop specific statements on assessment, referral, and patient management for post-stroke rehabilitation. Extensive literature searches were conducted and critical reviews and syntheses were used to evaluate empirical evidence and significant outcomes. Peer review and pilot testing were undertaken to evaluate the validity, reliability, and utility of the guideline in clinical practice.

This Quick Reference Guide for Clinicians presents summary points from the Clinical Practice Guideline. The latter provides a description of the guideline development process, thorough analysis and discussion of the available research, critical evaluation of the assumptions and knowledge of the field, more complete information for health care decisionmaking, consideration for patients with special needs, and references. Decisions to adopt particular recommendations from either publication must be made by practitioners in light of available resources and circumstances presented by the individual patient.

AHCPR invites comments and suggestions from users for consideration in development and updating of future guidelines. Please send written comments to: Director, Office of the Forum for Quality and Effectiveness in Health Care, AHCPR, Willco Building, Suite 310, 6000 Executive Boulevard, Rockville, MD 20852.

## Abstract

This Quick Reference Guide for Clinicians contains highlights from Post-Stroke Rehabilitation, Clinical Practice Guideline No. 16, which was developed by a multidisciplinary panel of private-sector health care providers and a consumer representative. The Quick Reference Guide for Clinicians is an example of how a clinician might implement the panel's findings and recommendations on the overall management of stroke patients who need post-stroke rehabilitation programs or services before returning to a family or other living environment. Topics include medical management of patients, systematic assessment and evaluation of patients throughout acute care and rehabilitation, referring patients to appropriate rehabilitation programs, managing the rehabilitation process, discharging patients from rehabilitation programs, and reintegrating patients into family and community environments.

## Suggested Citation

This document is in the public domain and may be used and reprinted without special permission. AHCPR appreciates citation as to source, and the suggested format is provided below:

Gresham GE, Duncan PW, Stason, WB, et al. Post-Stroke Rehabilitation: Assessment, Referral, and Patient Management. Clinical Practice Guideline. Quick Reference Guide for Clinicians, No. 16. Rockville, MD: U.S. Department of Health and Human Services, Public Health Service, Agency for Health Care Policy and Research. AHCPR Pub. No. 95-0663. May 1995.

## Purpose and Scope

Approximately 550,000 people suffer a stroke each year in the United States, and about 3 million Americans are currently living with varying degrees of disability from strokes. Brain infarctions account for about three-quarters of strokes and intracerebral or subarachnoid hemorrhages for about 15 percent. The remainder are of other or unknown causes.

Stroke frequency increases dramatically with advancing age, doubling with every decade after 55 years of age. Men experience strokes more frequently than women and African Americans more frequently than whites. Stroke mortality ranges in different reports from 17 to 34 percent in the first 30 days and from 25 to 40 percent in the first year. It has declined in recent years due to a combination of reduced stroke severity, earlier and more accurate diagnosis, and better acute care. Modifiable or potentially modifiable risk factors for stroke are hypertension, diabetes mellitus, cigarette smoking, atrial fibrillation, left ventricular hypertrophy, transient ischemic attacks, high serum cholesterol, coronary heart disease, congestive heart failure, cocaine use, obesity, and heavy alcohol consumption. Fixed or nonmodifiable risk factors for stroke are gender/sex, prior stroke, age, race, and family history.

Hemiparesis is a presenting finding in three-quarters of patients. Acute neurological impairments frequently resolve spontaneously, but persisting disabilities lead to partial or total dependence in activities of daily living (ADL) in 25 to 50 percent of stroke survivors.

The goal of this guideline is to improve the effectiveness of rehabilitation in helping individuals with disabilities from stroke to achieve the best possible functional outcomes and quality of life. The guideline addresses rehabilitation needs from the time of an acute stroke through the ensuing weeks of recovery and return to a community residence. The primary focus is on the patient with hemiparesis due to a first stroke, who participates in an interdisciplinary rehabilitation program. The guideline is intended for use by health care professionals who have primary responsibility for patients in the acute care hospital, during subsequent rehabilitation programs, and after return to a community residence.

The effects of rehabilitation may be difficult to distinguish from the spontaneous neurological recovery that typically follows a stroke, and there have been few well-controlled studies that demonstrate specific effects. Recommendations in this guideline are therefore based largely on the clinical experience of rehabilitation experts supported by scientific studies (where available).

The recommendations follow the clinical flow sequence for stroke rehabilitation shown in Figure 1. Most patients with a stroke are initially treated in a stroke unit or general medical service of an acute care hospital where they receive rehabilitation services directed at preventing complications of stroke and, as medically feasible, encouraging mobilization and resumption of self-care activities. When the patient is medically stable, screening for postacute rehabilitation is performed. Stroke survivors who recover completely will not need rehabilitation, and those who remain severely incapacitated are not likely to benefit, although some patients in this group may improve over a further period of recuperation and can be reevaluated at a later date. Between these extremes are patients with functional deficits who are candidates for either individual rehabilitation services or an interdisciplinary program. Key components of a rehabilitation program are:

- Medical management.
- Assessment, including use of selected standardized instruments.
- Rehabilitation referrals, matching patient needs and program capabilities.
- Provision of rehabilitation according to a well-defined management plan with explicit goals, measurement of progress, and adjustment of the plan or goals (as needed).
- Assistance in reintegrating the patient into the community.

Figure 1. Clinical flow diagram for stroke rehabilitation

## Medical Management

### 1. When possible, treat the acute stroke patient in a setting that provides coordinated, multidisciplinary stroke-related evaluation and services

Such settings include acute stroke units, well-staffed neurology or rehabilitation departments, or other acute hospital settings with coordinated stroke services. Studies have found improved survival and greater likelihood of returning home when acute stroke care is coordinated and multidisciplinary. This may be related to better organization of services, with an emphasis on early mobilization of the patient, and early implementation of rehabilitation interventions.

### 2. Fully document the patient's condition and clinical course in the medical record

Thorough documentation of clinical information during the acute hospitalization is essential to making appropriate rehabilitation decisions. Included are:

- Stroke etiology and areas of the brain involved.
- Type(s), severity, and trajectory of neurological deficits.
- Type(s) and severity of comorbid diseases.
- Complications and abnormal health patterns.
- Changes in clinical status (over time).
- Functional status prior to stroke.

### 3. Begin rehabilitation-oriented care immediately, and increase the patient's activity as soon as medically feasible during the acute phase

Position changes (to prevent skin breakdown) and careful range of motion exercises (to prevent contractures) should begin shortly after admission. Further mobilization should begin when medical stability is achieved, preferably within the first 24 to 48 hours. Transfer techniques should be followed closely and taught to the patient and family. As early as possible, the patient should be encouraged to participate in personal care activities and to communicate and interact with staff and other patients. Benefits of early mobilization include:

- Prevention of deep vein thrombosis (DVT), skin breakdown, contracture formation, constipation, and pneumonia.
- Better orthostatic tolerance.
- Earlier return of mental and motor function and ability to perform ADL.
- Improved morale of both patient and family.

Indications for delaying mobilization or approaching it with caution include:

- Coma or severe obtundation.
- Progressing neurological signs or symptoms.
- Subarachnoid or intracerebral hemorrhage.
- Severe orthostatic hypotension.
- Acute myocardial infarction.
- Acute DVT (until adequate anticoagulation has been achieved).

### 4. Manage general health functions throughout all stages of treatment

#### Functional health patterns

Health functions that need to be monitored and managed during acute care and rehabilitation and after the return to the community include:

- Dysphagia.
- Physicians should be alert to the possibility of dysphagia. If present, they should obtain consultation and initiate an appropriate program.
- Nutrition and hydration.
- The adequacy of intake of food and fluids should be monitored regularly.
- Bladder and bowel function.
- Persistent urinary incontinence should be evaluated to determine its etiology and cause-specific treatment provided. If possible, the use of indwelling urinary catheters should be avoided. Bowel management programs should be implemented in patients with persistent constipation or bowel incontinence.
- Sleep and rest.
- Disturbances in sleep patterns should be evaluated for their cause. Interventions may include keeping the patient active during the day, teaching relaxation techniques, and changing medications.
- Comorbid conditions.
- Symptoms and signs not clearly attributable to the stroke should be evaluated and treated as indicated.
- Acute illnesses.
- Patients who develop an acute medical illness during rehabilitation should be evaluated promptly and, if necessary, transferred to an acute care facility.

### 5. Take steps to prevent complications throughout all stages of treatment

Preventive measures should be initiated during acute care and continued throughout rehabilitation and after the return to the community. Potential complications include:

- Deep vein thrombosis (DVT) and pulmonary embolism.
- Preventive measures include early mobilization, low-dose heparin or low-molecular-weight heparin. Warfarin, intermittent pneumatic compression, and elastic stockings are also effective.
- Dysphagia and aspiration.
- Depending on the type of swallowing deficit, treatment includes training to relearn swallowing, compensatory approaches such as changes in food texture and, if necessary, a gastrostomy tube. Dysphagia frequently resolves spontaneously; however, the condition should be reassessed periodically during rehabilitation and treatments continued or adjusted as necessary.
- Skin breakdown.
- Preventive measures include daily skin inspection, gentle routine cleansing, minimizing exposure to moisture, avoidance of friction, reduction of pressure, upright sitting posture, proper nutrition/hydration, and early mobility.
- Prevention of urinary tract infections.
- If indwelling catheters are used, they should be removed as soon as possible.
- Seizures.
- Anticonvulsant medications are recommended for preventing recurrent seizures in patients with stroke who have had one or more seizures, but not for use with patients who have not had seizures.
- Falls.
- Stroke survivors are at increased risk of falls. Risk factors include problems with perceptual deficits, visual impairments, impaired communication, confusion, drug side effects, environmental hazards, mobility, balance, and coordination. The risk is increased by rehabilitation treatments aimed at increasing mobility. Risk prevention includes supervision of high-risk patients, proper seating and wheelchair modification, regular toileting, supervised transfer and ambulation, nurse call systems suited to a patient's abilities, institution-wide fall prevention programs addressing both patient and environmental risk factors, and patient and family education about preventing falls and getting up after a fall. Adequate supervision and environmental precautions should continue after the patient returns to the community.
- Spasticity and contractures.
- Methods of prevention and treatment include antispastic pattern positioning, range of motion exercises, stretching, splinting, and nerve blocks.
- Shoulder injury.
- This is a frequent cause of pain in stroke patients. Prevention emphasizes proper positioning and support as well as avoidance of overly vigorous range of motion exercises.

### 6. Take steps to prevent recurrent stroke throughout all stages of treatment

Individuals who have had a stroke are at increased risk of another stroke. Preventive measures should be taken throughout acute care and rehabilitation and after the patient returns to the community. They include:

- Identification and control of risk factors such as hypertension, cigarette smoking, diabetes mellitus, high serum cholesterol, and heavy alcohol consumption.
- Oral anticoagulants to prevent embolic strokes in patients with atrial fibrillation or prosthetic cardiac valves. These are not currently recommended for ischemic stroke not attributed to embolism from the heart.
- Aspirin or ticlopidine for prevention of recurrent stroke secondary to arterial diseases.
- Carotid endarterectomy to prevent recurrent strokes following nondisabling strokes or transient ischemic attacks (TIAs) in selected patients with carotid artery stenosis of greater than 70 percent. The effectiveness of this procedure has been demonstrated to reduce the risk of stroke in patients without previous stroke warning signs, but with greater than 60 percent stenosis of the carotid endarterectomy. The effectiveness of this procedure has not been demonstrated for lesser degrees of stenosis.
- Surgery to clip an intracranial aneurysm or resect an arteriovenous malformation.

## Patient Assessment

### 7. Systematically evaluate the patient at key stages throughout acute care and rehabilitation

A patient should be examined on admission to acute care and whenever there are questions about the person's condition. In addition, assessments should be made at the following times:

- At the time of screening for rehabilitation.
- On admission to a rehabilitation program.
- During rehabilitation (to monitor progress).
- After discharge from rehabilitation and return to a community residence.

Each of these types of assessment is described in its chronologic place in the guideline.

### 8. Use well-validated standardized measures

This guideline strongly recommends the use of well-validated, standardized instruments in evaluating stroke patients. These instruments help to ensure reliable documentation of a patient's neurological condition, levels of disability or functional independence, family support, quality of life, and progress over time. Table 1 lists recommended standardized instruments, the approximate time each requires for administration, and their major strengths and weaknesses.

Table 1. Preferred standard instruments for patient assessment in stroke

Type | Name and Source | Approximate Time to Administer | Strengths | Weaknesses
Level-of-consciousness scale | Glasgow Coma Scale[a] | 2 minutes | Simple, valid, reliable. | None observed.
Stroke deficit scales | NIH Stroke Scale [b] | 2 minutes | Brief, reliable, can be administered by non-neurologists. | Low sensitivity.
Stroke deficit scales | Canadian Neurological Scale [c] | 5 minutes | Brief, valid, reliable. | Some useful measures omitted.
Global disability scale | Rankin Scale [d,e] | 5 minutes | Good for overall assessment of disability. | Walking is the only explicit assessment criterion. Low sensitivity.
Measures of disability/activities of daily living (ADL) | Barthel Index [f] | 5-10 minutes | Widely used for stroke. Excellent validity and reliability. | Low sensitivity for high-level functioning.
Measures of disability/activities of daily living (ADL) | Functional Independence Measure (FIM) [g] | 40 minutes | Widely used for stroke. Measures mobility, ADL, cognition, functional communication. | "Ceiling" and "floor" effects.
Mental status screening | Folstein Mini-Mental State Examination [h] | 10 minutes | Widely used for screening. | Several functions with summed score. May misclassify patients with aphasia.
Mental status screening | Neurobehavioral Cognition Status Exam (NCSE) [i] | 10 minutes | Predicts gain in Barthel Index scores. Unrelated to age. | Does not distinguish right from left hemisphere. No reliability studies in stroke. No studies of factorial structure. Correlates with education.
Assessment of motor function | Fugl-Meyer [j] | 30-40 minutes | Extensively evaluated measure. Good validity and reliability for assessing sensorimotor function and balance. | Considered too complex and time-consuming by many.
Assessment of motor function | Motor Assessment Scale [k] | 15 minutes | Good, brief assessment of movement and physical mobility. | Reliability assessed only in stable patients. Sensitivity not tested.
Assessment of motor function | Motricity Index [l] | 5 minutes | Brief assessment of motor function of arm, leg, and trunk. | Sensitivity not tested.
Balance assessment | Berg Balance Assessment [m] | 10 minutes | Simple, well established with stroke patients, sensitive to change. | None observed.
Mobility assessment | Rivermead Mobility Index [n] | 5 minutes | Valid, brief, reliable test of physical mobility. | Sensitivity not tested.
Assessment of speech and language functions | Boston Diagnostic Aphasia Examination [o] | 1-4 hours | Widely used, comprehensive, good standardization data, sound theoretical rationale. | Time to administer long; half of patients cannot be classified.
Assessment of speech and language functions | Porch Index of Communicative Ability (PICA) [p] | 1/2-2 hours | Widely used, comprehensive, careful test development and standardization. | Time to administer long. Special training required to administer. Inadequate sampling of language other than one word and single sentences.
Assessment of speech and language functions | Western aphasia Battery [q] | 1-4 hours | Widely used, comprehensive. | Time to administer long. "Aphasia quotients" and "taxonomy" of aphasia not well validated.
Depression scales | Beck Depression Inventory (BDI) (BDI) [r] | 10 minutes | Widely used, easily administered. Norms available. Good with somatic symptoms. | Less useful in elderly and in patients with aphasia or neglect.High rate of false positives. Somatic items may not be due to depression.
Depression scales | Center for Epidemiologic Studies Depression (CES-D) [s] | < 15 minutes | Brief, easily administered, useful in elderly, effective for screening in stroke population. | Not appropriate for aphasic patients.
Depression scales | Geriatric Depression Scale (GDS) [t] | 10 minutes | Brief, easy to use with elderly, cognitively impaired, and those with visual or physical problems or low motivation. | High false negative rates in minor depression.
Depression scales | Hamilton Depression Scale [u] | < 30 minutes | Observer rated; frequently used in stroke patients. | Multiple differing versions compromise interobserver reliability.
Measures of instrumental ADL | PGC Instrumental Activities of Daily Living [v] | 5-10 minutes | Measures broad base of information necessary for independent living. | Has not been tested in stroke patients.
Measures of instrumental ADL | Frenchay Activities Index [w] | 10-15 minutes | Developed specifically for stroke patients; assesses broad array of activities. | Sensitivity and interobserver reliability not tested; sensitivity probably limited.
Family assessment | Family Assessment Device (FAD) [x] | 30 minutes | Widely used in stroke. Computer scoring available. Excellent validity and reliability. Available in multiple languages. | Assessment subjective; sensitivity not tested; "ceiling" and "floor" effects.
Health status/ quality of life measures | Medical Outcomes Study (MOS) 36-Item Short-Form Health Survey [y] | 10-15 minutes | Generic health status scale SF36 is improved version of SF20. Brief, can be self - administered or administered by phone or interview. Widely used in the United States. | Possible "floor" effect in seriously ill patients (especially for physical functioning), suggests it should be supplemented by an ADL scale in stroke patients.
Health status/ quality of life measures | Sickness Impact Profile (SIP) [z] | 20-30 minutes | Comprehensive and well-evaluated. Broad range of items reduces "floor" or "ceiling" effects. | Time to administer somewhat long. Evaluates behavior rather than subjective health; needs questions on well-being, happiness, and satisfaction.

[a] Teasdale G, Jennett B. Assessment of coma and impaired consciousness: a practical scale. Lancet 1974;2:81-3. Teasdale G, Murray G, Parker L, Jennett B. Adding up the Glasgow Coma Scale. Acta Neurochir 1979; Suppl 28:13-6.

[b] Brott T, Adams HP, Olinger CP, Marler JR, Barsan WG, Biller J, Spilker J, Holleran R, Eberle R, Hertzberg V, Rorick M, Moomaw CJ, Walker M. Measurements of acute cerebral infarction: a clinical examination scale. Stroke 1989;20:864-70.

[c] Cote R, Hachinski VC, Shurvell BL, Norris JW, Wolfson C. The Canadian Neurological Scale: a preliminary study in acute stroke. Stroke 1986; 17:731-7.

[d] Rankin J. Cerebral vascular accidents in patients over the age of 60. Scott Med J 1957;2:200-15.

[e] Modification of Rankin Scale: Bonita R, Beaglehole R. Recovery of motor function after stroke. Stroke 1988 Dec;19(12):1497-1500. Van Swieten JC, Koudstaal PJ, Visser MC, Schouten HJ, van Gijn J. Interobserver agreement for the assessment of handicap in stroke patients. Stroke 1988;19(5):604-7.

[f] Mahoney FI, Barthel DW. Functional evaluation: the Barthel Index. Maryland State Med J 1965;14:61-5. Wade DT, Collin C. The Barthel ADL Index: a standard measure of physical disability? Int Disabil Stud 1988;10(2):64-7.

[g] Guide for the uniform data set for medical rehabilitation (Adult FIM), version 4.0 Buffalo, NY 14214: State University of New York at Buffalo; 1993. Granger CV, Hamilton BB, Keith RA, Zielezny M, Sherwin FS. Advances in functional assessment for medical rehabilitation. Top Geriatr Rehabil 1986;1(3):59-74. Granger CV, Hamilton BB, Sherwin FS. Guide for the use of the uniform data set for medical rehabilitation. Uniform Data System for Medical Rehabilitation Project Office, Buffalo General Hospital, NY; 1986. Keith RA, Granger CV, Hamilton BB, Sherwin FS. The functional independence measure: a new tool for rehabilitation. In: Eisenberg MG, Grzesiak RC (ed.). Advances in clinical rehabilitation volume 1. New York: Springer-Verlag; 1987. p. 6-18.

[h] Folstein MF, Folstein SE, McHugh PR. "Mini-mental state." A practical method for grading the cognitive state of patients for the clinician. J Psychiatr Res 1975 Nov;12(3):189-98.

[i] Kiernan RJ, Mueller J, Langston JW, Van Dyke C. The Neurobehavioral Cognitive Status Examination: a brief but differentiated approach to cognitive assessment. Ann Intern Med 1987;107:481-5.

[j] Fugl-Meyer AR, Jaasko L, Leyman I, Olsson S, Steglind S. The post stroke hemiplegic patient. I. A method for evaluation of physical performance. Scand J Rehabil Med 1975;7:13-31.

[k] Carr JH, Shepherd RB, Nordholm L, Lynne D. Investigation of a new motor assessment scale for stroke patients. Phys Ther 1985 Feb;65(2):175-80. Poole JL, Whitney SL. Motor assessment scale for stroke patients: concurrent validity and interrater reliability. Arch Phys Med Rehabil 1988 Mar;69(3 Pt 1):195-7.

[l] Collin C, Wade D. Assessing motor impairment after stroke: a pilot reliability study. J Neurol Neurosurg Psychiatry 1990 Jul;53(7):576-9. Demeurisse G, Demol O, Robaye E. Motor evaluation in vascular hemiplegia. Eur Neurol 1980;19(6):382-9.

[m] Berg K, Maki B, Williams JI, Holliday P, Wood-Dauphinee S. Clinical and laboratory measures of postural balance in an elderly population. Arch Phys Med Rehabil 1992;73:1073-83. Berg K, Wood- Dauphinee S, Williams JI, Gayton D. Measuring balance in the elderly: preliminary development of an instrument. Physiother Can 1989;41:304-11.

[n] Collen FM, Wade DT, Robb GF, Bradshaw CM. The Rivermead Mobility Index: a further development of the Rivermead Motor Assessment. Int Disabil Stud 1991;13:50-4. Wade DT, Collen FM, Robb GP, Warlow CP. Physiotherapy intervention late after stroke and mobility. BMJ 1992 Mar 7;304(6827):609-13.

[o] Goodglass H, Kaplan E. The assessment of aphasia and related disorders. Philadelphia: Lea and Febiger; 1972. Chapter 4, Test procedures and rationale. Manual for the BDAE. Goodglass H, Kaplan E. Boston Diagnostic Aphasia Examination (BDAE). Philadelphia: Lea and Febiger; 1983.

[p] Porch B. Porch Index of Communicative Ability (PICA). Palo Alto: Consulting Psychologists Press; 1981.

[q] Kertesz A. Western Aphasia Battery. New York: Grune & Stratton; 1982.

[r] Beck AT, Ward CH, Mendelson M, Mock J, Erbaugh J. An inventory for measuring depression. Arch Gen Psychiatry 1961 June;4:561-71. Beck AT, Steer RA. Beck Depression Inventory: manual (revised edition). NY Psychological Corporation; 1987.

[s] Radloff LS. The CES-D scale: a self-report depression scale for research in the general population. J Appl Psychol Meas 1977;1:385-401.

[t] Yesavage JA, Brink TL, Rose TL, Lum O, Huang V, Adey M, Leirer VO. Development and validation of a geriatric depression screening scale: a preliminary report. J Psychiatr Res 1982-83;17(1):37-49.

[u] Hamilton M. A rating scale for depression. J Neurol Neurosurg Psychiatry 1960;23:56-62. Hamilton M. Development of a rating scale for primary depressive illness. Br J Soc Clin Psychol 1967;6:278- 96.

[v] Lawton MP. Assessing the competence of older people. In: Kent D, Kastenbaum R, Sherwood S (ed.). Research planning and action for the elderly, New York: Behavioral Publications;1972.

[w] Holbrook M, Skilbeck CE. An activities index for use with stroke patients. Age Ageing 1983 May;12(2):166-70.

[x] Epstein NB, Baldwin LM, Bishop DS. The McMaster Family Assessment Device. J Marital and Fam Ther 1983 Apr;9(2):171-80.

[y] Ware JE, Sherbourne CD. The MOS 36-Item short-form health survey (SF-36): I. Conceptual framework and item selection. Med Care 1992 Jun;30(6):473-83.

[z] Bergner M, Bobbitt RA, Carter WB, et al. The Sickness Impact Profile: development and final revision of a health status measure. Med Care 1981; 19:787-805. Instrument is available from the Health Services Research and Development Center, The Johns Hopkins School of Hygiene and Public Health, 624 North Broadway, Baltimore, MD 21205.

Note: ADL = activities of daily living. IADL = instrumental activities of daily living.

Other useful instruments for measuring disability/ADL include the following:

Katz Index of ADL. Katz S, Ford AB, Moskowitz RW, Jackson BA, Jaffe MW. Studies of illness in the aged. The index of ADL: a standardized measure of biological and psychosocial function. JAMA 1963 Sep 21:914-9. Kenny Self-Care Evaluation. Schoening HA, Iversen IA. Numerical scoring of self-care status: a study of the Kenny Self-Care Evaluation. Arch Phys Med Rehabil 1968 Apr;49(94):221-9. LORS/LAD. Carey RG, Posavac EJ. Program evaluation of a physical medicine and rehabilitation unit: a new approach. Arch Phys Med Rehabil 1978 Jul;59(7):330-7. PECS. Harvey RF, Jellinek HM. Functional performance assessment: a program approach. Arch Phys Med Rehabil 1981;62:456-61. Another useful instrument for assessing mental status is Motor Impersistence. Ben-Yishay Y, Diller L, Gerstman L, Haas A. The relationship between impersistence, intellectual function and outcome of rehabilitation in patients with left hemiplegia. Neurology 1968 Sep;18(9):852-61. Another useful instrument for assessing depression is the Zung Scale. Zung WK. A self-rating depression scale. Arch Gen Psychiatry 1965 Jan;12:63-70. Other useful instruments for measuring IADL include: OARS: Instrumental ADL. Duke University Center for the Study of Aging and Human Development. Multidimensional functional assessment: the OARS methodology. Durham, NC: Duke University; 1978. Functional Health Status. Rosow I, Breslau N. A Guttman health scale for the aged. J Gerontol 1966;21(4):556-9.

## The Rehabilitation Referral

### 9. Screen the patient for formal rehabilitation during the acute hospitalization

Screening for rehabilitation should be performed during the acute hospitalization, as soon as the patient's neurological and medical conditions permit. Its purposes are:

- To identify patients who may benefit from a formal rehabilitation program or from individual rehabilitation services.
- To guide selection of the appropriate rehabilitation program.

Needed types of information are listed in Table 2. In addition to the patient's clinical status, information about the home environment, family circumstances, and patient and family preferences regarding rehabilitation have important influences on rehabilitation decisions. The use of standardized instruments is recommended to document the extent of impairments and disabilities. They can also be The person performing the screening examination should be experienced in stroke rehabilitation and should have no direct financial interest in the referral decision. All screening information should be summarized in the medical record and provided to the rehabilitation setting at the time of referral.

Table 2. Screening for rehabilitation

- Current clinical status; - Neurological deficits.; - Comorbid diseases.; - Functional health patterns: nutrition and hydration, ability to swallow, bowel and bladder continence, skin integrity, activity tolerance, sleep patterns.; - Special emphases; - Functional status prior to stroke.; - Current functional deficits.; - Mental status and ability to learn.; - Emotional status and motivation to participate in rehabilitation.; - Functional communication.; - Physical activity endurance.; - Social and environmental factors; - Presence of spouse or significant other.; - Previous living situation.; - Ethnicity and native language.; - Adjustment of patient and family to stroke.; - Patient and family preferences for and expectations of rehabilitation.; - Extent of support by family or involved others (relationships, number, health, availability).; - Characteristics of potential postdischarge environments.; - Standardized instruments; - Stroke deficit scale.; - Measure ofdisability (ADL).; - Mental status screening test.

Note: ADL = activities of daily living.

### 10. Recommend whether the patient should receive further rehabilitation and whether this should consist of individual services or an interdisciplinary program

The decision whether to recommend rehabilitation--and whether the choice should be individual services or an interdisciplinary program--is based on information obtained during the acute hospitalization and the rehabilitation screening examination. The most important patient considerations are:

- Medical stability.
- Nature and extent of functional disabilities.
- Ability to learn.
- Physical activity endurance.

Referral criteria are:

- Patients are potential candidates for formal rehabilitation if they have one or more significant disabilities, are at least moderately stable medically, are able to learn, have enough physical endurance to sit supported for 1 hour, and are able to participate to at least some extent in active rehabilitation treatments.
- Patients are candidates for an interdisciplinary rehabilitation program if they meet the above criteria and also have significant disabilities in at least two of the following areas of function: mobility, basic ADL, bowel or bladder control, cognition, emotional functioning, pain management, swallowing, or communication.
- Patients with only a single area of disability are candidates for individual rehabilitation services but do not require an interdisciplinary program.
- Patients too impaired to participate in rehabilitation should receive appropriate supportive services, and their families should receive thorough education regarding their care.

Some patients, at first, may not be recommended for rehabilitation. With time, however, they may recover sufficiently to become candidates for rehabilitation. Providers should be alert to such opportunities.

### 11. Be familiar with local rehabilitation programs and their capabilities

Rehabilitation programs should maintain and make available information on staffing patterns, services offered, and performance. Programs vary widely, and physicians and other medical personnel who refer patients for rehabilitation should be knowledgeable about the capabilities of programs in their community. Basic rehabilitation settings are as follows:

- Hospital inpatient rehabilitation programs
- may be located in freestanding rehabilitation hospitals or may be distinct units in acute care hospitals. They are staffed by the full range of rehabilitation professionals and an interdisciplinary team provides a comprehensive rehabilitation program for each patient. Hospital inpatient rehabilitation is generally more intense than rehabilitation in other settings and requires greater physical and mental effort from the patient.
- Rehabilitation programs in nursing facilities
- vary widely in the spectrum of services they provide. Hospital-based nursing facilities are located in or adjacent to acute care hospitals. They provide rehabilitation designed primarily for patients who have the potential to improve enough during 2 or 3 weeks of treatment to become candidates for inpatient, home, or outpatient rehabilitation. Programs in community-based nursing facilities vary. Some are as comprehensive as hospital inpatient programs though usually less intense, while others are very limited.
- Outpatient rehabilitation programs
- are offered by hospital outpatient departments and freestanding outpatient facilities. They can provide either a comprehensive rehabilitation program or individual rehabilitation services. An advantage of outpatient programs is that they enable the patient to live at home while still having access to an interdisciplinary program and to rehabilitation equipment. There are also opportunities for the patient to make social contacts and obtain peer support. Though frequently more intense, day hospital programs are similar to outpatient programs. The patient spends several hours, 3 to 5 days a week, in a typical day hospital program. Availability of transportation is a prerequisite for both outpatient and day hospital programs.
- Home rehabilitation programs
- usually provide physical therapy, occupational therapy, and nursing services. Some of these programs can also provide speech therapy and social work services. Programs are expanding their capabilities, and some now provide comprehensive services including home visits by physicians and intense rehabilitation. An advantage of home rehabilitation programs is that new skills are learned in the same environment where they will be applied. An additional advantage is that many patients function better in a familiar environment.

### 12. If the patient is a candidate for interdisciplinary rehabilitation, choose an appropriate program in consultation with the patient and family

Criteria for program choice. Figure 2 shows the step-by-step process of arriving at rehabilitation recommendations on the basis of clinical and social/environmental factors. For patients who have been identified as candidates for interdisciplinary rehabilitation (see No. 10), the most important patient characteristics in choosing a program are:

- Medical stability.
- Nature and extent of functional disabilities.
- Physical activity endurance.
- Needs for assistance.
- Extent of support by family or caregivers.
- Patient and family wishes.

Figure 2. Selection of setting for rehabilitation program after hospitalization for acute stroke

Figure 2. Selection of setting for rehabilitation program after hospitalization for acute stroke [PART 1.]

Figure 2. Selection of setting for rehabilitation program after hospitalization for acute stroke [PART 2.] [a] Under special circumstances, some patients with multiple, complex, functional deficits may be appropriate for inpatient programs. Note: ADL = activities of daily living. IADL = instrumental activities of daily living.

The following are criteria for program choice:

- Patients who meet threshold criteria for an interdisciplinary program (see No. 10) and need moderate to total assistance with mobility or basic ADL are candidates for an intense rehabilitation program, if they can tolerate 3 or more hours of physically demanding rehabilitation activity each day. Otherwise, a less intense program is usually more appropriate.
- Patients who can benefit from intense rehabilitation but have complex medical problems should be treated in inpatient hospital programs that have 24-hour coverage by physicians and nurses skilled in acute medical care and rehabilitation.
- Patients who need only supervision or minimal assistance can usually be managed in home or outpatient rehabilitation programs--if the home environment and support are adequate. If not, a nursing facility program should be considered.

Need for consensus with the patient and family. In order to succeed, rehabilitation must have the full support and active participation of the patient and family. Hence, rehabilitation decisions need to be agreed on by the patient, family, treating physician, and accepting rehabilitation program to the maximum extent possible. To this end, health care providers should:

- Explain clearly the reasons for their recommendations concerning rehabilitation.
- Listen carefully to any concerns of the patient or family that might dictate a different choice.
- Point out the possibility of transfer to a different program in the future (if the patient's condition changes).

## Management of Rehabilitation

### 13. Perform a baseline assessment on admission to rehabilitation

The purposes of baseline assessment are to:

- Reaffirm the referral decision.
- Provide the information needed to develop rehabilitation goals and a rehabilitation management plan.
- Provide a baseline for monitoring progress.

Initial evaluation by a physician and a nurse should be completed on the first day of admission to an inpatient hospital or nursing facility program, and on the first visit in the case of an outpatient or home rehabilitation program. The entire assessment should be completed for most patients within 3 working days after admission to an intense hospital or nursing facility program, within 1 week of admission to a low-intensity nursing facility program, or within three visits in the case of an outpatient or home rehabilitation program. Recommended information is shown in Table 3. Suggested standardized instruments include:

- A broad-based disability/ADL scale for all patients.
- Specific measures targeting the patient's identified neurological impairments.
- A scale for assessing family functioning (if applicable).

Table 3. Baseline assessment on admission to a rehabilitation program

- Historical information; - Discharge summary from acute hospitalization.; - Complete profile from screening examination.; - General clinical assessment: neurological and medical examinations and; - selected laboratory tests; - Type(s) and severity of neurological deficits.; - Type(s) and severity of comorbid diseases.; - Complications of stroke.; - Functional health patterns: nutrition and hydration, ability to swallow, bowel and bladder function, skin integrity, activity tolerance, sleep patterns.; - Functional status prior to stroke.; - Social and environmental factors; - Presence of spouse or significant other.; - Previous living situation.; - Ethnicity and native language.; - Adjustment of patient and family to stroke.; - Patient and family preferences for and expectations of rehabilitation.; - Extent of support by family or involved others (relationships, number, health, availability).; - Characteristics of potential postdischarge environments.; - Standardized instruments; - Stroke deficit scale and mental status screening if not done as part of the screening examination.; - Impairment measures (individualized to patient's deficits):; - Motor function.; - Mobility.; - Balance.; - Language and speech.; - Measure of disability (ADL).; - Family assessment.

Note: ADL = activities of daily living.

The baseline assessment can be performed by the treating physician,nurse, and other rehabilitation professionals. It should be fully documented in the medical record.

### 14. Develop explicit rehabilitation goals and a plan for achieving them

Rehabilitation goals are derived from the baseline assessment and from the goals of the patient and family. This information then forms the basis of the rehabilitation management plan (see Figure 3). The goals should be:

- Realistic in terms of current levels of disability. Unrealistically ambitious goals set the patient up for failure and lead to excessive use of services, while goals that underestimate a patient's potential will fail to achieve the best outcome.
- Mutually agreed on by the patient, family, and rehabilitation clinicians.
- Stated in explicit, measurable terms, and documented in the medical record.

Figure 3. Development of a rehabilitation management plan

The management plan addresses both rehabilitation needs and medical problems such as complications of stroke or comorbidities. The plan includes:

- Treatment goals.
- Interventions planned to achieve the goals.
- The frequency, duration, sequencing, and intensity of interventions.

### 15. Involve the patient and family actively in rehabilitation

Patients and family members (or involved others) should participate in rehabilitation from the beginning. During formal rehabilitation programs, they should be encouraged to:

- Learn about the causes and consequences of stroke and stroke prevention.
- Learn about the goals, process, and prognosis of rehabilitation.
- Participate in setting rehabilitation goals and developing and modifying the rehabilitation management plan.
- Communicate their questions, concerns, and ideas.
- Participate in therapy sessions.

Patient and family involvement is essential to lay the groundwork for promoting independent function after formal rehabilitation ends.

### 16. Provide remedial treatment for sensorimotor deficits

Patients who have some voluntary control over movements of a weakened limb should be offered exercise and functional training activities to increase strength and motor control, relearn sensorimotor relationships, and improve functional performance.

Training should emphasize independent functioning with or without the assistance of a caregiver. Patients and their families need to accept responsibility for practice aimed at maintaining and increasing function outside scheduled therapy sessions.

Research evidence is inadequate to support recommendations regarding the following:

- Superiority of one type of exercise regimen over another.
- Use of biofeedback or functional electrical stimulation as adjuncts to functional therapy.
- Sensory retraining.

### 17. Provide compensatory training for disabilities

Patients with persistent functional deficits should be taught compensatory methods for performing important tasks and activities--using the affected limb when possible--and the unaffected limb if necessary. Compensatory treatment teaches patients to improve their mobility, perform ADL, communicate, and conduct other valued activities despite persisting motor, sensory, or other deficits.

Compensatory techniques for mobility and task performance can be supplemented by adaptive devices. Examples include:

- Lower extremity orthotic devices.
- These are needed if the ankle or knee requires stabilization.
- Other adaptive devices.
- These are needed when compensatory methods of performing a task cannot be learned or are too fatiguing.
- Wheelchairs.
- These devices should be used when deficits are too severe to permit ambulation or when the patient's physical exercise tolerance is insufficient. Wheelchair selection should be a joint decision of the patient and rehabilitation team. The selection is based on the patient's body measurements, specific needs for wheelchair modification, safety, comfort, maneuverability, and environmental considerations (e.g., door widths in the home).

### 18. Identify and, when possible, treat cognitive and perceptual deficits

Cognitive and perceptual problems affect achievement of treatment goals and the selection of interventions for other types of deficits. Deficits that preclude effective learning are a contraindication to rehabilitation. Managing less severe deficits is an intrinsic part of the rehabilitation management plan.

### 19. Maintain a high index of suspicion for depression and provide treatment

Patient depression is common after stroke:

- Minor symptoms of depression may represent a normal grieving response to the losses caused by the stroke; however, patients may respond to encouragement from others or to simple environmental changes.
- Major depression occurs in 10 to 27 percent of patients following stroke. It has been associated with higher mortality, greater disability in ADL, lower socialization and sexual functioning, and higher rates of institutionalization.

A diagnosis of depression should be considered under any of these circumstances:

- The patient persistently appears depressed.
- There is evidence of diminished interest in activities, loss of energy, loss of appetite, sleep disturbances, or agitated states.
- The patient expresses feelings of worthlessness, impaired concentration, or suicidal thoughts.

A clinical interview by a knowledgeable mental health professional is the most effective method of diagnosis. A standardized depression scale (see Table 1) may also be useful to screen for depression and to monitor responses to treatment.

Before treating depression, the clinician should ensure that depressive symptoms are not due to medications. Choice of treatment depends on the cause of depression and may involve psychotherapy, an antidepressant medication, or both. Risks of medication side effects are high in patients with strokes. Initial doses should be small when medications are used, and the patient should be monitored closely for side effects.

Other emotional disturbances noted less commonly following stroke include emotional lability, mania, delusions, hallucinations, personality changes, and obsessive-compulsive disorders. Treatment relies on behavioral approaches or medications.

### 20. Identify and treat speech and language disorders

Communication disorders occur in as many as 40 percent of stroke patients; frequently, they resolve spontaneously. If not, they need to be thoroughly evaluated so that treatment can be tailored to the underlying deficit. Persistent problems with communication can have pervasive effects on the ability to participate in rehabilitation and the quality of life.

Communication disorders include:

- Aphasia.
- This is a disorder of language comprehension, retrieval, and formulation. Patients may respond to retraining targeted at the identified deficits and to compensatory strategies for circumventing remaining problems.
- Right hemisphere communication disorders.
- These disorders include a variety of difficulties in organizing and using language. The effectiveness of treatment has not been adequately studied.
- Dysarthria and apraxia of speech.
- These are disorders that impede production of intelligible speech. Treatment is directed at the specific speech mechanisms that are disturbed. Effectiveness of treatment has not been adequately studied.21. Educate the patient, family, and caregivers.

Patients and family members or other caregivers need education about stroke and thorough training in the management of residual disabilities and general health. Topics should include:

- The etiology and effects of stroke.
- Potential complications with preventive measures, signs, and treatments.
- Prevention of recurrent strokes.
- Medications, side effects, and medication regimen.
- Exercises and task-performance techniques.
- Social and emotional functioning of patient and family or caregivers.
- Reintegration into the community after rehabilitation.

Education should be adapted to the educational and cultural background of the patient and family, the mental status of the patient, and emotional factors that may interfere with learning. Experiential learning is often more effective than didactic learning, and repetition is important.

### 22. Monitor progress

The patient's progress should be assessed regularly during rehabilitation and the results used to adjust the treatment plan.

- During an intense rehabilitation program, evaluations should be performed at least weekly in an inpatient rehabilitation facility, a nursing facility, or at home. They should be performed at least every other week during less intense nursing facility, outpatient, or home programs.
- A subset of the standardized measures administered at baseline assessment (see Table 3) should be chosen, targeting those impairments and disabilities that have been the focus of treatments during the preceding period.
- Absence of progress between two evaluations should lead to a change in regimen, transfer, or discharge (unless specific circumstances have interfered with rehabilitation).

### 23. Plan for discharge

Discharge from a rehabilitation program or transfer to a different type of program should be considered when reasonable treatment goals have been achieved or when no measurable progress is found on two successive evaluations. Discharge planning should begin on the day of admission and should be a systematic, interdisciplinary process, coordinated by only one health provider. Decisions should reflect a consensus among the patient, family/caregivers, and rehabilitation staff.

Goals of discharge planning are to identify a safe place of residence, ensure that the patient and family/caregivers are adequately trained in essential skills, and arrange for continued medical, rehabilitation, and other services.

- The ability of a stroke survivor to return home depends on the person's needs and the availability of caregiver support. If patient needs exceed caregiver capabilities, an alternative long-term placement should be considered. The proposed residence should be evaluated for safety (e.g., furniture placement, scatter rugs, and pets), accessibility, and assistance provided in making needed modifications.
- Patient and family education should focus on tasks that need to be performed by the patient and the family or caregivers after discharge and on any concerns or questions they may have.
- Continuity of services after discharge should be the responsibility of a single clinician. This individual may be the patient's previous health care provider or a rehabilitation specialist. A full report of the patient's medical condition, disability status, present treatment, and recommendations for further treatment (see Table 4) should be given to the health care provider and also to the patient or primary caregiver.

Table 4. Information to be included in discharge summary following rehabilitation

- Patient's medical history, including functional status prior to stroke and on admission to rehabilitation; - Current physical examination and clinical course including complications experienced, diagnoses, and current medical and rehabilitative treatment regimens.; - Type, intensity, and duration of interventions received during rehabilitation and functional responses to these.; - Continuing requirements for support in mobility, functional health patterns, and performance of self-care activities.; - Anticipated need for medical care and equipment.; - Cognitive, psychological, or behavioral problems experienced, their current treatments, and anticipated future problems.; - Specific recommendations for continued rehabilitation services and a "best estimate" of the functional prognosis.

Shortly before discharge, an assessment should be performed including evaluation of the patient's living environment, family/caregiver support, and other issues of concern to the patient and family. These issues may include concerns over financial resources and insurance coverage, disability entitlements, ability to drive a car, and potential for vocational rehabilitation.

## Reintegration Into the Community

### 24. Arrange for continued services

Routine followup care after discharge should give high priority to preventing recurrent stroke and complications, lowering cardiovascular risk, and preventing falls or other injuries. Continued rehabilitation services should be considered in order to:

- Help the patient maintain the gains made during the rehabilitation program.
- Build on patient and family strengths and interests to help the patient become reintegrated into the home and community.
- Identify and address any problem areas that were not evident in the rehabilitation setting.

Services should focus on areas that are high priorities for the patient and family, such as:

- Valued hobbies or recreational activities.
- Social relationships.
- Preexisting family roles.
- Vocational or volunteer activities.

Rehabilitation services should be phased out gradually to avoid a major discontinuity or a sense of abandonment.

### 25. Continue regular monitoring of progress

The period following return to the community is a high-risk one for the stroke survivor and family alike. One goal of postdischarge assessment is to identify problem areas. Types of information to be obtained are identified in Table 5. Important issues are measures of:

- Success in adapting to the living environment and functioning independently.
- Adherence to medical and rehabilitation regimens.
- Ability of the family or other caregivers to provide needed support.

Standardized instruments are recommended for assessing levels of functional independence, family functioning, and quality of life. These instruments can help in tracking the postdischarge experience over time and identifying needs for additional rehabilitation services, counseling, or other types of support for caregivers.

Table 5. Assessment after return to the community

- General; - Neurological deficits.; - Comorbid diseases.; - Stroke-related risk factors.; - Affective disorders.; - Adherence to medical and rehabilitation regimens.; - Functional health patterns: nutrition and hydration, ability to swallow, bowel and bladder continence, skin integrity,activity tolerance, sleep patterns.; - Adaptation; - Patient adaptation and functional performance.; - Family/caregiver functioning.; - Standardized instruments; - Measure of disability (ADL).; - Instrumental activities of daily living (IADL) scale.; - Family Assessment Device.; - Quality-of-life scale.

Note: ADL = activities of daily living.

The first postdischarge assessment should take place within a month after the patient's return to a community residence. Assessments should be repeated at regular intervals during at least the first year, consistent with the patient's condition, and patient and family preferences.

Assessment and followup should be the responsibility of the clinician who is coordinating medical care.

### 26. Provide support and assistance to caregivers

Help from family members or other caregivers is often critical to achieving successful long-term outcomes in individuals with disabilities; however, the burden of caregiving may be considerable and can have adverse effects on family functioning and the health of the caregiver. These effects need to be detected as early as possible so that steps can be taken to address them. To these ends:

- Evaluation of family and caregiver functioning is important. Clinicians need to be sensitive to potential problems.
- Interventions include providing practical assistance as well as counseling to treat emotional problems. Continuity with previous education or counseling services should be maintained whenever possible.
- The principal physician either should be familiar with local support groups and community social services or should refer the stroke survivor or caregiver to someone who can provide guidance to these resources. Table 6 lists major national organizations that can provide information or assistance to stroke patients and families; several of these provide assistance through local offices in many communities.

Table 6. Resources for stroke survivors and families/caregivers

ACTION 1100 Vermont Avenue NW Washington, DC 20525 Telephone: (202) 606-4855 Call for number of regional office | A Federal Agency. Sponsors older American volunteer programs. These include:; - Retired Senior Volunteer Program (RSVP). People age 55 and over are volunteers in schools, libraries, hospitals, and other community settings.; - Senior Companion Program. Volunteers (any age) provide assistance so that low-income people age 60 and over can remain in their homes.; - Foster Grandparent Program. Low-income people age 60 and over are volunteers caring for children with special needs.
Administration on Aging 330 Independence Avenue SW Washington, DC 20201 Telephone: toll-free (800) 677-1116 (Eldercare Locator Number) Call for list of community services for elders in local area | An Agency of the Department of Health and Human Services. Provides community services for people age 60 and over (and spouses, regardless of age). Services are provided by State and area agencies on aging. Services helpful to stroke survivors and families include homemaker services, Meals on Wheels (meals delivered to the home), congregate dining (group meals in a senior center or other community setting), transportation, senior center activities, and information and referrals.
AHA Stroke Connection (formerly the Courage Stroke Network) American Heart Association 7272 Greenville Avenue, Dallas, TX 75231-4596, Telephone: toll-free (800) 553-6321 Or, check telephone book for local AHA office | Operates through national office and through local American Heart Association offices. Provides:; - Educational books, pamphlets, videos, and tapes about stroke for stroke survivors and for families and caregivers.; - Referral to stroke clubs or other self-help groups in stroke survivor's local area.; - Help in starting stroke clubs and other self-help groups.; - Stroke Connection newsletter for stroke survivors and caregivers.; - Stroke of Luck newsletter for stroke survivors with aphasia and caregivers.
American Dietetic Association/National Center for Nutrition and Dietetics 216 West Jackson Boulevard Chicago, IL 60606-6995 Telephone: toll-free (800) 366-1655 (Consumer Nutrition Hotline) | Promotes optimal nutrition, health, and well-being for consumers through its various programs and services:; - Consumers may speak to a registered dietitian for answers to nutrition questions, or obtain a referral to a local registered dietitian.
American Self-Help Clearinghouse, St. Clares-Riverside Medical Center Denville, NJ 07834 Telephone: (201) 625-7101 Call for name and number of State of local clearinghouse National Aphasia Association P.O. Box 1887 Murray Hill Station New York, NY 10156-0611 Telephone: toll-free (800) 922-4622 | Operates through State and local clearinghouses. Provides information on local self-help groups and assistance in starting a self-help group. Operates through national office and local affiliates and promotes national awareness. Provides:; - Educational books and pamphlets about aphasia.; - Referral to community services.
National Easter Seal Society 230 West Monroe Street, Suite 1800 Chicago, IL 60606 Telephone: (312) 726-6200 Or, check telephone book for local Easter Seal Society | Provides information and services to help people with disabilities, including those from stroke. Operates through national office and local Easter Seal Societies. Provides:; - Educational books, pamphlets, and audiovisual aids about disabilities.; - Posters and other publicity to educate the public about people with disabilities.; - Rehabilitation services including physical, occupational, and speech therapy.; - Guidance about assistive devices (such as wheelchairs). Vocational evaluation, training, and placement.; - Recreational and social services.; - Catalog of publications and products.
National Stroke Association 8480 East Orchard Road, Suite 1000 Englewood, CO 80111-5015 Telephone: (303) 771-1700 Toll-free (800) STROKES (787-6537) | Promotes stroke prevention, treatment, rehabilitation, family support, and research. Provides:; - Educational books, pamphlets, and audiovisual materials about stroke for stroke survivors, families, and caregivers.; - Information on local stroke clubs and other self-help groups.; - Support for stroke research.; - Training programs about stroke for health care professionals.; - Be Stroke Smart newsletter for stroke survivors, families/caregivers, and health care professionals.
Rosalynn Carter Institute Georgia Southwestern College 600 Simmons Street Americus, GA 31709 | Provides information on caregiving. Reading lists, video products, and other caregiver resources are available by writing to the address listed at left.
Stroke Clubs International 805 12th Street Galveston, TX 77550 Telephone: (409) 762-1022 | Run by stroke survivors. Promotes hiring of people with disabilities. Provides lists of stroke clubs in each State.
The Well Spouse Foundation P.O. Box 801 New York, NY 10023 Telephone: (212) 724-7209 Toll-free (800) 838-0879 | Provides support for the husbands, wives, and partners of people who are chronically ill or disabled. Provides bimonthly newsletter, regional support groups, pen pal system, and an advocacy program.

## Availability of Guidelines

For each clinical practice guideline developed under the sponsorship of the Agency for Health Care Policy and Research (AHCPR), several versions are produced to meet different needs.

Clinical Practice Guideline presents recommendations for health care providers with brief supporting information, tables and figures, and pertinent references.

Quick Reference Guide for Clinicians is a distilled version of the Clinical Practice Guideline, with summary points for ready reference on a day-to-day basis.

Consumer Version, available in English and Spanish, is an information booklet for the general public to increase patient knowledge and involvement in health care decisionmaking.

Single copies of the Clinical Practice Guideline are available for sale from the Government Printing Office, Superintendent of Documents, Washington, DC 20402, with a 25-percent discount given for bulk orders of 100 copies or more. The Quick Reference Guide for Clinicians and the Consumer Version in English are also available for sale in bulk quantities only. Call (202) 512-1800 for price and ordering information.

The Guideline Technical Report contains complete supporting materials for the Clinical Practice Guideline, including background information, methodology, literature review, scientific evidence tables, recommendations for research, and a comprehensive bibliography. It is available from the National Technical Information Service, 5285 Port Royal Road, Springfield, VA 22161. Call (703) 487-4650 for price and ordering information.

The full text of guideline documents for online retrieval may be accessed through a free electronic service from the National Library of Medicine called HSTAT (Health Services/Technology Assessment Text). Guideline information is also available through some of the computer-based information systems of the National Technical Information Service, professional associations, nonprofit organizations, and commercial enterprises.

A fact sheet describing Online Access for Clinical Practice Guidelines (AHCPR Publication No. 94-0075) and copies of the Quick Reference Guide for Clinicians and the Consumer Version of each guideline are available through AHCPR's InstantFAX, a fax-on-demand service that operates 24 hours a day, 7 days a week. AHCPR's InstantFAX is accessible to anyone using a facsimile machine equipped with a touchtone telephone handset: Dial (301) 594-2800, push "1," and then press the facsimile machine's start button for instructions and a list of currently available publications.

- U.S. Department of Health and Human Services Public Health Service Agency for Health Care Policy and Research
- Executive Office Center, Suite 501 2101 East Jefferson Street Rockville, MD 20852
- AHCPR Publication No. 95-0663, May 1995.

## Selected Bibliography

Brandstater M, Basmajian J. Stroke rehabilitation, Baltimore,, MD:. Williams & Wilkins; 1987
Depression Guideline Panel. Depression in primary care: Vol. 2. Treatment of major depression. Clinical Practice Guideline, Number 5. Rockville, MD: U.S. Department of Health and Human Services, Public Health Service, Agency for Health Care Policy and Research. AHCPR Publication No. 93-0551. April 1993.
Dombovy ML, Basford JR, Whisnant JP, Bergstralh EJ. Disability and use of rehabilitation services following stroke in Rochester, Minnesota, 1975-1979 Stroke 1987 Sep-Oct 18(5):830 6 3629639
Evans RL, Matlock AL, Bishop DS, Stranahan S, Pederson C. Family intervention after stroke: does counseling or education help? Stroke 1988 Oct 19(10):1243 9 3176084
Garraway WM, Akhtar AJ, Prescott RJ, Hockey L. Management of acute stroke in the elderly: preliminary results of a controlled trial BMJ 1980 Apr 12 280(6220):1040 3 6996779
Garraway WM, Akhtar AJ, Hockey L, Prescott RJ. Management of acute stroke in the elderly: followup of a controlled trial. BMJ. 1980 Sep 27;281:827-9. [pmid: 7000279].
Gelber DA, Good DC, Laven LJ, Verhulst SJ. Causes of urinary incontinence after acute hemispheric stroke Stroke 1993 24(3):378 82 8446973
Gresham GE, Phillips TF, Wolf PA, McNamara PM, Kannel WB, Dawber TR. Epidemiologic profile of long-term stroke disability: the Framingham Study Arch Phys Med Rehabil 1979 60(11):487 91 508073
Indredavik B, Bakke F, Solberg R, Rokseth R, Haaheim LL, Holme I. Benefit of a stroke unit: a randomized controlled trial Stroke 1991 Aug 22(8):1026 31 1866749
Jongbloed L. Prediction of function after stroke: a critical review Stroke 1986 Jul-Aug 17(4):765 76 3526649
Kalra L, Dale P, Crome P. Improving stroke rehabilitation. Stroke. 1993;24:1462-7. [pmid: 8378947].
National Association of Rehabilitation Facilities. Medical rehabilitation: what is it and where is it?, Washington, DC;November 1988
Robinson RG, Bolduc PL, Price TR. A two-year longitudinal study of post-stroke mood disorders: diagnosis and outcome at one and two years Stroke 1987 Sep-Oct 18(5):837 43 3629640
Smith DS, Goldenberg E, Ashburn A, Kinsella G, Sheikh K, Brennan PJ, Meade TW, Zutshi DW, Perry JD, Reeback JS. Remedial therapy after stroke: a randomised controlled trial BMJ (Clin Res) 1981 Feb 14 282(6263):517 20
Sunderland A, Tinson DJ, Bradley EL, Fletcher D, Langton-Hewer R, Wade DT. Enhanced physical therapy improves recovery of arm function after stroke. A randomised controlled trial J Neurol Neurosurg Psychiatry 1992 Jul 55(7):530 5 1640226 489160
Sunderland A, Tinson DJ, Bradley EL, Fletcher D, Langton-Hewer R, Wade DT. Enhanced physical therapy for arm function after stroke: a one year followup study. J Neurol Neurosurg Psychiatry. 1994;57:856-8. [pmid: 8021679]. [pmcid: 1073035].
Wade DT. In: Stevens A, Raftery J, editors. Health care needs assessment. The epidemiologically based needs assessment reviews. Volume 1, Oxford: Radcliffe Medical Press; 1994. p. 111 255
Wade DT. Measurement in neurological rehabilitation, Oxford: Oxford University Press; 1992
Wertz RT, Collins MJ, Weiss D, Kurtzke JF, Friden T, Brookshire RH, Pierce J, Holtzapple P, Hubbard DJ, Porch BE, West JA, Davis L, Matovitch V, Morley GK, Resurrection E. Veterans Administration cooperative study on aphasia: a comparison of individual and group treatment. J Speech Hear Res. 1981;24:580-94. [pmid: 6173512].
Wertz RT, Weiss DG, Aten JL, Brookshire RH, Garcia-Bunuel L, Holland AL, Kurtzke JF, LaPointe LL, Milianti FJ, Brannegan R, et al. Comparison of clinic, home, and deferred language treatment for aphasia. A Veterans Administration Cooperative Study Arch Neurol 1986 Jul 43(7):653 8 3524513
Wolf SL, Lecraw DE, Barton LA, Jann BB. Forced use of hemiplegic upper extremities to reverse the effect of learned nonuse among chronic stroke and head-injured patients Exp Neurol 1989 May 104(2):125 32 2707361
World Health Organization (WHO). International classification of impairments, disabilities, and handicaps (ICDIDH), Geneva; 1980