# Managing Otitis Media with Effusion in Young Children

Quick Reference Guideline Number 12

## Attention Clinicians

The Quick Reference Guide for Clinicians, Managing Otitis Media with Effusion in Young Children , was developed by the American Academy of Pediatrics under contract with the Agency for Health Care Policy and Research (AHCPR) and in consortium with the American Academy of Family Physicians and the American Academy of Otolaryngology Head and Neck Surgery (the "Consortium"). With AHCPR approval, the Consortium convened an interdisciplinary, non-Federal panel comprising health care professionals and a consumer representative.

Panel members were:

- Sylvan E. Stool, MD (Co-chair)
- Alfred O. Berg, MD, MPH (Co-chair)
- Stephen Berman, MD
- Cynthia J. Carney
- James R. Cooley, MD
- Larry Culpepper, MD, MPH
- Roland D. Eavey, MD
- Lynne V. Feagans, PhD
- Terese Finitzo, PhD, CCC/A
- Ellen Friedman, MD
- Janice A. Goertz, RN, BS, CPNP
- Allan J. Goldstein, MD
- Kenneth M. Grundfast, MD
- Douglas G. Long, MD
- Loretta L. Macconi, RN, MSN,CRNP
- LoBirtha Melton, RN, BSN, MPA
- Joanne Erwick Roberts, PhD, CCC-SLP & AUD
- Jessie L. Sherrod, MD, MPH
- Jane E. Sisk, PhD

For a description of the guideline development process and information about the sponsoring agency (AHCPR), see the Clinical Practice Guideline, Otitis Media with Effusion in Young Children (AHCPR Publication No. 94 0622). To receive copies of the Clinical Practice Guideline , as well as this Quick Reference Guide for Clinicians, Managing Otitis Media with Effusion in Young Children (AHCPR Publication No. 94 0623) and Middle Ear Fluid in Children: Parent Guide (AHCPR Publication No. 94 0624), call toll free 800-358-9295 or write the AHCPR Publications Clearinghouse, P.O. Box 8547, Silver Spring, MD 20907.

AHCPR invites comments and suggestions from users for consideration in development and updating of future guidelines. Please send written comments to Director, Office of the Forum for Quality and Effectiveness in Health Care, AHCPR, Willco Building, Suite 310, 6000 Executive Boulevard, Rockville, MD 20852.

## Purpose and Scope

Otitis media (inflammation of the middle ear) is the most frequent primary diagnosis at visits to U.S. physician offices by children younger than 15 years. Otitis media particularly affects infants and preschoolers: almost all children experience one or more episodes of otitis media before age 6.

The American Academy of Pediatrics, the American Academy of Family Physicians, and the American Academy of Otolaryngology Head and Neck Surgery, with the review and approval of the Agency for Health Care Policy and Research of the U.S. Department of Health and Human Services, convened a panel of experts to develop a guideline on otitis media for providers and consumers of health care for young children. Providers include primary care and specialist physicians, professional nurses and nurse practitioners, physician assistants, audiologists, speech-language pathologists, and child development specialists. Because the term otitis media encompasses a range of diseases, from acute to chronic and with or without symptoms, the Otitis Media Guideline Panel narrowed the topic. Two types of otitis media often encountered by clinicians were considered:

- Acute otitis media -- fluid in the middle ear accompanied by signs or symptoms of ear infection (bulging eardrum usually accompanied by pain; or perforated eardrum, often with drainage of purulent material).
- Otitis media with effusion -- fluid in the middle ear without signs or symptoms of ear infection.

The Clinical Practice Guideline, Otitis Media with Effusion in Young Children , and this Quick Reference Guide for Clinicians, Managing Otitis Media with Effusion in Young Children , based on the Guideline , discuss only otitis media with effusion. Further, the Guideline and this Quick Reference Guide narrow their discussion of the identification and management of otitis media with effusion to a very specific "target patient":

- A child age 1 through 3 years.
- With no craniofacial or neurologic abnormalities or sensory deficits.
- Who is healthy except for otitis media with effusion.

When the scientific evidence for management permitted, Guideline recommendations were broadened to include older children.

## Highlights of Patient Management

Congenital or early onset hearing impairment is widely accepted as a risk factor for impaired speech and language development. In general, the earlier the hearing problem begins and the more severe it is, the worse its effects on speech and language development. Because otitis media with effusion is often associated with a mild to moderate hearing loss, most clinicians have been eager to treat the condition to restore hearing to normal and thus prevent any long-term problems.

Studies of the effects of otitis media with effusion on hearing have varied in design and have examined several aspects of hearing and communication skills. Because of these differences, the results cannot be combined to provide a clear picture of the relationship between otitis media with effusion and hearing. Also, it is uncertain whether changes in hearing due to middle ear fluid have any long-term effects on development. Evidence of dysfunctions mediated by otitis media with effusion that have persisted into later childhood, despite resolution of the middle ear fluid and a return to normal hearing, would provide a compelling argument for early, decisive intervention. There is, however, no consistent, reliable evidence that otitis media with effusion has such long-term effects on language or learning.

The following recommendations for managing otitis media with effusion are tempered by the failure to find rigorous, methodologically sound research to support the theory that untreated otitis media with effusion results in speech/language delays or deficits.

Recommendations and options were developed for the diagnosis and management of otitis media with effusion in otherwise healthy young children. The following steps parallel the management algorithm provided at the end of this booklet.

### Diagnosis and Hearing Evaluation

#### 1. Suspect otitis media with effusion in young children

Most children have at least one episode of otitis media with effusion before entering school. Otitis media with effusion may be identified following an acute episode of otitis media, or it may be an incidental finding. Symptoms may include discomfort or behavior changes.

#### 2. Use pneumatic otoscopy to assess middle ear status

Pneumatic otoscopy is recommended for assessment of the middle ear because it combines visualization of the tympanic membrane (otoscopy) with a test of membrane mobility (pneumatic otoscopy). When pneumatic otoscopy is performed by an experienced examiner, the accuracy for diagnosis of otitis media with effusion may be between 70 and 79 percent.

#### 3. Tympanometry may be performed to confirm suspected otitis media with effusion

Tympanometry provides an indirect measure of tympanic membrane compliance and an estimate of middle ear air pressure. The positive predictive value of an abnormal (type B, flat) tympanogram is between 49 and 99 percent; that is, as few as half of ears with abnormal tympanograms may have otitis media with effusion. The negative predictive value of this test is better the majority of middle ears with normal tympanograms will in fact be normal. Because the strengths of tympanometry (it provides a quantitative measure of tympanic membrane mobility) and pneumatic otoscopy (many abnormalities of the eardrum and ear canal that can skew the results of tympanometry are visualized) offset the weaknesses of each, using the two tests together improves the accuracy of diagnosis.

- Acoustic reflectometry has not been studied well enough for a recommendation to be made for or against its use to diagnose otitis media with effusion.
- Tuning fork tests: No recommendation is made regarding the use of tuning fork tests to screen for or diagnose otitis media with effusion, except to note that they are inappropriate in the youngest children.

#### 4. A child who has had fluid in both middle ears for a total of 3 months should undergo hearing evaluation. Before 3 months of effusion, hearing evaluation is an option

A change in hearing threshold is both a clinical outcome and a possible indicator of the presence of otitis media with effusion. Methods used to determine a child's hearing acuity will vary depending on the resources available and the child's willingness and ability to participate in testing. Optimally, air- and bone-conduction thresholds can be established for 500, 1,000, 2,000, and 4,000 Hz, and an air-conduction pure tone average can be calculated. This result should be verified by obtaining a measure of speech sensitivity. Determinations of speech reception threshold or speech awareness threshold alone may be used if the child cannot cooperate for pure tone testing. If none of the test techniques is available or tolerated by the child, the examiner should use his/her best judgment as to adequacy of hearing. In these cases, the health care provider should be aware of whether the child is achieving the appropriate developmental milestones for verbal communication.

Although hearing evaluation may be difficult to perform in young children, evaluation is recommended after otitis media with effusion has been present bilaterally for 3 months, because of the strong belief that surgery is not indicated unless otitis media with effusion is causing hearing impairment (defined as equal to or worse than 20 decibels hearing threshold level the better hearing ear.)

### Natural History

Longitudinal studies of otitis media with effusion show spontaneous resolution of the condition in more than half of children within 3 months from development of the effusion. After 3 months the rate of spontaneous resolution remains constant, so that only a small percentage of children experience otitis media with effusion lasting a year or longer. In most children, episodes of otitis media with effusion do not persist beyond early childhood. The likelihood that middle ear fluid will resolve by itself underlies the recommendations made for management of otitis media with effusion.

### Environmental Risk Factors

Scientific evidence showed that the following environmental factors may increase potential risks of getting acute otitis media or otitis media with effusion:

- Bottle-feeding rather than breast-feeding infants.
- Passive smoking.
- Group child-care facility attendance.

Because the target child for Guideline recommendations is beyond the age when the choice of breast-feeding versus bottle-feeding is an issue, this risk factor was not considered at length.

Passive smoking (exposure to another's cigarette smoke) is associated with higher risk of otitis media with effusion. Although there is no proof that stopping passive smoking will help prevent middle ear fluid, there are many health reasons for not exposing persons of any age to tobacco smoke. Therefore, clinicians should advise parents of the benefits of decreasing children's exposure to tobacco smoke.

Studies of otitis media with effusion in children cared for at home compared to those in group child-care facilities found that children in group child-care facilities have a slightly higher relative risk (less than 2.0) of getting otitis media with effusion. Research did not show whether removing the child from the group child-care facility helped prevent otitis media with effusion

### Therapeutic Interventions

#### 5. Observation OR antibiotic therapy are treatment options for children with effusion that has been present less than 4 to 6 months and at any time in children without a 20-decibel hearing threshold level or worse in the better-hearing ear

Most cases of otitis media with effusion resolve spontaneously. Meta-analysis of controlled studies showed a 14 percent increase in the resolution rate when antibiotics were given. Length of treatment in these studies was typically 10 days.

The most common adverse effects of antibiotic therapy are gastrointestinal. Dermatologic reactions may occur in 3 to 5 percent of cases; severe anaphylactic reactions are much rarer; severe hematologic, cardiovascular, central nervous system, endocrine, renal, hepatic, and respiratory adverse effects are rarer still. The potential for the development of microbial resistance is always present with antibiotics.

#### 6. For the child who has had bilateral effusion for a total of 3 months and who has a bilateral hearing deficiency (defined as a 20-decibel hearing threshold level or worse in the better-hearing ear), bilateral myringotomy with tube insertion becomes an additional treatment option. Placement of tympanostomy tubes is recommended after a total of 4 to 6 months of bilateral effusion with a bilateral hearing deficit

The principal benefits of myringotomy with insertion of tympanostomy tubes are the restoration of hearing to the pre-effusion threshold and clearance of the fluid and possible feeling of pressure. While patent and in place, tubes may prevent further accumulation of fluid in the middle ear. Although there is insufficient evidence to prove that there are long-term deleterious effects of otitis media with effusion, concern about the possibility of such effects led the panel to recommend surgery, based on their expert opinion. Tubes are available in a myriad of designs, most constructed from plastic and/or metal. Data comparing outcomes with tubes of various designs are sparse, and so there were assumed to be no notable differences between available tympanostomy tubes.

Insertion of tympanostomy tubes is performed under general anesthesia in young children. Calculation of the risks for two specific complications of myringotomy with tympanostomy tube insertion showed that tympanosclerosis might occur after this procedure in 51 percent, and postoperative otorrhea in 13 percent, of children.

A number of treatments are not recommended for treatment of otitis media with effusion in the otherwise healthy child age 1 through 3 years.

- Steroid medications are not recommended to treat otitis media with effusion in a child of any age because of limited scientific evidence that this treatment is effective and the opinion of many experts that the possible adverse effects (agitation, behavior change, and more serious problems such as disseminated varicella in children exposed to this virus within the month before therapy) outweighed possible benefits.
- Antihistamine/decongestant therapy is not recommended for treatment of otitis media with effusion in a child of any age, because review of the literature showed that these agents are not effective for this condition, either separately or together.
- Adenoidectomy is not an appropriate treatment for uncomplicated middle ear effusion in the child younger than age 4 years when adenoid pathology is not present (based on the lack of scientific evidence). Potential harms for children of all ages include the risks of general anesthesia and the possibility of excessive postoperative bleeding.
- Tonsillectomy, either alone or with adenoidectomy , has not been found effective for treatment of otitis media with effusion.
- The association between allergy and otitis media with effusion was not clear from available evidence. Thus, although close anatomic relationships between the nasopharynx, eustachian tube, and middle ear have led many experts to suggest a role for allergy management in treating otitis media with effusion, no recommendation was made for or against such treatment.
- Evidence regarding other therapies for the treatment of otitis media with effusion was sought, but no reports of chiropractic, holistic, naturopathic, traditional/indigenous, homeopathic, or other treatments contained information obtained in randomized controlled studies. Therefore, no recommendation was made regarding such other therapies for the treatment of otitis media with effusion in children.

## Treatment Outcomes

The following table summarizes the benefits and harms identified for management interventions in the target child with otitis media with effusion.

Table 1. Outcomes of treating otitis media with effusion[1]

Intervention Observation | Benefits[2] Base case. | Harms[2] Base case
Antibiotics | Improved clearance of effusion at 1 month or less, 14.0% (95% CI [3.6%,24.2%]). Possible reduction in future infections. | Nausea, vomiting, diarrhea (2%-32% depending on dose and antibiotic). Cutaneous reactions (< 5%). Numerous rare organ system effects, including very rare fatalities. Cost. Possible development of resistant strains of bacteria.
Antibiotics plus steroids | Possible improved clearance at 1 month, 25.1% (95% CI [-1.3%,49.9%]).[3] Possible reduction in future infections. | See antibiotics and steroids separately.
Steroids alone | Possible improved clearance at 1 month, 4.5% (95% CI [-11.7%, 20.6%]).[3] | Possible exacerbation of varicella. Long-term complications not established for low doses.Cost.
Antihistamine/ decongestant | Same as base case | Drowsiness and/or excitability[4] Cost.
Myringotomy with tubes | Immediate clearance of effusion in all children. Improved hearing. | Invasive procedure. Anesthesia risk. Cost. Tympanosclerosis. Otorrhea. Possible restrictions on swimming.
Adenoidectomy | Benefits for young children have not been established | Invasive procedure.[4] Anesthesia risk. Cost.
Tonsillectomy | Same as base case. | Invasive procedure.[4] Anesthesia risk. Cost.

[1]The target patient is an otherwise healthy child age 1 through 3 years with no craniofacial or neurologic abnormalities or sensory deficits.

[2] Outcomes are reported as differences from observation, which is treated as the base case. When possible, meta-analysis was performed to provide a mean and associated confidence interval (CI).

[3] Difference from base case not statistically significant.

[4] Risks were not examined in detail because no benefits were identified.

## Algorithm

The notes below are an integral part of the algorithm that follows.

### Notes to Algorithm

1. Otitis media with effusion (OME) is defined as fluid in the middle ear without signs or symptoms of infection; OME is not to be confused with acute otitis media (inflammation of the middle ear with signs of infection). The Guideline and this algorithm apply only to the child with otitis media with effusion. This algorithm assumes followup intervals of 6 weeks.
2. The algorithm applies only to a child age 1 through 3 years with no craniofacial or neurologic abnormalities or sensory deficits (except as noted) who is healthy except for otitis media with effusion. The Guideline recommendations and algorithm do not apply if the child has any craniofacial or neurologic abnormality (for example, cleft palate or mental retardation) or sensory deficit (for example, decreased visual acuity or pre-existing hearing deficit).
3. The Panel found some evidence that pneumatic otoscopy is more accurate than otoscopy performed without the pneumatic test of eardrum mobility.
4. Tympanometry may be used as confirmation of pneumatic otoscopy in the diagnosis of otitis media with effusion (OME). Hearing evaluation is recommended for the otherwise healthy child who has had bilateral OME for 3 months; before 3 months, hearing evaluation is a clinical option.
5. In most cases, otitis media with effusion (OME) resolves spontaneously within 3 months.
6. The antibiotic drugs studied for treatment of otitis media with effusion (OME) were amoxicillin, amoxicillin-clavulanate potassium, cefaclor, erythromycin, erythromycin-sulfisoxazole, sulfisoxazole, and trimethoprim-sulfamethoxazole.
7. Exposure to cigarette smoke (passive smoking) has been shown to increase the risk of otitis media with effusion (OME). For bottle-feeding versus breast-feeding and for child-care facility placement, associations were found with OME, but evidence available to the Panel did not show decreased incidence of OME with breast-feeding or with removal from child-care facilities.
8. The recommendation against tonsillectomy is based on the lack of added benefit from tonsillectomy when combined with adenoidectomy to treat otitis media with effusion in older children. Tonsillectomy and adenoidectomy may be appropriate for reasons other than otitis media with effusion.
9. The Panel found evidence that decongestants and/or antihistamines are ineffective treatments for otitis media with effusion.
10. Meta-analysis failed fo show a significant benefit for steroid medications without antibiotic medications in treating otitis media with effusion in children.

### Algorithm 1 Part 1. Algorithm for managing otitis media with effusion in an otherwise healthy child age 1 through 3 years

[image]

### Algorithm 1 Part 2. Algorithm for managing otitis media with effusion in an otherwise healthy child age 1 through 3 years

[image]

### Algorithm 1 Part 3. Algorithm for managing otitis media with effusion in an otherwise healthy child age 1 through 3 years

[image]

## Abstract

This Quick Reference Guide for Clinicians contains highlights from the Clinical Practice Guideline, Otitis Media with Effusion in Young Children . The Otitis Media Guideline Panel, a private-sector panel of health care providers, developed the Guideline after comprehensively analyzing the research literature and current scientific knowledge of the development, diagnosis, and treatment of otitis media with effusion in young children.

Specific recommendations are given for the management of otitis media with effusion in young children age 1 through 3 years with no craniofacial or neurologic abnormalities or sensory deficits. The natural history of otitis media with effusion, the functional impairments that may result from otitis media with effusion, and the difficulty of measuring the effects of medical and surgical interventions on long-term outcomes are included. The medical interventions studied involve antibiotic therapy, steroid therapy, and antihistamine/decongestant therapy. The surgical interventions studied involve myringotomy with insertion of tympanostomy tubes, adenoidectomy, and tonsillectomy. Short-term outcomes addressed are resolution of effusion and restoration of hearing.

This document is in the public domain and may be used and reprinted without special permission. AHCPR would appreciate citations as to source, and the suggested format is below:

Stool SE, Berg AO, Berman S, Carney CJ, Cooley JR, Culpepper L, Eavey RD, Feagans LV, Finitzo T, Friedman E, et al. Managing Otitis Media with Effusion in Young Children. Quick Reference Guide for Clinicians . AHCPR Publication No. 94 0623. Rockville, MD: Agency for Health Care Policy and Research, Public Health Service, U.S. Department of Health and Human Services. July 1994.

## Selected Bibliography

Black N. The aetiology of glue ear a case-control study. Int J Pediatr Otorhinolaryngol. 1985;;9(2):121-33. [pmid: 4040897].
Cantekin EI, Mandel EM, Bluestone CD, Rockette HE, Paradise JL, Stool SE, Fria TJ, Rogers KD. Lack of efficacy of a decongestant-antihistamine combination for otitis media with effusion ("secretory" otitis media) in children: results of a double-blind, randomized trial. N Engl J Med. 1983;;308(6):297-301. [pmid: 6337322].
Casselbrant ML, Brostoff LM, Cantekin EI, Flaherty MR, Doyle WJ, Bluestone CD, Fria TJ. Otitis media with effusion in preschool children. Laryngoscope. 1985 Apr;;95:428-36. [pmid: 4039020].
Etzel RA, Pattishall EN, Haley NJ, Fletcher RH, Henderson FW. Passive smoking and middle ear effusion among children in day care. Pediatrics. 1992 Aug;;90(2):228-32. [pmid: 1641287].
Friel-Patti S, Finitzo T. Language learning in a prospective study of otitis media with effusion in the first two years of life. J Speech Hear Res. 1990;;33:188-94. [pmid: 2314079].
Maw AR. Development of tympanosclerosis in children with otitis media with effusion and ventilation tubes. J Laryngol Otol. 1991;;105(8):614-7. [pmid: 1919311].
Rosenfeld RM, Mandel EM, Bluestone CD. Systemic steroids for otitis media with effusion in children. Arch Otolaryngol Head Neck Surg. 1991 Sept;;117:984-9. [pmid: 1832876].
Rosenfeld RM, Post JC. Meta-analysis of antibiotics for the treatment of otitis media with effusion. Otolaryngol Head Neck Surg. 1992;;106:378-86. [pmid: 1533027].
Teele DW, Klein JO, Rosner B; the Greater Boston Otitis Media Study Group. Middle ear disease and the practice of pediatrics. Burden during the first five years of life. JAMA. 1983 Feb 25;;249(8):1026-9. [pmid: 6823056].
Teele DW, Klein JO, Rosner B; the Greater Boston Otitis Media Study Group. Otitis media with effusion during the first three years of life and development of speech and language. Pediatrics. 1984;;74(2):282-7. [pmid: 6540437].
Toner JG, Mains B. Pneumatic otoscopy and tympanometry in the detection of middle ear effusion. Clin Otolaryngol. 1990;;15(2):121-3. [pmid: 2350887].
Williams RL, Chalmers TC, Stange KC, Chalmers FT, Bowlin SJ. Use of antibiotics in preventing recurrent acute otitis media and in treating otitis media with effusion: a meta-analytic attempt to resolve the brouhaha. JAMA. 1993 Sep 15;;270(11):1344-51. [pmid: 8141875].
Zielhuis GA, Straatman H, Rach GH, van den Broek P. Analysis and presentation of data on the natural course of otitis media with effusion in children. Int J Epidemiol. 1990 Dec;;19(4):1037-44. [pmid: 2083987].