# Heart Failure: Management of Patients with Left-Ventricular Systolic Dysfunction

Quick Reference Guideline Number 11

## Attention Clinicians

The Clinical Practice Guideline on which this Quick Reference Guide for Clinicians is based was developed by an multidisciplinary, non-Federal panel comprising health care professionals and consumer representatives. Panel members were:

- Marvin A. Konstam, MD (Co-chair)
- Kathleen Dracup, DNSc, RN (Co-chair)
- Michael B. Bottorff, PharmD
- Neil H. Brooks, MD
- Robert A. Dacey
- Sandra B. Dunbar, DSN, RN
- Anne B. Jackson, MA, RN
- Mariell Jessup, MD
- Jerry C. Johnson, MD
- Robert H. Jones, MD
- Robert J. Luchi, MD
- Barry M. Massie, MD
- Bertram Pitt, MD
- Eric A. Rose, MD
- Lewis J. Rubin, MD
- Richard F. Wright, MD

For a description of the guideline development process and information about the sponsoring agency (Agency for Health Care Policy and Research [AHCPR]), see the Heart Failure: Evaluation and Care of Patients with Left-Ventricular Systolic Dysfunction. Clinical Practice Guideline No. 11 (AHCPR Publication No. 94-0612). To receive copies of the Clinical Practice Guideline, Quick Reference Guide for Clinicians (AHCPR Publication No. 94-0613), and Patient and Family Guide (AHCPR Publication No. 94-0614), call toll-free (800) 358-9295 or write the AHCPR Publications Clearinghouse, P.O. Box 8547, Silver Spring, MD 20907.

AHCPR invites comments and suggestions from users for consideration in development and updating of future guidelines. Please send written comments to Director, Office of the Forum for Quality and Effectiveness in Health Care, AHCPR, Willco Building, Suite 310, 6000 Executive Boulevard, Rockville, MD 20852.

## Purpose and Scope

Heart failure is a clinical syndrome or condition characterized by (1) signs and symptoms of intravascular and interstitial volume overload, including shortness of breath, rales, and edema or (2) manifestations of inadequate tissue perfusion, such as fatigue or poor exercise tolerance.

Heart failure is a major public health problem. The National Heart, Lung, and Blood Institute estimates that over 2 million Americans have heart failure and that about 400,000 new cases of heart failure are diagnosed each year. Heart failure claims the lives of over 200,000 people in the United States every year. Almost 1 million hospitalizations occur each year for patients with this condition, at an estimated cost of over $7 billion. Total treatment costs for heart failure, including physician visits, drugs, and nursing home stays, were over $10 billion in 1990.

This Quick Reference Guide for Clinicians provides recommendations concerning the outpatient evaluation and care of patients with heart failure due to left-ventricular systolic dysfunction, which is the most common cause of heart failure. It does not address the management of patients with heart failure occurring despite normal ventricular systolic performance or due to surgically correctable valvular disease.

This Quick Reference Guide for Clinicians is intended for use by a broad range of health care practitioners, including family physicians, physician assistants, nurse practitioners, internists, cardiologists, cardiac surgeons, and clinical nurse specialists. Consultation is advised when patients remain symptomatic despite appropriate care or experience significant adverse effects, or when invasive management is contemplated.

The most significant recommendations in the Clinical Practice Guideline are described here. To place these recommendations in a logical framework, this publication is organized around a clinical algorithm. These recommendations are presented in a very abbreviated form. Readers should refer to the text of the Clinical Practice Guideline for supporting discussion, including citations and levels of evidence for each recommendation.

Figure 1. Clinical Algorithm for Evaluation and Care of Patients With Heart Failure

LV = left-ventricular, MI = myocardial infarction.

The clinical algorithm is not intended as a rigid pathway that must be followed in all cases. The algorithm visually shows the conceptual organization, procedural flow, decision points, and preferred management pathways discussed in the guideline.

When applied to the individual patient, this algorithm should be adapted to accommodate patient preferences and overall patient goals. Numbers in the algorithm indicate the desired sequence of diagnostic, treatment, and management decisions and interventions.

## Highlights of Patient Management

### Initial Evaluation

All patients who complain of paroxysmal nocturnal dyspnea, orthopnea, or new-onset dyspnea on exertion should undergo evaluation for heart failure unless history and physical examination clearly indicate a noncardiac cause for their symptoms, such as pulmonary disease.

Although the physical examination can provide important information about the etiology of patients' symptoms and about appropriate initial treatment, physical signs are not highly sensitive for detecting heart failure. Therefore, patients with symptoms highly suggestive of heart failure should undergo echocardiography or radionuclide ventriculography to measure left-ventricular ejection fraction (EF) (see below) even if physical signs of heart failure are absent. Patients with less specific symptoms (i.e., fatigue, lower extremity edema) should only undergo such testing if there are physical or radiographic signs of heart failure.

Conversely, many physical findings of heart failure are not highly specific. Elevated jugular venous pressure and a third heart sound are the most specific findings and are virtually diagnostic in patients with compatible symptoms. Pulmonary rales or peripheral edema are relatively nonspecific findings, however. The presence of these signs does not require measurement of left-ventricular ejection fraction if other symptoms, signs, and radiographic findings of heart failure (e.g., cardiomegaly and pulmonary vascular congestion) are absent or if they can be attributed to other causes.

Table 1 summarizes the tests that should be performed to evaluate patients with new-onset signs or symptoms of heart failure for underlying causes.

Table 1. Recommended Tests for Patients With Signs or Symptoms of Heart Failure

Test Recommendation | Finding | Suspected Diagnosis
Electrocardiogram | Acute ST-T wave changes Atrial fibrillation, other tachyarrhythmia | Myocardial ischemia Thyroid disease or heart failure due to rapid ventricular rate
| Bradyarrhythmias | Heart failure due to low heart rate
| Previous MI (e.g., Q waves) | Heart failure due to reduced left-ventricular performance
| Low voltage | Pericardial effusion
| Left-ventricular hypertrophy | Diastolic dysfunction
Complete blood count | Anemia | Heart failure due to or aggravated by decreased oxygen-carrying capacity
Urinalysis | Proteinuria | Nephrotic syndrome
| Red blood cells or cellular casts | Glomerulonephritis
Serum creatinine | Elevated | Volume overload due to renal failure
Serum albumin | Decreased | Increased extravascular volume due to hypoalbuminemia
T4 and TSH (obtain only if atrial fibrillation, evidence of thyroid disease, or patient age >65) | Abnormal T4 or TSH | Heart failure due to or aggravated by hypo/hyperthyroidism

Note: TSH = Thyroid-stimulating hormone, MI = myocardial infraction.

A variety of conditions can mimic or provoke heart failure, including pulmonary disease, myocardial infarction (MI), arrhythmias, anemia, renal failure, nephrotic syndrome, and thyroid disease. These conditions should be considered in every patient with suspected new-onset heart failure. This guideline does not address the management of patients with these conditions.

### Hospital Management

The presence or suspicion of heart failure and any of the following findings usually indicate a need for hospitalization:

- Clinical or electrocardiographic evidence of acute myocardial ischemia.
- Pulmonary edema or severe respiratory distress.
- Oxygen saturation below 90 percent (not due to pulmonary disease).
- Severe complicating medical illness (e.g., pneumonia).
- Anasarca.
- Symptomatic hypotension or syncope.
- Heart failure refractory to outpatient therapy.
- Inadequate social support for safe outpatient management.

Occasionally, patients with one of the above findings may be managed at home or in an assisted living or nursing home setting if the clinician believes it is safe to do so and adequate followup can be arranged. Heart failure is one of the most common causes for recurrent admission to hospitals, and many of these admissions may be avoidable. Readmission rates as high as 57 percent within 90 days have been reported in patients over the age of 70 years. Proper discharge planning is essential to prevent those unnecessary readmissions.

Patients with heart failure should be discharged from the hospital only when:

- Symptoms of heart failure have been adequately controlled.
- All reversible causes of morbidity have been treated or stabilized.
- Patients and caregivers have been educated about medications, diet, activity, and exercise recommendations, and symptoms of worsening heart failure.
- Adequate outpatient support and followup care have been arranged.

Patients who have been hospitalized for heart failure should be seen or contacted within 1 week of discharge to make sure that they are stable in the outpatient setting and to check their understanding of and compliance with the treatment plan. This guideline does not address management strategies specific to the hospital setting (e.g., invasive hemodynamic monitoring, intravenous dobutamine).

### Clinical Volume Overload

During initial evaluation, the clinician should determine if the patient manifests symptoms or signs of volume overload. Symptoms and signs of volume overload include orthopnea, paroxysmal nocturnal dyspnea, dyspnea on exertion, pulmonary rales, a third heart sound, jugular venous distension, hepatic engorgement, ascites, peripheral edema, and pulmonary vascular congestion or pulmonary edema on chest x-ray.

Patients suspected of heart failure with signs of significant volume overload should be started immediately on a diuretic. Patients with mild volume overload can be managed adequately on thiazide diuretics, while those with more severe volume overload should be started on a loop diuretic. Patients with severe volume overload may require intravenous loop diuretics and/or hospitalization. See "Initial Pharmacological Management" (Algorithm Node 9) for a discussion of agents and dosing.

### Left-Ventricular Function

Measurement of left-ventricular performance is a critical step in the evaluation and management of almost all patients with suspected or clinically apparent heart failure. The combined use of history, physical examination, chest radiography, and electrocardiography does not appear to be reliable in determining whether a patient's symptoms and physical findings are due to dilated cardiomyopathy, left-ventricular diastolic dysfunction, valvular heart disease, or a noncardiac etiology. Therefore, echocardiography or radionuclide ventriculography can substantially improve diagnostic accuracy.

Patients with suspected heart failure should undergo echocardiography or radionuclide ventriculography to measure left-ventricular ejection fraction (if information about ventricular function is not available from previous tests). Table 2 summarizes the advantages and disadvantages of echocardiography and radionuclide ventriculography in the evaluation of left-ventricular performance.

Table 2. Echocardiography and Radionuclide Ventriculography Compared in Evaluation of Left-Ventricular Performance

Test | Advantages | Disadvantages
Echocardiogram | Permits concomitant assessment of valvular disease, left-ventricular hypertrophy, and left-atrial size Less expensive than radionuclide ventriculography in most areas Able to detect pericardial effusion and ventricular thrombus More generally available | Difficult to perform in patients with lung disease Usually only semi-quantitative estimate of ejection fraction provided Technically inadequate in up to 18% of patients under optimal circumstances
Radionuclide ventriculogram | More precise and reliable measurement of EF Better assessment of right-ventricular function | Requires venipuncture and radiation exposure Limited assessment of valvular heart disease and left-ventricular hypertrophy

Most patients with signs and symptoms of heart failure are found to have EF's less than 40 percent. Patients with an EF of 40 percent or greater may still have heart failure on the basis of valvular disease or stiffness of the ventricular wall (diastolic dysfunction). The recommendations contained in this Quick Reference Guide for Clinicians are designed for patients with heart failure due to left-ventricular systolic dysfunction, i.e., EF's less than 35-40 percent.

Screening for arrhythmias, such as ambulatory electrocardiographic (Holter) recording, is not warranted as part of the evaluation of patients with heart failure. Patients with a history of syncope or near-syncope should be referred immediately to a cardiologist with expertise in arrhythmias.

### General Counseling

Patients with heart failure should be informed about their diagnoses including the prognosis, symptoms of worsening heart failure, and what to do if these symptoms occur. Information should also be provided concerning the benefits of regular activity, dietary restrictions, necessary medications, and the importance of compliance with recommendations. It is vital that patients understand their disease and be involved in developing the plan for their care. In addition, family members and other responsible caregivers should be included in counseling and decisionmaking sessions.

Activity. Regular exercise such as walking or cycling should be encouraged for all patients with stable heart failure. Even short periods of bedrest result in reduced exercise tolerance and aerobic capacity, muscular atrophy, and weakness. Recent studies show that patients with heart failure can exercise safely, and regular exercise may improve functional status and decrease symptoms.

An explanation of the importance of exercise can help prevent patients from becoming afraid to perform daily activities that might provoke some shortness of breath. Patients should be advised to stay as active as possible.

There is insufficient evidence at this time to recommend the routine use of formal rehabilitation programs for patients with heart failure, although patients who are anxious about exercising on their own or are dyspneic at a low work level may benefit from such programs.

Diet. Dietary sodium should be restricted to as close to 2 grams per day as possible. In no case should sodium intake exceed 3 grams daily. Alcohol use should be discouraged. Patients who drink alcohol should be advised to consume no more than one drink per day. One drink equals a glass of beer or wine, or a mixed drink or cocktail containing no more than 1 ounce of alcohol. Patients with heart failure should be advised to avoid excessive fluid intake. However, fluid restriction is not advisable unless patients develop hyponatremia. Patients should be advised to keep a diary of their daily weights and to advise the clinicians if a weight gain of 3-5 pounds or more occurs within 1 week or since the previous visit with the clinician.

Medications. Medications are prescribed for patients with heart failure for two basic reasons: (1) to reduce mortality (angiotensin-converting enzyme [ACE] inhibitors, isosorbide dinitrate/ hydralazine) and (2) to reduce symptoms and improve functional status (ACE inhibitors, diuretics, digoxin). Patients should be provided with complete and accurate information concerning the medications they are being asked to take, including the reasons the medications are being prescribed, dosing requirements, and possible side effects.

Compliance. Because noncompliance is a major cause of morbidity and unnecessary hospital admissions for heart failure, educational programs or support groups can be very helpful in the care of patients with heart failure. Noncompliance may reduce life expectancy (e.g., if patients are not taking beneficial medications) and is also a major cause of hospitalizations. Practitioners should be aware of the problem of noncompliance and its causes and should discuss the importance of compliance at followup visits and assist patients in removing barriers to compliance (e.g., cost, side effects, or complexity of the medical regimen).

Prognosis. Patients with heart failure must understand the serious implications of this diagnosis, including a 5-year mortality rate approaching 50 percent in some studies. Patients should be encouraged to complete advance directives regarding their health care preferences. Patients, families, and caregivers must be provided with the accurate information necessary to make decisions and plans for the future, while maintaining hope and emphasizing that good quality of life is still possible.

Table 3 summarizes many of the topics that should be discussed during counseling.

Table 3. Suggested Topics for Patient, Family, and Caregiver Education and Counseling

General Counseling; - Explanation of heart failure and the reason for symptoms; - Cause or probable cause of heart failure; - Expected symptoms; - Symptoms of worsening heart failure; - What to do if symptoms worsen; - Self-monitoring with daily weights; - Explanation of treatment/care plan; - Clarification of patient's responsibilities; - Importance of cessation of tobacco use; - Role of family members or other caregivers in the treatment/care plan; - Availability and value of qualified local support group; - Importance of obtaining vaccinations against influenza and pneumococcal disease
Prognosis; - Life expectancy; - Advance directives; - Advice for family members in the event of sudden death
Activity Recommendations; - Recreation, leisure, and work activity; - Exercise; - Sex, sexual difficulties, and coping strategies
Dietary Recommendations; - Sodium restriction; - Avoidance of excessive fluid intake; - Fluid restriction (if required); - Alcohol restriction
Medications; - Effects of medications on quality of life and survival; - Dosing; - Likely side effects and what to do if they occur; - Coping mechanisms for complicated medical regimens; - Availability of lower cost medications or financial assistance
Importance of Compliance With the Treatment/Care Plan

### Initial Pharmacological Management

Table 4 summarizes the usual dosing and potential adverse effects of the pharmacological agents commonly used to treat patients with heart failure.

Table 4. Medications Commonly Used for Heart Failure

Drug | Initial Dose (mg) | Target Dose (mg) | Recommended Maximal Dose (mg) | Major Adverse Reactions
Thiazide Diuretics
Hydrochlorothiazide | 25 QD | As needed | 50 QD | Postural hypotension, hypokalemia, hyperglycemia, hyperuricemia, rash. Rare severe reaction includes pancreatitis, bone marrow suppression, and anaphylaxis.
Chlorthalidone | 25 QD | As needed | 50 QD | Postural hypotension, hypokalemia, hyperglycemia, hyperuricemia, rash. Rare severe reaction includes pancreatitis, bone marrow suppression, and anaphylaxis.
Loop Diuretics
Furosemide | 10-40 QD | As needed | 240 BID | Same as thiazide diuretics.
Bumetanide | 0.5- 1.0 QD | As needed | 10 QD | Same as thiazide diuretics.
Ethacrynic acid | 50 QD | As needed | 200 BID | Same as thiazide diuretics.
Thiazide-Related Diuretic
Metalazone | 2.5[a] | As needed | 10 QD | Same as thiazide diuretics.
Potassium-Sparing Diuretics
Spironolactone | 25 QD | As needed | 100 BID | Hyperkalemia, especially if administered with ACE inhibitor; rash; gynecomastia (spironolactone only).
Triamterene | 50 QD | As needed | 100 BID | Hyperkalemia, especially if administered with ACE inhibitor; rash; gynecomastia (spironolactone only).
Amiloride | 5 QD | As needed | 40 QD | Hyperkalemia, especially if administered with ACE inhibitor; rash; gynecomastia (spironolactone only).
ACE Inhibitors
Enalapril | 2.5 BID | 10 BID | 20 BID | Hypotension, hyperkalemia, renal insufficiency, cough, skin rash, angioedema, neutropenia.
Captopril | 6.25-12.5 TID | 50 TID | 100 TID | Hypotension, hyperkalemia, renal insufficiency, cough, skin rash, angioedema, neutropenia.
Lisinopril | 5 QD | 20 QD | 40 QD | Hypotension, hyperkalemia, renal insufficiency, cough, skin rash, angioedema, neutropenia.
Quinapril | 5 BID | 20 BID | 20 BID | Hypotension, hyperkalemia, renal insufficiency, cough, skin rash, angioedema, neutropenia.
Digoxin | See pages 58-60 | See pages 58-60 | See pages 58-60 | Cardiotoxicity, confusion, nausea, anorexia, visual disturbances.
Hydralazine | 10-25 TID | 75 TID | 100 TID | Headache, nausea, dizziness, tachycardia, lupus-like syndrome.
Isosorbide Dinitrate | 10 TID | 40 TID | 80 TID | Headache, hypotension, flushing.

Note: TSH = Thyroid-stimulating hormone, MI = myocardial infraction.

Note:ACE = angiotensin-converting enzyme, BID = twice a day, QD = once a day, TID = three times a day.

Diuretics. Diuretics are extremely useful for reducing symptoms of volume overload, including orthopnea and paroxysmal nocturnal dyspnea. As noted above under "Clinical Volume Overload" (Algorithm Node 5), diuretics should be started immediately when patients present with symptoms or signs of volume overload.

Although initiation of diuretics is important in these patients, it is also important to avoid overdiuresis before starting ACE inhibitors. Volume depletion may lead to hypotension or renal insufficiency when ACE inhibitors are started or when the doses of these agents are increased to full therapeutic levels. After the ACE inhibitor is increased to full therapeutic levels, additional diuretic therapy may be necessary to optimize the patient's status.

ACE Inhibitors. Because of their beneficial effects on mortality risk and functional status, ACE inhibitors should be prescribed for all patients with left-ventricular systolic dysfunction unless specific contraindications exist (i.e., history of intolerance or adverse reactions to these agents, serum potassium >5.5, or symptomatic hypotension). Patients with contraindications to ACE inhibitors or who cannot tolerate them should be placed on isosorbide dinitrate/hydralazine.

ACE inhibitors may be considered as sole therapy in patients who present with fatigue or mild dyspnea on exertion and who do not have any signs or symptoms of volume overload. Diuretics should be added if symptoms persist in these patients despite ACE inhibitors or if volume overload develops at a later time.

Digoxin. Digoxin increases the force of ventricular contraction in patients with left-ventricular systolic dysfunction. Although physical functioning and symptoms may be improved with digoxin, its effect on mortality is not known. Digoxin should be initiated along with ACE inhibitors and diuretics in patients with severe heart failure. Patients with mild-to-moderate heart failure will often become asymptomatic on optimal doses of ACE inhibitors and diuretics; these patients do not require digoxin. Digoxin should be added to the therapeutic regimen of those patients whose symptoms persist despite optimal doses of ACE inhibitors and diuretics. Digoxin dosing and precautions are discussed in the Clinical Practice Guideline.

Anticoagulation. Routine anticoagulation is not recommended. Patients with a history of systemic or pulmonary embolism or recent atrial fibrillation should be anticoagulated to a prothrombin time ratio of 1.2-1.8 times each individual control time (International Normalization Ratio of 2.0-3.0). Although there has never been a controlled trial of anticoagulation for patients with heart failure, the risks of routine treatment, including intracranial or gastrointestinal hemorrhage, do not appear warranted given the relatively low incidence of significant thromboembolic events in this population.

### Revascularization

Coronary artery disease is currently the most common cause of heart failure in the United States, and some patients may benefit from revascularization. In particular, patients with viable myocardium subserved by substantially stenotic vessels may reasonably be expected to obtain longevity benefits and, perhaps, improved quality of life if the stenosis is successfully relieved. On the other hand, revascularization entails significant morbidity and mortality. Before studies are initiated to determine if patients are candidates for revascularization (i.e., have viable myocardium subserved by stenotic arteries), it is important to determine first if any conditions exist that may preclude intervention or that could raise the risk of revascularization above any potential benefit. These may include:

- Patient would not consider surgery or is unable to give informed consent.
- Severe comorbid diseases, especially renal failure, pulmonary disease, or cerebrovascular disease (e.g., severe stroke).
- Very low ejection fraction (i.e., <20%).
- Illnesses with a projected life expectancy less than or equal to 1 year. These include advanced cancer, severe lung or liver disease, chronic renal disease, advanced diabetes mellitus, and advanced collagen vascular disease.
- Technical factors, including previous myocardial revascularization or other cardiac procedure, history of chest irradiation, and diffuse distal coronary artery atherosclerosis.

Patients without contraindication to revascularization should be advised of the possibility of revascularization, including its potential benefits and harms.

Three parameters are important:

1. likelihood of surgically correctable lesions,
2. expected benefits of revascularization, and
3. expected risks and potential harms of revascularization.

These parameters vary depending on several factors, including whether clinical evidence of myocardial ischemia is present and the patient's general state of health.

Counseling should be based on patients' particular characteristics, particularly on an assessment of patients' risk factors for coronary artery disease. Patients can be classified into three major subgroups:

1. patients who have neither angina nor a history of myocardial infarction,
2. patients without significant angina (angina that limits exercise or occurs frequently at rest), but who have a history of MI, and
3. patients with significant angina pectoris.

#### No Angina and No MI

The likelihood of coronary disease in heart failure patients without angina or history of myocardial infarction varies depending on patient risk factors (e.g., age, sex, smoking history, hyperlipidemia, hypertension, family history of premature coronary artery disease, and diabetes).

Patients should be counseled concerning the expected benefits and risks of evaluation for ischemia, including the fact that there is no evidence from controlled trials to show that revascularization benefits heart failure patients in the absence of angina.

It is unclear whether patients without a history of MI or significant angina should be routinely evaluated for ischemia. The decision about whether to perform physiological tests for ischemia or coronary angiography should be based on a consideration of patients' risk factors for coronary artery disease and the likelihood of alternative etiologies (e.g., alcoholic cardiomyopathy).

#### No Angina and History of MI

Available evidence suggests that as many as half of patients who suffer a myocardial infarction have clinically important myocardial ischemia in areas supplied by other coronary arteries. There are no data, however, to show that revascularization of these areas is beneficial, in terms of increased life expectancy or enhanced quality of life, in the absence of angina. Nevertheless, patients with large areas of ischemia may possibly benefit from revascularization.

Patients without angina but with a history of MI should undergo a physiological test for ischemia and should undergo cardiac catheterization if ischemic regions are detected. This strategy will miss a small number of patients with false negative physiological tests. However, in view of the lack of evidence that these patients benefit from surgery, together with a consideration of the morbidity, mortality, and the cost of catheterizing all patients in this group, this drawback is considered relatively minor. Although there are a number of acceptable physiological tests for ischemia, the most widely available and accepted procedure for determining the presence of ischemic myocardium is myocardial perfusion scintigraphy, such as thallium scanning, with poststress, redistribution, and rest reinjection imaging.

#### Angina

The potential benefit of revascularization is clearest and probably greatest in individuals with severe or limiting angina or angina-equivalent (e.g., recurrent acute episodes of pulmonary edema despite appropriate medical management). Available evidence suggests that about 75 percent of heart failure patients with significant concomitant angina have operable disease. Although the three randomized trials of coronary artery bypass graft (CABG) surgery excluded patients with heart failure or severe left-ventricular dysfunction, several cohort studies and registries suggest that patients with angina and impaired left-ventricular function have improved functional status and survival if they undergo bypass surgery.

Heart failure patients without contraindications to revascularization and who have exercise-limiting angina, angina that occurs frequently at rest, or recurrent episodes of acute pulmonary edema should be advised to undergo coronary artery angiography as the initial test for significant coronary lesions. Some patients may need physiological testing for ischemia to interpret the significance of the findings from coronary artery angiography.

#### Counseling and Decision

Based on the results of physiological testing and/or cardiac catheterization, the physician should give the patient a refined estimate of the risks and benefits of revascularization. The patient can then decide if he or she desires revascularization. No data are available that address the question of how much ischemia should be present to justify the risk of revascularization for the chance of an improvement in survival. In general, patients with severely depressed ejection fractions (EF <20 PERCENT) should undergo revascularization only if large areas of ischemia are detected. patients with less severely depressed ejection fractions may be willing to risk surgery for more modest-sized ischemic areas. The lack of data in this area makes it difficult to justify revascularization for small ischemic areas, except when severe angina is present.

#### Continue Medical Management

If (1) a patient is not a candidate for revascularization, (2) studies show insufficient evidence of reversible ischemia, or (3) surgery has been performed but the patient still has residual left-ventricular dysfunction, then the medical therapy started under "Initial Pharmacological Management" (Algorithm Node 9) should be continued. As stated previously, an assessment of compliance is recommended at each visit. Use of a home health nurse or visiting nurse may be helpful for this purpose.

#### Revascularize

Coronary artery bypass grafting is the only revascularization procedure that has been shown to prolong life in patients with angina and left-ventricular dysfunction. The effect of coronary artery angioplasty on survival of heart failure patients has not been studied, nor are the risks of angioplasty in heart failure patients known at this time. The choice between CABG and angioplasty will depend on numerous considerations, including multiple technical factors (e.g., coronary anatomy), relative risk of the two procedures in individual patients, and patient preferences. A discussion of these factors lies beyond the scope of this Quick Reference Guide for Clinicians.

### Followup

Careful history and physical examination should be the main guide to determining outcomes and directing therapy. A thorough history should include questions regarding physical functioning, mental health, sleep disturbance, sexual function, cognitive function, and ability to perform usual work and social activities.

On followup visits, patients should be asked about the presence of orthopnea, paroxysmal nocturnal dyspnea, edema, and dyspnea on exertion. It is important to remember that patients are likely to experience changes in symptoms before there is evidence of deterioration by physical examination.

Patients should be encouraged to keep a record of their daily weights and to bring that record with them when visiting their practitioner. Patients should be instructed to call if they experience an unexplained weight gain greater than 3-5 pounds since their last clinical evaluation.

Family members or other caregivers can often contribute important additional information about the patient's status and compliance when asked similar questions. In some cases, it may be desirable to interview family members or other caregivers apart from the patient in order to validate the patient's report. If discrepancies do occur, additional measures need to be instituted for clarification.

In addition to questions about symptoms and activities, providers should ask about other aspects of patients' health-related quality of life, including sleep, sexual function, mental health (or outlook on life), appetite, and social activities. A worsening in any of these parameters may indicate the need to adjust therapy. To ensure optimal care for heart failure, the provider must view the disease in the broad context of the patient's life and see how the patient is coping with the disease. Consultation with psychologists, dieticians, health educators, and clinical nurse specialists may be necessary to deal with specific problems such as depression, difficulties adhering to complicated dietary or medical regimens, or poor functional status.

The Heart Failure Guideline Panel recommends against the use of other tests (e.g., echocardiography, exercise testing) for monitoring the response of heart failure patients to treatment. No data exist to suggest that the monitoring of these endpoints contributes information beyond that obtained by a careful history and physical examination. However, repeat testing may be useful in patients with a new heart murmur, a new myocardial infarction, or sudden deterioration despite compliance with medications. Repeat testing as part of the evaluation for transplantation may also be necessary.

### Additional Pharmacological Management

If patients remain symptomatic on a combination of a diuretic, an ACE inhibitor, and digoxin, they should be seen at least once by a cardiologist.

Patients with persistent volume overload despite initial medical management may require more aggressive administration of the current diuretic (e.g., intravenous administration), more potent diuretics, or a combination of diuretics.

Patients with persistent dyspnea after optimal doses of diuretics, ACE inhibitors, and digoxin should be given a trial of hydralazine and/or nitrates. The addition of a vasodilator to an ACE inhibitor may also relieve symptoms. Direct vasodilators may be particularly helpful in patients with hypertension or evidence of severe mitral regurgitation. Even patients with blood pressure in the usual normal range may benefit by reducing their blood pressure with direct vasodilators. Alternatively, if a patient primarily has symptoms of pulmonary congestion or has a low systolic blood pressure, nitrates are preferred over arterial vasodilators.

There is some evidence that gradually incremental therapy with low dose beta blockers may produce long-term improvements in symptoms and in natural history in patients with heart failure. However, because beta blockers may also cause acute deterioration in patients with heart failure, this form of treatment should be considered experimental at this time.

### Heart Transplantation

Consideration should be given to cardiac transplantation in patients with severe limitation and/or repeated hospitalization because of heart failure, despite aggressive medical therapy, and in whom revascularization is not likely to convey benefit. Patients with severe symptoms should be referred to a cardiologist to ensure that medical therapy is optimized prior to referral for possible transplantation. Practitioners should refer to existing documents concerning heart transplantation for further information on patient selection criteria.

Patients with poor systolic function whose symptoms are controlled on optimal medical management need not be referred for transplantation. Where appropriate, patients with severe symptoms uncontrolled by optimal medical management who are unable to obtain a heart transplant should be informed of the availability of experimental treatment protocols for which they may be eligible (e.g., new drugs, mechanical assist devices).

### Prevention in Patients with Left-Ventricular Systolic Dysfunction

Asymptomatic patients who are found to have moderately or severely reduced left-ventricular systolic function (ejection fraction <35-40 PERCENT) should be treated with an ACE inhibitor to reduce the chance of developing clinical heart failure.

Probably the largest number of such patients will be those who have recently sustained a myocardial infarction. For this reason, the EF should be myocardial infarction. For this reason, the EF should be determined in most patients following a myocardial infarction unless they are at low risk for significant systolic dysfunction, i.e., unless they meet all of the following criteria:

1. No previous myocardial infarction.
2. Inferior infarction.
3. Relatively small increase in cardiac enzymes (i.e., <2-4 times normal).
4. No Q waves develop on electrocardiogram.
5. Uncomplicated clinical course (e.g., no arrhythmia or hypotension).

Other asymptomatic patients without infarctions may be found to have reduced EF on evaluation of heart murmurs or cardiomegaly. These patients should also be treated with ACE inhibitors.

## Abstract

More than 2 million Americans have heart failure, and about 400,000 new cases are diagnosed each year. Mortality is high, with 5-year mortality in the range of 50 percent. Many of the almost 1 million hospitalizations each year for heart failure might be prevented by improved evaluation and care.

This Quick Reference Guide for Clinicians summarizes major recommendations in Heart Failure: Evaluation and Care of Patients with Left-Ventricular Systolic Dysfunction. Clinical Practice Guideline No. 11. The document was prepared by RAND, a nonprofit research and policy organization, and a private-sector panel of experts and consumers. Guideline recommendations are intended for use by a broad range of health care practitioners.

The guideline recommendations are based on a combination of evidence obtained through extensive literature reviews and on expert judgment where evidence was lacking. Specific recommendations are made in the following areas:

- Prevention of heart failure with asymptomatic left-ventricular systolic dysfunction.
- Approaches to diagnosis and initial evaluation of suspected heart failure.
- Hospital admission and discharge criteria.
- Pharmacological management.
- Patient counseling and education.
- Exercise and rehabilitation.
- Evaluation for myocardial revascularization.
- Patient monitoring and followup evaluation.

This document is in the public domain and may be used and reprinted without special permission. AHCPR appreciates citation as to source, and the suggested format is provided below:

Konstam M, Dracup K, Baker D, et al. Heart Failure: Management of Patients With Left-Ventricular Systolic Dysfunction. Quick Reference Guide for Clinicians No. 11. AHCPR Publication No. 94-0613. Rockville, MD: Agency for Health Care Policy and Research, Public Health Service, U.S. Department of Health and Human Services. June 1994.

## Selected References

Alderman EL, Fisher LD, Litwin P, et al. Results of coronary artery surgery in patients with poor left ventricular function (CASS). Circulation. 1983;68:785-95. [pmid: 6352078].
Arnsdorf MF, Bump TE. Management of arrhythmias in heart failure. Cardiol Clin. 1989;7:145-69. [pmid: 2650869].
Bonow RO, Udelson JE. Left ventricular diastolic dysfunction as a cause of congestive heart failure: mechanisms and management. Ann Intern Med. 1992;117:502-10. [pmid: 1503353].
Bounous EP, Mark DB, Pollock BG, et al. Surgical survival benefits for coronary disease patients with left-ventricular dysfunction. Circulation. 1988 Sep;78(3 Pt 2):I151-7. [pmid: 3261652].
The Cardiac Arrhythmia Suppression Trial (CAST) Investigators. Preliminary report: effect of encainide and flecainide on mortality in a randomized trial of arrhythmia suppression after myocardial infarction. N Engl J Med. 1989;321:406-12. [pmid: 2473403].
Chakko CS, Woska D, Martinez H, et al. Clinical, radiographic, and hemodynamic correlations in chronic congestive heart failure: conflicting results may lead to inappropriate care. Am J Med. 1991;90:353-9. [pmid: 1825901].
Christakis GT, Ivanov J, Weisel R, et al. The changing pattern of coronary artery bypass surgery. Circulation. 1989;80(3 Pt 1):I151-61. [pmid: 2788531].
Coats AJ, Adamopoulos S, Meyer TE, et al. Effects of physical training in chronic heart failure. Lancet. 1990;335(8681):63-6. [pmid: 1967416].
Cody RJ. Management of refractory congestive heart failure. Am J Cardiol. 1992;69:141G-149. [pmid: 1626487].
Cohn JN, Archibald DG, Ziesche S, et al. Effect of vasodilator therapy on mortality in chronic congestive heart failure: results of a Veterans Administration Cooperative Study. N Engl J Med. 1986;314:1547-52. [pmid: 3520315].
Cohn JN, Johnson G, Ziesche S, et al. A comparison of enalapril with hydralazine-isosorbide dinitrate in the treatment of chronic congestive heart failure. N Engl J Med. 1991;325:303-10. [pmid: 2057035].
CONSENSUS Trial Study Group. Effects of enalapril on mortality in severe congestive heart failure. N Engl J Med. 1987;316:1429-35. [pmid: 2883575].
Dougherty AH, Naccarelli GV, Gray EL, et al. Congestive heart failure with normal systolic function. Am J Cardiol. 1984;54:778-82. [pmid: 6486027].
Dracup K, Walden JA, Stevenson LW, et al. Quality of life in patients with advanced heart failure. J Heart Lung Transplant. 1992;2:273-9. [pmid: 1576133].
Dubach P, Froelicher VF. Cardiac rehabilitation for heart failure patients. Cardiology. 1989;76:368-73. [pmid: 2688876].
Echeverria HH, Bilsker MS, Myerburg RJ, et al. Congestive heart failure: echocardiographic insights. Am J Med. 1983;75:750-5. [pmid: 6638044].
Falk RH. A plea for a clinical trial of anticoagulation in dilated cardiomyopathy [editorial]. Am J Cardiol. 1990;65:14-5. [pmid: 2294677].
Fleg JL, Hinton PC, Lakatta EG, et al. Physician utilization of laboratory procedures to monitor outpatients with congestive heart failure. Arch Intern Med. 1989;149:393-6. [pmid: 2916884].
Ghali JK, Kadakia S, Cooper R, et al. Precipitating factors leading to decompensation of heart failure. Traits among urban blacks. Arch Intern Med. 1988;148:2013-6. [pmid: 3046541].
Ghali JK, Kadakia S, Cooper RS, et al. Bedside diagnosis of preserved versus impaired left-ventricular systolic function in heart failure. Am J Cardiol. 1991;67:1002-6. [pmid: 2018002].
Hannan EL, Kilburn H Jr, O'Donnell JF, et al. Adult open heart surgery in New York State. An analysis of risk factors and hospital mortality rates. JAMA. 1990 Dec 5;264:2768-74. [pmid: 2232064].
Hartzler GO, Rutherford BD, McConahay DR, et al. "High-risk" percutaneous transluminal coronary angioplasty. Am J Cardiol. 1988;61:33G-37G. [pmid: 2966564].
Jaeschke R, Oxman AD, Guyatt GH. To what extent do congestive heart failure patients in sinus rhythm benefit from digoxin therapy? A systematic overview and meta-analysis. Am J Med. 1990;88:279-86. [pmid: 2178412].
Kannel WB. Epidemiological aspects of heart failure. Cardiol Clin. 1989;7:1-9. [pmid: 2523239].
Kotler TS, Diamond GA. Exercise thallium-201 scintigraphy in the diagnosis and prognosis of coronary artery disease. Ann Intern Med. 1990;113:684-702. [pmid: 2221649].
Küpper AJ, Fintelman H, Huige MC, et al. Cross-over comparison of the fixed combination of hydrochlorothiazide and triamterene and the free combination of furosemide and triamterene in the maintenance treatment of congestive heart failure. Eur J Clin Pharmacol. 1986;30:341-3. [pmid: 3732372].
Marantz PR, Tobin JN, Wassertheil-Smoller S, et al. The relationship between left-ventricular systolic function and congestive heart failure diagnosed by clinical criteria. Circulation. 1988;77:607-12. [pmid: 3342491].
Mattleman SJ, Hakki A, Iskandrian AS, et al. Reliability of bedside evaluation in determining left-ventricular ejection fraction determined by radionuclide ventriculography. J Am Coll Cardiol. 1983;1:417-20. [pmid: 6826952].
Molgaard H, Kristensen BO, Baandrup U. Importance of abstention from alcohol in alcoholic heart disease. Int J Cardiol. 1990;26:373-5. [pmid: 2312207].
On bedresting in heart failure [editorial]. Lancet. 1990 Oct;336(8721):975-6. [pmid: 1977010].
Perlman LV, Isenberg E, Donovan I, et al. Public health nurses and the prevention of recurrences of congestive heart failure. Geriatrics. 1969;24:82-9. [pmid: 5811750].
Pfeffer MA, Braunwald E, Moyé LA, et al. Effect of captopril on mortality and morbidity in patients with left-ventricular dysfunction after myocardial infarction: results of the survival and ventricular enlargement trial. N Engl J Med. 1992;327:669-77. [pmid: 1386652].
SOLVD Investigators. Effect of enalapril on survival in patients with reduced left-ventricular ejection fractions and congestive heart failure. N Engl J Med 1991;325:293-302.
SOLVD Investigators. Effect of enalapril on mortality and the development of heart failure in asymptomatic patients with reduced left-ventricular ejection fractions. N Engl J Med 1992;327:10;685-91.
Vinson JM, Rich MW, Sperry JC, et al. Early readmission of elderly patients with congestive heart failure. J Am Geriatr Soc. 1990;38:1290-5. [pmid: 2254567].